# Risk of Bias Assessment

Table D.1 Risk of bias: Randomized controlled trials

Author, Year, PMID | 1a* | 1c* | 2a* | 2b* | 3b* | 3c* | 3d* | 3e* | 3f* | 3g* | 3h* | 4a*
Balzer, 2009, 19135837 | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low
Bax, 2009, 19414832 | Low | Low | Low | Low | Low | High | Low | High | Low | High | Low | Low
Cooper, 2014, 24245566 | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | High (multiple protocol changes)
Marcantoni, 2012, 22495466 | Unclear | Low | Low | Low | Low | Low | Low | High | Low | High | Low | Low
Scarpioni, 2009 Conference abstract | Unclear | High | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Low | Low | High | High (incomplete conference abstract)
Uzzo, 2002, 12009679 | Low | Low | Unclear | Unclear | Low | Low | Unclear | Low | Low | Low | Low | Low
Wheatley, 2009, 19907042 | Low | Low | Low | Low | Low | Low | Low | High | Low | Low | Low | High (specific interventions at physician discretion)
Zeller, 2013 Conference abstract | High | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Low | Low | High | High (data from 1 of 4 countries, terminated trial, incomplete conference abstract)
Ziakka, 2008, 19016147 | Unclear | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low

1a. Sampling: Were the subjects in the study representative of the entire population from which they were recruited?

1b. Sampling: Comparability of cohorts on the basis of the design or analysis

1c. Sampling: Group similarity at baseline (selection bias): Selection bias due to dissimilarity at baseline for the most important prognostic indicators

1d. Sampling: Selection of the comparator (Medicine) cohort

2a. Selection: Random sequence generation (selection bias): Selection bias (biased allocation to interventions) due to inadequate generation of a randomized sequence

2b. Selection: Allocation concealment (selection bias): Selection bias (biased allocation to interventions) due to inadequate concealment of allocations prior to assignment

3a. Measurement: Ascertainment of exposure

3b. Measurement: Co-interventions (performance bias): Performance bias because co-interventions were different across groups

3c. Measurement: Blinding of outcome assessor (detection bias): Detection bias due to knowledge of the allocated interventions by outcome assessors

3d. Measurement: Intention-to-treat-analysis: Bias due to incomplete reporting and analysis according to group allocation

3e. Measurement: Incomplete outcome data (attrition bias): Attrition bias due to amount, nature or handling of incomplete outcome data

3f. Measurement: Timing of outcome assessments (detection bias): Detection bias because important outcomes were not measured at the same time across groups

3g. Measurement: Do the analyses adjust for different lengths of follow-up of patients?

3h. Measurement: Selective Reporting (reporting bias): Reporting bias due to selective outcome reporting

4a. Additional Bias: Bias due to problems not covered elsewhere in the table.

Table D.2 Risk of bias: Nonrandomized comparative studies

Author, Year, PMID | Study Design | 1a* | 1b* | 1c* | 1d* | 3a* | 3b* | 3c* | 3e* | 3f* | 3g* | 3h* | 4a*
Arthurs, 2007, 17398382 | Retrospective | Low | Low | High | Low | Low | Low | Low | High | Low | Low | Low | Low
Cianci, 2011, 20547539 | Prospective | Low | High | Low | Low | N/A | Low | Low | Low | Low | Low | High | Low
Crutchley, 2009, 18951751 | Retrospective | Unclear | High | Unclear | Low | Low | Unclear | Low | High | Low | Low | Unclear | Low
de Donato, 2007, 17653002 | Prospective | Low | Low | Unclear | Low | Low | Low | High | Low | Low | Low | Low | Low
Dichtel, 2010, 20630131 | Retrospective | Low | High | Low | Low | Low | Unclear | Low | Low | High | High | Low | Low
Hackam, 2011 21156722 | Retrospective | Low | N/A | N/A | N/A | Low | N/A | N/A | Low | N/A | High | Low | Low
Hanzel, 2005, 16253607 | Retrospective | Low | High | High | Low | N/A | Low | Low | Low | Low | Low | Low | Low
Kalra, 2010, 19937777 | Prospective | Unclear | High | High | High | Low | High | Low | Low | Low | Low | Unclear | Low
Kane, 2010, 19666661 | Retrospective | Low | Low | Low | Low | Low | Low | High | Low | Low | High | Low | Low
Losito, 2005 15870215 | Prospective | Low | Low | Low | Low | N/A | Unclear | Low | Low | Low | Low | Low | Low
Patel, 2009, 19497511 | Retrospective | Low | Low | High | Low | Unclear | Unclear | Low | High | High | Low | Low | Low
Ritchie, 2014, 24074824 | Prospective | Low | Low | High | Low | Low | Low | Low | High | Low | Low | High | Low
Sofroniadou, 2012, 22127407 | Prospective | Low | High | High | Low | N/A | Low | Low | High | High | High | High | Low

1a. Sampling: Were the subjects in the study representative of the entire population from which they were recruited?

1b. Sampling: Comparability of cohorts on the basis of the design or analysis

1c. Sampling: Group similarity at baseline (selection bias): Selection bias due to dissimilarity at baseline for the most important prognostic indicators

1d. Sampling: Selection of the comparator (Medicine) cohort

2a. Selection: Random sequence generation (selection bias): Selection bias (biased allocation to interventions) due to inadequate generation of a randomized sequence

2b. Selection: Allocation concealment (selection bias): Selection bias (biased allocation to interventions) due to inadequate concealment of allocations prior to assignment

3a. Measurement: Ascertainment of exposure

3b. Measurement: Co-interventions (performance bias): Performance bias because co-interventions were different across groups

3c. Measurement: Blinding of outcome assessor (detection bias): Detection bias due to knowledge of the allocated interventions by outcome assessors

3d. Measurement: Intention-to-treat-analysis: Bias due to incomplete reporting and analysis according to group allocation

3e. Measurement: Incomplete outcome data (attrition bias): Attrition bias due to amount, nature or handling of incomplete outcome data

3f. Measurement: Timing of outcome assessments (detection bias): Detection bias because important outcomes were not measured at the same time across groups

3g. Measurement: Do the analyses adjust for different lengths of follow-up of patients?

3h. Measurement: Selective Reporting (reporting bias): Reporting bias due to selective outcome reporting

4a. Additional Bias: Bias due to problems not covered elsewhere in the table.

Table D.3 Risk of bias: Single-arm studies

Author, Year, PMID | Study Design | 1a* | 3e* | 3g* | 3h* | 4a*
Alhadad, 2004, 14718896 | NRCS of surgery | Low | Low | High | Low | Low
Baril, 2007, 17391902 | Prospective | Low | Low | Low | Unclear | Low
Beck, 2010, 19939607 | Retrospective | Low | Low | Low | Low | Low
Bersin, 2013, 22581488 | Prospective | Low | Low | Low | Low | Low
Blum, 1997, 9017938 | Prospective | Low | High | High | Low | Low
Bruno, 2014, 24555729 | Prospective | Low | Low | Low | Low | Low
Cherr, 2002, 11854720 | Prospective | Low | Low | Low | Low | Low
Christie, 2012, 23083664 | Prospective | High | Low | Low | Unclear | Low
Chrysant, 2014, 24909590 | Prospective | Low | Low | Low | Low | Low
Chrysochou, 2012, 21993376 | Prospective | Low | High | Low | Low | Low
Cianci, 2013, 23467950 | Prospective | High | High | Low | High | Low
Cooper, 2008, 18490527 | RCT of PTRAS | Low | Low | Low | Low | Low
Dangas, 2001, 11491257 | Prospective | Low | High | High | High | Low
Dorros, 2002, 11835644 | Prospective | Low | High | Low | High | Low
Galaria, 2005, 15735947 | Retrospective NRCS of surgery | Low | High | Low | High | Low
Gill, 2003, 12601202 | Prospective | Low | High | High | Low | Low
Gill-Leertouwer, 2002, 12466252 | Prospective | Low | Low | Low | Low | Low
Girndt, 2007, 17164562 | Prospective | High | High | High | Low | Low
Gonçalves, 2007, 17364124 | Prospective | Low | High | High | High | High
Gray, 2002, 12710843 | Prospective | Low | High | High | Unclear | Low
Gross, 1998, 9736342 | Prospective | Low | Low | Low | High | Low
Harden, 1997, 9113012 | Prospective | Low | High | Low | Low | Low
Henry, 2003, 14571477 | Prospective | Low | High | High | Low | Low
Holden, 2006, 16837918 | Prospective | Low | Low | High | Low | Low
Iannone, 1996, 8974797 | Prospective | Unclear | Low | High | Low | Low
Jaff, 2012, 22511402 | Prospective | Low | Low | Low | Low | Low
Jokhi, 2009, 19668788 | Prospective | Low | Unclear | Low | High | Low
Kawarada, 2010, 20884436 | Prospective | Low | Low | High | Low | Low
Kennedy, 2003, 14582036 | Prospective | Low | High | Low | Low | Low
Kobo, 2010, 20684176 | Prospective | High | Low | Low | Low | Low
Leesar, 2009, 19539148 | Prospective | Unclear | Low | High | High | Low
Lekston, 2008, 19006027 | RCT of PTRAS | Unclear | High | High | High | High
Mannarino, 2012, 22260219 | Prospective NRCS of PTRAS | High | Low | High | Low | Low
Murphy, 2014, 24325931 | Prospective | Low | High | Low | Low | High
Ramos, 2003, 12472793 | Prospective | High | Low | Low | Low | Low
Rastan, 2008, 19110785 | Prospective | Low | Low | High | Low | Low
Rivolta, 2005, 16358234 | Prospective | Low | High | Low | High | Low
Rocha-Singh, 1999, 10376497 | Prospective | Low | Low | Low | Low | Low
Rocha-Singh, 2005, 16139124 | Prospective | Low | Low | High | Low | Low
Rocha-Singh, 2008, 19006254 | Prospective | Low | High | Low | High | Low
Rocha-Singh, 2011, 21648052 | Prospective | Low | Low | High | Low | Low
Ruchin, 2007, 17317314 | Retrospective | Low | Low | High | Low | Low
Rzeznik, 2011 21129903 | Prospective | Low | Low | Low | Low | Low
Safak, 2013, 23321402 | Prospective | Low | Low | High | Unclear | Low
Sapoval, 2005, 16151060 | Prospective | Low | Low | Low | Low | Low
Sapoval, 2010, 19908091 | Prospective | Low | High | High | Low | High
Silva, 2008, 18670414 | Retrospective NRCS of medication | Low | Low | Low | Unclear | Low
Staub, 2010, 20739200 | Prospective | Low | Low | Low | Low | Low
Trani, 2010, 20578190 | Prospective NRCS of PTRAS | Low | Low | Low | Low | Low
Trani, 2013, 22503569 | Prospective | Low | Low | Low | Low | Low
Tsao, 2005, 16394602 | Prospective | Low | Low | Low | High | Low
Valluri, 2012, 21765186 | Prospective | High | Low | High | Low | Low
van de Ven, 1999, 9929021 | RCT of PTRAS | Low | Low | Low | Low | Low
Webster, 1998, 9655655 | RCT of medication | Low | High | High | Low | Low
White, 1997, 9362400 | Prospective | Low | High | High | High | Low
Zahringer, 2007, 17696619 | Prospective NRCS of PTRAS | Low | Low | Low | Low | High
Zeller, 2004, 15056029 | Prospective | Low | High | High | Low | Low
Zeller, 2005, 16212462 | Prospective | Low | Low | High | High | High

1a. Sampling: Were the subjects in the study representative of the entire population from which they were recruited?

1b. Sampling: Comparability of cohorts on the basis of the design or analysis

1c. Sampling: Group similarity at baseline (selection bias): Selection bias due to dissimilarity at baseline for the most important prognostic indicators

1d. Sampling: Selection of the comparator (Medicine) cohort

2a. Selection: Random sequence generation (selection bias): Selection bias (biased allocation to interventions) due to inadequate generation of a randomized sequence

2b. Selection: Allocation concealment (selection bias): Selection bias (biased allocation to interventions) due to inadequate concealment of allocations prior to assignment

3a. Measurement: Ascertainment of exposure

3b. Measurement: Co-interventions (performance bias): Performance bias because co-interventions were different across groups

3c. Measurement: Blinding of outcome assessor (detection bias): Detection bias due to knowledge of the allocated interventions by outcome assessors

3d. Measurement: Intention-to-treat-analysis: Bias due to incomplete reporting and analysis according to group allocation

3e. Measurement: Incomplete outcome data (attrition bias): Attrition bias due to amount, nature or handling of incomplete outcome data

3f. Measurement: Timing of outcome assessments (detection bias): Detection bias because important outcomes were not measured at the same time across groups

3g. Measurement: Do the analyses adjust for different lengths of follow-up of patients?

3h. Measurement: Selective Reporting (reporting bias): Reporting bias due to selective outcome reporting

4a. Additional Bias: Bias due to problems not covered elsewhere in the table.

Figure D.1 Risk of bias in RCTs

Appendix Figure D.1: depicts a bar graph of the risk of bias in included randomized controlled trials. Regarding 1a, Sampling, subjects representative of entire population, 1 study was high risk of bias, 5 were low risk of bias, 3 were unclear risk of bias. Regarding 1c, Sampling, group similarity at baseline, 1 study was high risk of bias, 7 were low risk of bias, and 1 was unclear risk of bias. Regarding both 2a and 2b, Selection, random sequence generation and allocation concealment, 6 studies had low risk of bias and 3 unclear risk of bias. Regarding 3b, Measurement, co-interventions performance bias, 7 studies were low risk of bias and 2 unclear risk of bias. Regarding 3c Measurement, blinding of outcome assessor (detection bias), 1 had high risk of bias, 6 low risk of bias, and 2 unclear risk of bias. Regarding 3d, Measurement, intention to treat analysis, 6 were low risk of bias and 3 unclear risk of bias. Regarding 3e, Measurement, incomplete outcome data, attrition bias, 3 studies were high risk of bias, 4 low risk of bias, and 2 unclear risk of bias. Regarding 3f, Measurement, timing of outcome assessment, detection bias, all 9 studies were low risk of bias. Regarding 3g and 3h, Measurement, adjustment for different lengths of follow-up and Measurement, selective reporting, 2 were high risk of bias and 7 low risk of bias. Regarding bias due to problems not covered elsewhere, 4 were high risk of bias, 5 low risk of bias.

Figure D.2 Risk of bias in NRCS

Appendix Figure D.2: depicts a bar graph of the risk of bias in included nonrandomized comparative studies. Regarding 1a, Sampling, subjects representative of entire population, 11 studies were low risk of bias, 2 unclear. Regarding 1b, Sampling, comparability of cohorts, 6 studies were high risk of bias, 6 low risk of bias, and 1 not applicable. Regarding 1c, Sampling, group similarity at baseline, 6 studies were high risk of bias, 4 low risk of bias, 2 unclear, and 1 not applicable. Regarding 1d, Sampling, selection of the comparator group, 1 study was high risk of bias, 11 low risk of bias, and 1 not applicable. Regarding 3a, Measurement, ascertainment of exposure, 8 were low risk of bias, 1 unclear, and 4 not applicable. Regarding 3b, Measurement, co-interventions performance bias, 1 was high risk of bias, 7 low risk of bias, 4 unclear, and 1 not applicable. Regarding 3c Measurement, blinding of outcome assessor (detection bias), 2 were high risk of bias, 10 low risk of bias, and 1 not applicable. Regarding 3e, Measurement, incomplete outcome data, attrition bias, 5 were high risk of bias and 8low risk of bias. Regarding 3f, Measurement, timing of outcome assessment, detection bias, 3 studies were high risk of bias, 9 low risk of bias, and 1 not applicable. Regarding 3g, Measurement, adjustment for different lengths of follow-up, 4 were high risk of bias and 9 low risk of bias. Regarding 3h, Measurement, selective reporting, 3 were high risk of bias, 8 low risk of bias, and 2 unclear. Regarding bias due to problems not covered elsewhere, all 13 studies were low risk of bias.

Figure D.3 Risk of bias in single arm studies of PTRAS

Appendix Figure D.3: depicts a bar graph of the risk of bias in included single arm studies of PTRAS. Regarding 1a, Sampling, subjects representative of entire population, 7 studies were high risk of bias, 41 low risk of bias, and 3 unclear. Regarding 3e, Measurement, incomplete outcome data, attrition bias, 18 were high risk of bias, 32 low risk of bias, and 1 unclear. Regarding 3g, Measurement, adjustment for different lengths of follow-up, 22 were high risk of bias, 29 low risk of bias. Regarding 3h, Measurement, selective reporting, 13 were high risk of bias, 35 low risk of bias, and 3 unclear. Regarding bias due to problems not covered elsewhere, 6 had high risk of bias and 45 low risk of bias.

Figure D.4 Risk of bias in single arm studies of medication

Appendix Figure D.4: depicts a bar graph of the risk of bias in included single arm studies of medication. Regarding 1a, Sampling, subjects representative of entire population, all 4 studies were low risk of bias. Regarding 3e, Measurement, incomplete outcome data, attrition bias, 2 were high risk of bias and 2 low risk of bias. Regarding 3g, Measurement, adjustment for different lengths of follow-up, 2 were high risk of bias and 2 low risk of bias. Regarding 3h, Measurement, selective reporting, 2 were low risk of bias and 2 unclear. Regarding bias due to problems not covered elsewhere, all 4 were low risk of bias.

Figure D.5 Risk of bias in single arm studies of surgery

Appendix Figure D.5: depicts a bar graph of the risk of bias in included single arm studies of surgery. Regarding 1a, Sampling, subjects representative of entire population, all 3 were low risk of bias. Regarding 3e, Measurement, incomplete outcome data, attrition bias, 1 was high risk of bias and 2 low risk of bias. Regarding 3g, Measurement, adjustment for different lengths of follow-up, 1 was high risk of bias and 2 low risk of bias. Regarding 3h, Measurement, selective reporting, 1 was high risk of bias and 2 low risk of bias. Regarding bias due to problems not covered elsewhere, all 3 studies were low risk of bias.