# Summary Tables

Table C.1 Study design

Table C.2.1 Arm details: Comparative studies, PTRAS versus medication only

Table C.2.2 Arm details: Comparative studies, surgery versus medication only

Table C.2.3 Arm details: Comparative studies, PTRAS versus surgery

Table C.2.4 Arm details: PTRAS single arm studies

Table C.2.5 Arm details: Medication only single arm studies

Table C.2.6 Arm details: Surgical revascularization single arm studies

Table C.3 Baseline data

Table C.4.1 Results: Mortality

Table C.4.2 Results: Kidney function, within arm change, angioplasty with stent

Table C.4.3 Results: Kidney function, within arm change, medication

Table C.4.4 Results: Kidney function, within arm change, surgery

Table C.4.5 Results: Kidney function, between-arm differences

Table C.4.6 Results: Kidney function, categorical outcomes, simple

Table C.4.7 Results: Kidney function, categorical outcomes, multiple

Table C.4.8 Results: Blood pressure, within-arm change, angioplasty with stent

Table C.4.9 Results: Blood pressure, within-arm change, medication

Table C.4.10 Results: Blood pressure, within-arm change, surgery

Table C.4.11 Results: Blood pressure, between-arm differences

Table C.4.12 Results: Blood pressure/hypertension, categorical outcomes, simple

Table C.4.13 Results: Blood pressure/hypertension, categorical outcomes, multiple

Table C.4.14 Results: Number of medications

Table C.4.15 Results: Medications, categorical outcomes, simple

Table C.4.16 Results: Medications, categorical outcomes, multiple

Table C.4.17 Results: Cardiovascular events

Table C.4.18 Results: Congestive heart failure

Table C.4.19 Results: Composite major adverse events

Table C.4.20 Results: Periprocedural adverse events