# Excluded Studies

Table B Excluded studies with rejection reasons

Rejection Reason | PMID | Authors | Title | Journal | Note
P: Not primarily ARAS treatment | 9408615 | Harjai | Effect of Geer on Outcomes Following Renal Artery Stent Placement for Renovascular Hypertension | | Original report
P: Not primarily ARAS treatment | 10658941 | Johansson | Increased cardiovascular mortality in hypertensive patients with renal artery stenosis. Relation to sympathetic activation, renal function and treatment regimens. | | Original report
P: Not primarily ARAS treatment | 18472384 | Modrall JG Rosero EB Smith ST Arko FR 3rd Valentine RJ Clagett GP Timaran CH | Operative mortality for renal artery bypass in the United States: Results from the National Inpatient Sample | Journal of Vascular Surgery | New
P: Not primarily ARAS treatment | 19233600 | Mohabbat W Greenberg RK Mastracci TM Cury M Morales JP Hernaez AV | Revised duplex criteria and outcomes for renal stents and stent grafts following endovascular repair of juxtarenal and thoracoabdominal aneurysms | Journal of Vascular Surgery | New
P: Not primarily ARAS treatment | 19853403 | Patel R Conrad MF Paruchuri V Kwolek CJ Cambria RP Comment in: J Vasc Surg. 2010 Feb;51(2):315–6; PMID: 20141955 | Balloon expandable stents facilitate right renal artery reconstruction during complex open aortic aneurysm repair | Journal of Vascular Surgery | New
P: Not primarily ARAS treatment | 22104341 | Reed NR Kalra M Bower TC Oderich GS McKusick M Duncan AA Schleck CD Gloviczki P | Efficacy of combined renal and mesenteric revascularization | Journal of Vascular Surgery | New
P: Not primarily ARAS treatment | no PMID | Marone | Revascularization for renal function retrieval: which patients will benefit? | Pers Vasc Surg Endovasc Ther | Original report
Other: Restenosis | 23538936 | HS Itani | First use of a drug-eluting balloon in the treatment of acute renal artery occlusion and in-stent restenosis | | New
Other: RCT protocol | 19229814 | Marcantoni C Zanoli L Rastelli S Tripepi G Matalone M Di Laro D Scaura S Tamburino C Zoccali C Castellino P | Stenting of renal artery stenosis in coronary artery disease (RAS-CAD) study: a prospective, randomized trial | Journal of Nephrology | New
Other: Protocol | 19635148 | Schwarzwalder U Hauk M Zeller T | RADAR - A randomized, multi-centre, prospective study comparing best medical treatment versus best medical treatment plus renal artery stenting in patients with haemodynamically relevant atherosclerotic renal artery stenosis | Trials [Electronic Resource] | New
Other: Not primary study | 18670376 | Henry M Henry I Polydorou A Hugel M | Embolic protection for renal artery stenting | Journal of Cardiovascular Surgery | New
Other: Not primary study | no PMID | | Revascularization versus medical therapy for renal-artery stenosis. The ASTRAL investigators. The New Engla Journal of Medicine 2009; 361: 1953–1962 | Vascular Medicine | New
Other: Not ARAS | 17349328 | Grigoryants V Henke PK Watson NC Upchurch GR Jr Wakefield TW Stanley JC | Iliorenal bypass: indications and outcomes following 41 reconstructions | Annals of Vascular Surgery | New
Other: Not ARAS | 17453127 | Lanzer P Weser R Prettin C | Intentional single-stage revascularization of two different vascular beds in patients with vascular multimorbidity; a feasibility study | Clinical Research in Cardiology | New
Other: Not ARAS | 18760724 | Cai S Ouyang YS Li JC Dai Q Tan L Xia Y Xu ZH Li HJ Jiang YX | Evaluation of acute renal artery thrombosis or embolism with color Doppler sonography | | New
Other: Not an analysis of interest (CORAL) | no PMID | David A Folt1; Kaleigh L Evans1; Sravya Brahmaam1; Wencan He1; Pamela Brewster1; Timothy P Murphy2; Donald E Cutlip3; Lance Dworkin4; Kenneth Jamerson5; William Henrich6; Diane Reid7; Christopher J Cooper1 | Abstract 14746: Region and physician specialty influence medical management of atherosclerotic renal artery stenosis | Circulation | New
Other: No new primary data (PMID 18490527) | no PMID | He W, Chen J, Zhang D et al | Abstract 14283: Time depeant changes in systolic blood pressure after renal artery stenting: Role of stenosis severity | Circulation | New
Other: No new primary data (ASTRAL abstract plus commentary) | no PMID | | Should revascularisation be recommended for atherosclerotic renal artery stenosis? | Journal of the Royal College of Physicians of Edinburgh | New
Other: Natural Hx | 8254782 | Fergany | Management of atherosclerotic renal artery disease in younger patients | | Original report
Other: Natural Hx | 9507221 | Caps | Risk of atrophy in kidneys with atherosclerotic renal artery stenosis. | | Original report
Other: Natural Hx | 11099684 | Iglesias | The Natural History of Incidental Renal Artery Stenosis in Patients with Aortoiliac Vascular Disease | | Original report
Other: Natural Hx | 11576364 | Conlon | Severity of renal vascular disease predicts mortality in patients undergoing coronary angiography | | Original report
Other: Natural Hx | 11752032 | Cheung | Epidemiology of Renal Dysfunction and Patient Outcome in Atherosclerotic Renal Artery Occlusion | | Original report
Other: Natural Hx | 12027983 | Pillay | Prospective multicentre study of the natural history of atherosclerotic renal artery stenosis in patients with peripheral vascular disease. | | Original report
Other: Natural Hx | 12358138 | Uzu | Prevalence and outcome of renal artery stenosis in atherosclerotic patients with renal dysfunction. | | Original report
Other: Natural Hx | 15161949 | Houston | Spiral laminar flow in the abdominal aorta: a predictor of renal impairment deterioration in patients with renal artery stenosis? | | Original report
Other: Natural Hx | 17713349 | Cheung CM Patel A Shaheen N Cain S Eddington H Hegarty J Middleton RJ Cowie A Mamtora H Kalra PA | The effects of statins on the progression of atherosclerotic renovascular disease | Nephron | New
Other: Natural Hx | 19667039 | Wright JR Shurrab AE Cooper A Kalra PR Foley RN Kalra PA | Progression of cardiac dysfunction in patients with atherosclerotic renovascular disease | Qjm | New
Other: Natural Hx | 25150754 | Aboyans V and Tanguy and B. and Desormais and I. and Bonnet and V. and Chonchol and M. and Laskar and M. and Mohty and D. and Lacroix and P. | Prevalence of renal artery disease and its prognostic significance in patients undergoing coronary bypass grafting | American Journal of Cardiology | New
Other: Drive by stent | 19952777 | Rimoldi SF de Marchi SF Wiecker S Meier B Allemann Y | Screening renal artery angiography in hypertensive patients undergoing coronary angiography a 6-month follow-up after ad hoc percutaneous revascularization | Journal of Hypertension | New
Other: Case, not ARAS | 17003541 | Rehan A and Almanaseer and Yassar and Desai and Devang M. and Ali and Arshad and Yamasaki and Hiroshi | Complete resolution of acute renal failure after left renal artery angioplasty and stent placement for total renal artery occlusion | | New
Other: Case, not acute decompensation | 17022392 | Mannebach PC and Dieter and Robert S. and Marks and David Scott | Use of gadolinium-based angiography for renal artery stenting in a patient with renal insufficiency: A case report | Angiology | New
Other: Case, not acute decompensation | 17712213 | Adriaenssens T and Kastrati and Adnan and Schomig and Albert | Successful stenting of bilateral multiple renal arteries in a patient with renovascular hypertension | Journal of Invasive Cardiology | New
O: No outcome of interest | 17723005 | Puchner S Stadler A Minar E Lammer J Bucek RA | Multidetector CT angiography in the follow-up of patients treated with renal artery stents: value of different reformation techniques compared with axial source images | Journal of Endovascular Therapy | New
O: No outcome of interest | 18386125 | Parenti GC Palmarini D Bilzoni M Campioni P Mannella P Ginevra A | Role of color-Doppler sonography in the follow-up of renal artery stenting | Radiologia Medica | New
O: No outcome of interest | 18712043 | Tanemoto M Abe M Uruno A Abe T Ito S | Angiographic index for angioplasty-treatable atheromatous renal artery stenosis | Hypertension Research - Clinical & Experimental | New
O: No outcome of interest | 18922676 | Giles H Lesar C Erdoes L Sprouse R Myers S | Balloon-expandable covered stent therapy of complex endovascular pathology | Annals of Vascular Surgery | New
O: No outcome of interest | 20675902 | Thalhammer C Ferriani V Husmann M Rufibach K Meier T Amann-Vesti BR | Predictive value of duplex ultrasound for restenosis after renal artery stenting | Clinical Hemorheology & Microcirculation | New
O: No outcome of interest | 24746646 | Crimmins JM | Validity of estimated glomerular filtration rates for assessment of renal function after renal artery stenting in patients with atherosclerotic renal artery stenosis | Jacc: Cardiovascular Interventions | New
O: No outcome of interest | no PMID | | Determinants of angiotensin converting enzyme inhibitor/angiotensin receptor blocker use in patients with atherosclerotic renal artery stenosis and effects on blood pressure | Circulation | New
I: No specific intervention(s) | 16892443 | Jones NJ Bates ER Chetcuti SJ Lederman RJ Grossman PM | Usefulness of translesional pressure gradient and pharmacological provocation for the assessment of intermediate renal artery disease | Catheterization & Cardiovascular Interventions | New
I: No specific intervention(s) | 17631082 | de Silva R Loh H Rigby AS Nikitin NP Witte KK Goode K Bhaari S Nicholson A Clark AL Clela JG | Epidemiology, associated factors, and prognostic outcomes of renal artery stenosis in chronic heart failure assessed by magnetic resonance angiography | American Journal of Cardiology | New
I: No specific intervention(s) | 17891347 | Komea P Zalunardo N Burnett S Love J Buller C Taylor P Duncan J Djurdjev O Levin A | Conservative outpatient renoprotective protocol in patients with low GFR undergoing contrast angiography: a case series | Clinical & Experimental Nephrology | New
I: No specific intervention(s) | 18569908 | Onuigbo MA Onuigbo NT | Renal failure and concurrent RAAS blockade in older CKD patients with renal artery stenosis: an exteed Mayo Clinic prospective 63-month experience | Renal Failure | New
I: No specific intervention(s) | 18670374 | Bergqvist D Bjorck M Lugren F Troeng T | Invasive treatment for renovascular disease. A twenty year experience from a population based registry | Journal of Cardiovascular Surgery | New
I: No specific intervention(s) | 18692990 | Davies MG Saad WE Peden EK Mohiuddin IT Naoum JJ Lumsden AB | Implications of acute functional injury following percutaneous renal artery intervention | Annals of Vascular Surgery | New
I: No specific intervention(s) | 19098012 | Esteban C Perez P Fernaez-Llamazares J Surinach JM Camafort M Martorell A Monreal M Comment in: Angiology. 2010 May;61(4):415–6; PMID: 20483812 | Clinical outcome in patients with peripheral artery disease and renal artery stenosis | Angiology | New
I: No specific intervention(s) | 19754857 | Dechering DG Kruis HM Adiyaman A Thien T Postma CT | Clinical significance of low-grade renal artery stenosis | Journal of Internal Medicine | New
I: No specific intervention(s) | 21133827 | Andersen UB Borglykke A Jorgensen T | Prevalence of renal artery stenosis in subjects with moderate hypertension. A population-based study | Blood Pressure | New
I: No specific intervention(s) | 22771675 | A. Eirin and Gloviczki and Monika L. and Tang and Hui and Gossl and Mario and Jordan and Kyra L. and Woollard and John R. and Lerman and Amir and Grae and Joseph P. and Textor and Stephen C. and Lerman and Lilach O. | Inflammatory and injury signals released from the post-stenotic human kidney | | New
I: No specific intervention(s) | no PMID | | Severity of renal artery lesions in patients enrolled into the CORAL trial | Journal of Vascular and Interventional Radiology | New
I: No specific intervention(s) | 2150435 | Khangura KK and A.; Kane and G. C.; Misra and S.; Textor and S. C.; Lerman and A.; Lerman and L. O.; Khangura and Kirandeep K.; Eirin and Alfonso; Kane and Garvan C.; Misra and Sanjay; Textor and Stephen C.; Lerman and Amir; Lerman and Lilach O. | Extrarenal atherosclerotic disease blunts renal recovery in patients with renovascular hypertension | Journal of Hypertension | New
I: Angioplasty w/o stent (≥80%) | 2939491 | L. G. Martin and Casarella and W. J. and Alspaugh and J. P. and Chuang and V. P. | Renal artery angioplasty: increased technical success and decreased complications in the seco 100 patients | | New
I: Angioplasty w/o stent (≥80%) | 10924577 | Baumgartner | Stent Placement in Ostial and Nonostial Atherosclerotic Renal Arterial Stenoses: A Prospective Follow-up Study | | Original report
I: Angioplasty w/o stent (≥80%) | 11172177 | Radermacher | Use of Doppler ultrasonography to predict the outcome of therapy for renal-artery stenosis | | Original report
I: Angioplasty w/o stent (≥80%) | 12469977 | Ziakka | Percutaneous transluminal renal artery angioplasty: who benefits most? | | Original report
I: Angioplasty w/o stent (≥80%) | 16897141 | Lanzer P Weser R Prettin C | Coronary-like revascularization for atherosclerotic renal artery stenosis--results in 181 consecutive patients | Clinical Research in Cardiology | New
I: Angioplasty w/o stent (≥80%) | 17491539 | Mak G Tan CY Ben Khiaron O McEniff N Feely J | An evaluation of the effects of renal artery stenting in renovascular hypertension | Irish Medical Journal | New
I: Angioplasty w/o stent (≥80%) | 18580055 | Zalunardo N Rose C Starovoytov A Djurdjev O Fox R Taylor P Duncan JA Buller CE Levin A | Incidental atherosclerotic renal artery stenosis diagnosed at cardiac catheterization: no difference in kidney function with or without stenting | American Journal of Nephrology | New
I: Angioplasty w/o stent (≥80%) | 18772602 | Lekston A Chudek J Gasior M Wilczek K Wiecek A Kokot F Gierlotka M Niklewski T Fijalkowski M Szygula-Jurkiewicz B Wojnicz R Bialas B Osuch M Maciejewski B Polonski L | Angiographic and intravascular ultrasound assessment of immediate and 9-month efficacy of percutaneous transluminal renal artery balloon angioplasty with subsequent brachytherapy in patients with renovascular hypertension | Kidney & Blood Pressure Research | New
I: Angioplasty w/o stent (≥80%) | 19217744 | Davies MG Saad WE Bismuth JX Naoum JJ Peden EK Lumsden AB | Endovascular revascularization of renal artery stenosis in the solitary functioning kidney | Journal of Vascular Surgery | New
I: Angioplasty w/o stent (≥80%) | 19337882 | Jensen G Annerstedt M Klingenstierna H Herlitz H Aurell M Hellstrom M Comment in: Sca J Urol Nephrol. 2010 Feb;44(1):62–3; author reply 64; PMID: 19958074 | Survival and quality of life after renal angioplasty: a five-year follow-up study | Scainavian Journal of Urology & Nephrology | New
I: Angioplasty w/o stent (≥80%) | 19367240 | Alhadad A Mattiasson I Ivancev K Liblad B Gottsater A | Predictors of long-term beneficial effects on blood pressure after percutaneous transluminal renal angioplasty in atherosclerotic renal artery stenosis | International Angiology | New
I: Angioplasty w/o stent (≥80%) | 19413179 | Lekston A Niklewski T Gasior M Chudek J Wilczek K Wiecek A Kokot F Fijalkowski M Gierlotka M Osuch M Maciejewski B Polonski L | Effects of short- and long-term efficacy of percutaneous transluminal renal angioplasty with or without intravascular brachytherapy on regression of left ventricular hypertrophy in patients with renovascular hypertension | Polskie Archiwum Medycyny Wewnetrznej | New
I: Angioplasty w/o stent (≥80%) | 19950087 | Lekston A Chudek J Wilczek K Gasior M Wiecek A Kokot F Fijalkowski M Gierlotka M Szygula-Jurkiewicz B Wojnicz R Bialas B Osuch M Maciejewski B Polonski L | Comparison of early and late efficacy of percutaneous transluminal renal angioplasty with or without subsequent brachytherapy: the effect on blood pressure in patients with renovascular hypertension | Cardiology Journal | New
I: Angioplasty w/o stent (≥80%) | 19955827 | Duranay M Kanbay M Akay H Unverdi S Surer H Altay M Kirbas I Covic A Zoccali C | Nebivolol improves renal function in patients who underwent angioplasty due to renal artery stenosis: a pilot study | Nephron | New
I: Angioplasty w/o stent (≥80%) | 21613792 | Nowakowska Fortuna E Herlitz H Saeed A Attman PO Jensen G Alaupovic P Guron G | Lipoprotein abnormalities in patients with atherosclerotic renovascular disease | Kidney & Blood Pressure Research | New
D: Surg retro cohort N<100 | 21636929 | Kumar B Sinha PK Unnikrishnan M | Anesthetic management of patients undergoing extra-anatomic renal bypass surgery for renovascular hypertension | Annals of Cardiac Anaesthesia | New
D: Surg retro cohort N<100 | 21821380 | Ghanami RJ, Rana H, Craven TE, Hoyle J, Edwards MS, Hansen KJ. | Diastolic function predicts survival after renal revascularization. | Journal of Vascular Surgery | New
D: Plasty/Rx cohort, retrospective | 19631505 | Corriere MA Hoyle JR Craven TE D’Agostino RB Jr Edwards MS Moore PS Hansen KJ | Changes in left ventricular structure and function following renal artery revascularization | Annals of Vascular Surgery | New
D: Plasty/Rx cohort, retrospective | 2939491 | Martin LG and Casarella and W. J. and Alspaugh and J. P. and Chuang and V. P. | Renal artery angioplasty: increased technical success and decreased complications in the seco 100 patients | | New
D: Plasty/Rx cohort, retrospective | 9774123 | Tuttle | Treatment of Atherosclerotic Ostial Renal Artery Stenosis With the Intravascular Stent | | Original report
D: Plasty/Rx cohort, retrospective | 11479472 | Lederman | Primary renal artery stenting: Characteristics and outcomes after 363 procedures | | Original report
D: Plasty/Rx cohort, retrospective | 14718831 | Pizzolo | Renovascular disease: Effect of ACE gene deletion polymorphism and endovascular revascularization | | Original report
D: Plasty/Rx cohort, retrospective | 14743583 | Bucek | Long-term follow-up after renal artery stenting | | Original report
D: Plasty/Rx cohort, retrospective | 17042665 | Bates MC Rashid M Campbell JE Stone PA Broce M Lavigne PS | Factors influencing the need for target vessel revascularization after renal artery stenting | Journal of Endovascular Therapy | New
D: Plasty/Rx cohort, retrospective | 17192944 | Silva JA Potluri S White CJ Collins TJ Jenkins JS Subramanian R Ramee SR Comment in: Catheter Cardiovasc Interv. 2007 May 1;69(6):908–9; PMID: 17427206 | Diabetes mellitus does not preclude stabilization or improvement of renal function after stent revascularization in patients with kidney insufficiency and renal artery stenosis | Catheterization & Cardiovascular Interventions | New
D: Plasty/Rx cohort, retrospective | 17210392 | Kashyap VS Sepulveda RN Bena JF Nally JV Poggio ED Greenberg RK Yadav JS Ouriel K | The management of renal artery atherosclerosis for renal salvage: does stenting help? | Journal of Vascular Surgery | New
D: Plasty/Rx cohort, retrospective | 17400563 | Tan J Filobbos R Raghunathan G Nicholson T Fowler R Wright M Eadington D | Efficacy of renal artery angioplasty and stenting in a solitary functioning kidney | Nephrology Dialysis Transplantation | New
D: Plasty/Rx cohort, retrospective | 17488176 | Zeller T Rastan A Schwarzwalder U Muller C Frank U Burgelin K Sixt S Schwarz T Noory E Neumann FJ | Regression of left ventricular hypertrophy following stenting of renal artery stenosis | Journal of Endovascular Therapy | New
D: Plasty/Rx cohort, retrospective | 17525962 | Bates MC Campbell JE Stone PA Jaff MR Broce M Lavigne PS Comment in: Catheter Cardiovasc Interv. 2007 Jun 1;69(7):1046–7; PMID: 17525963 Comment in: Catheter Cardiovasc Interv. 2007 Jun 1;69(7):1044–5; PMID: 17525995 Comment in: Catheter Cardiovasc Interv. 2007 Jun 1;69(7):1048–9; PMID: 17525964 | Factors affecting long-term survival following renal artery stenting | Catheterization & Cardiovascular Interventions | New
D: Plasty/Rx cohort, retrospective | 17606122 | Edwards MS Corriere MA Craven TE Pan XM Rapp JH Pearce JD Mertaugh NB Hansen KJ | Atheroembolism during percutaneous renal artery revascularization | Journal of Vascular Surgery | New
D: Plasty/Rx cohort, retrospective | 17673882 | Tagle R Acevedo M Xu M Pohl M Vidt D | Use of endovascular stents in atherosclerotic renovascular stenosis: blood pressure and renal function changes in hypertensive patients | Journal of Clinical Hypertension | New
D: Plasty/Rx cohort, retrospective | 17934918 | Ovrehus KA Aersen PE Jacobsen IA Comment in: Blood Press. 2007;16(5):288–90; PMID: 17934915 | Treatment of renovascular hypertension by transluminal angioplasty--13 years experience in a single centre | Blood Pressure | New
D: Plasty/Rx cohort, retrospective | 18238866 | Bates MC Campbell JE Broce M Lavigne PS Riley MA | Serum creatinine stabilization following renal artery stenting | Vascular & Endovascular Surgery | New
D: Plasty/Rx cohort, retrospective | 18256017 | Kane GC Stanson AW Kalnicka D Rosenthal DW Lee CU Textor SC Garovic VD | Comparison between gadolinium and iodine contrast for percutaneous intervention in atherosclerotic renal artery stenosis: clinical outcomes | Nephrology Dialysis Transplantation | New
D: Plasty/Rx cohort, retrospective | 18620111 | Suliman A Imhoff L Greenberg JI Angle N | Renal stenting for incidentally discovered renal artery stenosis: is there any outcome benefit? | Annals of Vascular Surgery | New
D: Plasty/Rx cohort, retrospective | 18727962 | Corriere MA Pearce JD Edwards MS Stafford JM Hansen KJ Comment in: Perspect Vasc Surg Endovasc Ther. 2009 Sep;21(3):201–2; PMID: 19602506 | Endovascular management of atherosclerotic renovascular disease: early results following primary intervention | Journal of Vascular Surgery | New
D: Plasty/Rx cohort, retrospective | 18760140 | Hackam DG Duong-Hua ML Mamdani M Li P Tobe SW Spence JD Garg AX | Angiotensin inhibition in renovascular disease: a population-based cohort study | American Heart Journal | New
D: Plasty/Rx cohort, retrospective | 18789723 | Misra S Gomes MT Mathew V Barsness GW Textor SC Bjarnason H McKusick MA | Embolic protection devices in patients with renal artery stenosis with chronic renal insufficiency: a clinical study | Journal of Vascular & Interventional Radiology | New
D: Plasty/Rx cohort, retrospective | 18829238 | Klonaris C Katsargyris A Alexarou A Tsigris C Giannopoulos A Bastounis E | Efficacy of protected renal artery primary stenting in the solitary functioning kidney | Journal of Vascular Surgery | New
D: Plasty/Rx cohort, retrospective | 19128271 | Singer GM Setaro JF Curtis JP Remetz MS | Distal embolic protection during renal artery stenting: impact on hypertensive patients with renal dysfunction | Journal of Clinical Hypertension | New
D: Plasty/Rx cohort, retrospective | 19172426 | Eklof H Bergqvist D Hagg A Nyman R | Outcome after endovascular revascularization of atherosclerotic renal artery stenosis | Acta Radiologica | New
D: Plasty/Rx cohort, retrospective | 19202165 | Chrysochou C Cheung CM Durow M Middleton RJ Solomon LR Craig A Venning M Kalra PA | Proteinuria as a predictor of renal functional outcome after revascularization in atherosclerotic renovascular disease (ARVD) | Qjm | New
D: Plasty/Rx cohort, retrospective | 19217748 | Davies MG Saad WA Bismuth JX Peden EK Naoum JJ Lumsden AB | Outcomes of eoluminal reintervention for restenosis after percutaneous renal angioplasty and stenting | Journal of Vascular Surgery | New
D: Plasty/Rx cohort, retrospective | 19328725 | Thatipelli MR Misra S Sanikommu SR Schainfeld RM Sharma SK Soukas PA | Embolic protection device use in renal artery stent placement | Journal of Vascular & Interventional Radiology | New
D: Plasty/Rx cohort, retrospective | 19595532 | Corriere MA Edwards MS Pearce JD Arews JS Geary RL Hansen KJ | Restenosis after renal artery angioplasty and stenting: incidence and risk factors | Journal of Vascular Surgery | New
D: Plasty/Rx cohort, retrospective | 19625262 | Padigala KK Hartle JE Kirchner HL Schultz MF | Renal cortical thickness as a predictor of renal function and blood pressure status post renal artery stenting | Angiology | New
D: Plasty/Rx cohort, retrospective | 19699353 | Dieter RS Darki A Nanjuappa A Chhokar VS Khadim G Morshedi-Meibodi A Freihage JH Steen L Lewis B Leya F | Usefulness of wide pulse pressure as a predictor of poor outcome after renal artery angioplasty and stenting | American Journal of Cardiology | New
D: Plasty/Rx cohort, retrospective | 19759030 | Albertal M Nau G Padilla LT Cura FA Thierer J Belardi JA | Do men and women respo differently to percutaneous renal artery interventions? | Angiology | New
D: Plasty/Rx cohort, retrospective | 19878369 | Singer GM Remetz MS Curtis JP Setaro JF | Impact of baseline renal function on outcomes of renal artery stenting in hypertensive patients | Journal of Clinical Hypertension | New
D: Plasty/Rx cohort, retrospective | 20022208 | Davies MG Saad WE Bismuth J Naoum JJ Peden EK Lumsden AB | Impact of metabolic syndrome on the outcomes of percutaneous renal angioplasty and stenting | Journal of Vascular Surgery | New
D: Plasty/Rx cohort, retrospective | 20150008 | Dervisoglu E Ciftci E Selek A Sarisoy HT Kaleer B Yilmaz A Comment in: Anadolu Kardiyol Derg. 2010 Feb;10(1):66–8; PMID: 20150009 | Percutaneous renal artery stenting reduces arterial blood pressure, but what about renal function? A single-center experience | Anadolu Kardiyoloji Dergisi | New
D: Plasty/Rx cohort, retrospective | 20201707 | Chang JH Kim BS Oh HJ Yoo TH Kang SW Lee HY Choi D Shim WH Choi KH | Effect of baseline glomerular filtration rate on renal function following stenting for atherosclerotic renal artery stenosis | Scainavian Journal of Urology & Nephrology | New
D: Plasty/Rx cohort, retrospective | 20410427 | Bommart S Cliche A Therasse E Giroux MF Vidal V Oliva VL Soulez G | Renal artery revascularization: predictive value of kidney length and volume weighted by resistive iex | AJR. American Journal of Roentgenology | New
D: Plasty/Rx cohort, retrospective | 20619585 | Fleming SH Davis RP Craven TE Deonanan JK Godshall CJ Hansen KJ | Accuracy of duplex sonography scans after renal artery stenting | Journal of Vascular Surgery | New
D: Plasty/Rx cohort, retrospective | 21034349 | A. Pelta and Aersen and Ulrik B. and Just and Sven and Baekgaard and Niels | Flash pulmonary edema in patients with renal artery stenosis--the Pickering Syndrome | | New
D: Plasty/Rx cohort, retrospective | 21316901 | Modrall JG Rosero EB Leonard D Timaran CH Anthony T Arko FA 3rd Valentine RJ Clagett GP Trimmer C | Clinical and kidney morphologic predictors of outcome for renal artery stenting: data to inform patient selection | Journal of Vascular Surgery | New
D: Plasty/Rx cohort, retrospective | 21803522 | Modrall JG Timaran CH Rosero EB Chung J Arko FA 3rd Valentine RJ Clagett GP Trimmer C | Predictors of outcome for renal artery stenting performed for salvage of renal function | Journal of Vascular Surgery | New
D: Plasty/Rx cohort, retrospective | 21992685 | Hegde U Rajapurkar M Gang S Khanapet M Durugkar S Gohel K Aghor N Ganju A Dabhi M Comment in: Semin Dial. 2012 Jan–Feb;25(1):105–7; PMID: 21917001 | Fifteen years’ experience of treating atherosclerotic renal artery stenosis by interventional nephrologists in India | Seminars in Dialysis | New
D: Plasty/Rx cohort, retrospective | 22097232 | Wolak T Belkin A Ginsburg V Greenberg G Mayzler O Bolotin A Paran E Szero G | Does percutaneous transluminal renal artery angioplasty improve blood pressure control and renal function in patients with atherosclerotic renal artery stenosis? | Israel Medical Association Journal: Imaj | New
D: Plasty/Rx cohort, retrospective | 22133456 | Modrall JG Rosero EB Timaran CH Anthony T Chung J Valentine RJ Trimmer C | Assessing outcomes to determine whether symptoms related to hypertension justify renal artery stenting | Journal of Vascular Surgery | New
D: Plasty/Rx cohort, retrospective | 22264697 | Modrall JG Timaran CH Rosero EB Chung J Plummer M Valentine RJ Trimmer C | Longitudinal changes in kidney parenchymal volume associated with renal artery stenting | Journal of Vascular Surgery | New
D: Plasty/Rx cohort, retrospective | 22613636 | Liao CJ Yang BZ Wang ZG | Percutaneous transluminal renal angioplasty with stent is effective for blood pressure control and renal function improvement in atherosclerotic renal artery stenosis patients | Chinese Medical Journal | New
D: Plasty/Rx cohort, retrospective | 22692467 | Khosla A Misra S Greene EL Pflueger A Textor SC Bjarnason H McKusick MA | Clinical outcomes in patients with renal artery stenosis treated with stent placement with embolic protection compared with those treated with stent alone | Vascular & Endovascular Surgery | New
D: Plasty/Rx cohort, retrospective | 23043033 | Yuksel UC Anabtawi AG Cam A Poddar K Agarwal S Goel S Kim E Bajzer C Gornik HL Shishehbor MH Tuzcu EM Kapadia SR | Predictive value of renal resistive index in percutaneous renal interventions for atherosclerotic renal artery stenosis | Journal of Invasive Cardiology | New
D: Plasty/Rx cohort, retrospective | 23057705 | He Y Liu Y Wang M Sun Y Dong D Yuan H Wu X Chong Z Jin X | Clinical effect of endovascular treatment on blood pressure and kidney function for hypertensive patients with renal artery stenosis | Clinical & Experimental Hypertension (New York) | New
D: Plasty/Rx cohort, retrospective | 23091375 | Zhao J Cheng Q Zhang X Li M Liu S Wang X | Efficacy of percutaneous transluminal renal angioplasty with stent in elderly male patients with atherosclerotic renal artery stenosis | Clinical Interventions In Aging | New
D: Plasty/Rx cohort, retrospective | 23645044 | Su CS Liu TJ Tsau CR Liang KW Chang WC Ting CT Lee WL | The feasibility, safety, and mid-term outcomes of concomitant percutaneous transluminal renal artery stenting in acute coronary syndrome patients at high clinical risk of renal artery stenosis | Journal of Invasive Cardiology | New
D: Plasty/Rx cohort, retrospective | 23688626 | Simone TA Brooke BS Goodney PP Walsh DB Stone DH Powell RJ Cronenwett JL Nolan BW | Clinical effectiveness of secondary interventions for restenosis after renal artery stenting | Journal of Vascular Surgery | New
D: Plasty/Rx cohort, retrospective | 23863797 | Ginzburg V Volak T Grinberg G Maiizler O Leitsin A Saro G | Angioplasty and stenting of renal arteries: in search for prognostic criteria | AngiologIndia i Sosudistaia KhirurgIndia/Angiology & Vascular Surgery | New
D: Plasty/Rx cohort, retrospective | 24502495 | Kawarada O and Yokoi and Y. and Sakamoto and S. and Harada and K. and Ishihara and M. and Yasuda and S. and Ogawa and H. | Impact of aortorenal morphology on renal artery stent procedures: significance of aortic tortuosity and renal artery derivation | Journal of Endovascular Therapy | New
D: Plasty/Rx cohort, retrospective | 25327064 | Sathyamurthy I and Sudhakar and K. and Jayanthi and K. and Subramanyan and K. and Ramachandran and P. and Mao and R. and Samuel and K. M. | Renal artery stenting: one year outcome on BP control and antihypertensive medication | Journal of the Association of Physicians of India | New
D: Plasty/Rx cohort, retrospective | no PMID | Nau | Long-term outcome of atherosclerotic renovascular disease in patients treated with angioplasty | Revista Argentina de Cardiologia | New
D: Plasty cohort N<30 | 2996342 | Franklin | Comparison of effects of enalapril plus hydrochlorothiazide versus standard triple therapy on renal function in renovascular hypertension. | | Original report
D: Plasty cohort N<30 | 3018602 | Franklin | A comparison of enalapril plus hydrochlorothiazide with standard triple therapy in renovascular hypertension | | Original report
D: Plasty cohort N<30 | 6100883 | Tillman | Enalapril in hypertension with renal artery stenosis: long-term follow-up and effects on renal function. | | Original report
D: Plasty cohort N<30 | 12603580 | S. Prasad and Bannister and K. and Taylor and J. | Is magnetic resonance angiography useful in renovascular disease? | | New
D: Plasty cohort N<30 | 17351955 | Mitchell JA Subramanian R White CJ Soukas PA Almagor Y Stewart RE Rosenfield K | Predicting blood pressure improvement in hypertensive patients after renal artery stent placement: renal fractional flow reserve | Catheterization & Cardiovascular Interventions | New
D: Plasty cohort N<30 | 18341947 | Urbano J Manzarbetia F Caramelo C | Cholesterol embolism evaluated by polarized light microscopy after primary renal artery stent placement with filter protection | Journal of Vascular & Interventional Radiology | New
D: Plasty cohort N<30 | 18471677 | Wierema TK Yaqoob MM | Renal artery stenosis in chronic renal failure: caution is advised for percutaneous revascularization | European Journal of Internal Medicine | New
D: Plasty cohort N<30 | 18954765 | Thatipelli M Misra S Johnson CM Arews JC Stanson AW Bjarnason H McKusick MA | Renal artery stent placement for restoration of renal function in hemodialysis recipients with renal artery stenosis | Journal of Vascular & Interventional Radiology | New
D: Plasty cohort N<30 | 19084431 | Brountzos EN Tavernaraki K Gouliamos AD Degiannis D Chaidaroglou A Panagiotou I Arsenis G Kelekis D Vlahakos D | Systemic inflammatory response to renal artery percutaneous angioplasty with stent placement and the risk for restenosis: a pilot study | Journal of Vascular & Interventional Radiology | New
D: Plasty cohort N<30 | 19463314 | Mahmud E Smith TW Palakodeti V Zaidi O Ang L Mitchell CR Zafar N Bromberg-Marin G Keramati S Tsimikas S Comment in: JACC Cardiovasc Interv. 2008 Jun;1(3):293–4; PMID: 19463315 | Renal frame count and renal blush grade: quantitative measures that predict the success of renal stenting in hypertensive patients with renal artery stenosis | Jacc: Cardiovascular Interventions | New
D: Plasty cohort N<30 | 19493475 | Li CJ Wu Z Yan HB Wang J Zhao HJ | Safety and efficacy of coronary drug eluting stent for atherosclerotic stenosis of the small renal artery | Chinese Medical Journal | New
D: Plasty cohort N<30 | 19647181 | Pellerin O Garcon P Beyssen B Raynaud A Rossignol P Jacquot C Plouin PF Sapoval M | Spontaneous renal artery dissection: long-term outcomes after endovascular stent placement | Journal of Vascular & Interventional Radiology | New
D: Plasty cohort N<30 | 21805607 | Laird JR Tehrani F Soukas P Joye JD Ansel GM Rocha-Singh K Comment in: Catheter Cardiovasc Interv. 2012 Feb 15;79(3):437–8; PMID: 22328234 | Feasibility of FiberNet embolic protection system in patients undergoing angioplasty for atherosclerotic renal artery stenosis | Catheterization & Cardiovascular Interventions | New
D: Plasty cohort N<30 | 22134935 | Takumi T Mathew V Barsness GW Kataoka T Rubinshtein R Rihal CS Gulati R Eeckhout E Lennon RJ Lerman LO Lerman A | The association between renal atherosclerotic plaque characteristics and renal function before and after renal artery intervention | Mayo Clinic Proceedings | New
D: Plasty cohort N<30 | 22785108 | Koivuviita N Liukko K Kudomi N Oikonen V Tertti R Manner I Vahlberg T Nuutila P Metsarinne K | The effect of revascularization of renal artery stenosis on renal perfusion in patients with atherosclerotic renovascular disease | Nephrology Dialysis Transplantation | New
D: Plasty cohort N<30 | 23207915 | Kok HK Leong S Goveer P Browne R Torreggiani WC | Percutaneous renal artery angioplasty and stenting: indications, technique and results | Irish Journal of Medical Science | New
D: Plasty cohort N<30 | 24434389 | Labidi J Touat D Abdelghanim K Ajili F Ariba YB Abdelhafidh NB Louzir B Othmani S | Renovascular hypertension: a report of 21 cases | Saudi Journal of Kidney Diseases & Transplantation | New
D: Plasty cohort N<30 | No PMID | Adel SMH | Clinical efficacy of percutaneous renal revascularization with stent placement in hypertension among patients with atherosclerotic renovascular diseases | Journal | New
D: No analysis of interest | no PMID | Yu MSM and A. H.; Pencina and K.; Tuttle and K.; He and W.; Evans and K.; Ren and K.; Folt and D. A.; Brewster and P. S.; Murphy and T. P.; Cutlip and D. E.; Dworkin and L. D.; Jaff and M. R.; Steffes and M.; Shapiro and J. I.; Henrich and W.; Cooper and C. J. | Stenosis severity and kidney function in atherosclerotic renal artery stenosis | Circulation | New
D: No analysis of interest | no PMID | He WE and K. L.; Ren and K.; Folt and D. A.; Brewster and P. S.; Murphy and T. P.; Cutlip and D. E.; Dworkin and L. D.; Shapiro and J. I.; Henrich and W.; Cooper and C. J.; Steffes and M.; Jaff and M. R. | Albuminuria determines event-free survival in atherosclerotic renal-artery stenosis | Circulation | New
D: Comparative N<10/arm | 18375475 | Onuigbo MA Onuigbo NT | Worsening renal failure in older chronic kidney disease patients with renal artery stenosis concurrently on renin angiotensin aldosterone system blockade: a prospective 50-month Mayo-Health-System clinic analysis | Qjm | New
D: Comparative N<10/arm | 18503896 | Misra S Thatipelli MR Howe PW Hunt C Mathew V Barsness GW Pflueger A Textor SC Bjarnason H McKusick MA | Preliminary study of the use of drug-eluting stents in atherosclerotic renal artery stenoses 4 mm in diameter or smaller | Journal of Vascular & Interventional Radiology | New
D: Comparative N<10/arm | 22134468 | Mazza A Rigatelli G Piva M Rampin L Cardaioli P Giordan M Roncon L Zattoni L Zuin M Al-Nahhas A Rubello D Ramazzina E Ravenni R Casiglia E | In high risk hypertensive subjects with incidental and unilateral renal artery stenosis percutaneous revascularization with stent improves blood pressure control but not glomerular filtration rate | Minerva Cardioangiologica | New
D: <6 mo follow-up (and no AE/comp) | no PMID | Kanjwal K, Haller S. Steffes M. Virmani R. Shapiro J. I. Burket M. W. Cooper C. J. Colyer W. R. | Complete versus partial distal embolic protection during renal artery stenting | Catheterization and cardiovascular interventions | New
D: <6 mo follow-up (a no AE/comp) | 2009147 | Ogihara | Clinical evaluation of delapril in Japan. Report from the Japan Study Group on Delapril. | | Original report
D: <6 mo follow-up (a no AE/comp) | 19261820 | Tanemoto M Suzuki T Abe M Abe T Ito S | Hemodynamic index of atheromatous renal artery stenosis for angioplasty | Clinical Journal of The American Society of Nephrology: CJASN | New
D: <6 mo follow-up (a no AE/comp) | 20209644 | Kanjwal K Cooper CJ Virmani R Haller S Shapiro JI Burket MW Steffes M Brewster P Zhang H Colyer WR Jr Comment in: Catheter Cardiovasc Interv. 2010 Jul 1;76(1):24–5; PMID: 20578189 | Predictors of embolization during protected renal artery angioplasty and stenting: Role of antiplatelet therapy | Catheterization & Cardiovascular Interventions | New
D: <6 mo follow-up (a no AE/comp) | 21078879 | Mangiacapra F Trana C Sarno G Davidavicius G Protasiewicz M Muller O Ntalianis A Misonis N Van Vlem B Heyrickx GR De Bruyne B Comment in: Circ Cardiovasc Interv. 2010 Dec;3(6):526–7; PMID: 21078878 | Translesional pressure gradients to predict blood pressure response after renal artery stenting in patients with renovascular hypertension | Circulation: Cardiovascular Interventions | New
D: <6 mo follow-up (a no AE/comp) | 21389959 | Pokrovskii AV Kokov LS Suntsov DS | [Surgical management of atherosclerotic-aetiology vasorenal hypertension] | AngiologIndia i Sosudistaia KhirurgIndia/Angiology & Vascular Surgery | New
D: <6 mo follow-up (a no AE/comp) | 22407515 | Paul TK Lee JH White CJ Comment in: Catheter Cardiovasc Interv. 2012 Nov 15;80(6):1023–4; PMID: 23166103 | Renal embolic protection devices improve blood flow after stenting for atherosclerotic renal artery stenosis | Catheterization & Cardiovascular Interventions | New
D: <6 mo follow-up (a no AE/comp) | 23853222 | McBride J Schueler B Oderich G Misra S | An analysis of the factors influencing radiation dose and fluoroscopic time during renal artery stent placement | Vascular & Endovascular Surgery | New
D: <6 mo follow-up (a no AE/comp) | 24135303 | Protasiewicz M Kadziela J Poczatek K Poreba R Podgorski M Derkacz A Prejbisz A Mysiak A Januszewicz A Witkowski A | Renal artery stenosis in patients with resistant hypertension | American Journal of Cardiology | New
Case report, old | 424606 | B. T. Katzen and Chang and J. and Lukowsky and G. H. and Abramson and E. G. | Percutaneous transluminal angioplasty for treatment of renovascular hypertension | Radiology | Case report
Case report, old | 496100 | M. H. Weinberger and Yune and H. Y. and Grim and C. E. and Luft and F. C. and Klatte and E. C. and Donohue and J. P. | Percutaneous transluminal angioplasty for renal artery stenosis in a solitary functioning kidney | Annals of Internal Medicine | Case report
Case report, old | 786649 | N. Serrallach and Sole-Balcells and F. and de Torres and J. A. and de Blas and A. and Serrate and R. and Brulles and A. | Severe renal insufficiency and renovascular hypertension | European Urology | Case report
Case report, old | 839607 | B. Jackson and Clarkson and A. R. and Jamieson and G. G. and Marshall and V. R. and Seymour and A. E. | Persistent acute renal failure with renal artery stenosis: cure following reconstructive arterial operation | Journal of Urology | Case report
Case report, old | 856104 | D. Heaney and Kupor and L. R. and Noon and G. P. and Suki and W. N. | Bilateral renal artery stenosis causing acute oliguric renal failure. Report of a case corrected by renovascular surgery | Archives of Surgery | Case report
Case report, old | 946990 | A. Besarab and Brown and R. S. and Rubin and N. T. and Salzman and E. and Wirthlin and L. and Steinman and T. and Atlia and R. R. and Skillman and J. J. | Reversible renal failure following bilateral renal artery occlusive disease. Clinical features, pathology, and the role of surgical revascularization | JAMA | Case report
Case report, old | 1463668 | J. R. Schneider and Wright and A. and Mitchell and R. S. | Successful percutaneous balloon catheter treatment of renal artery occlusion and anuria | Annals of Vascular Surgery | Case report
Case report, old | 1865575 | T. Koga and Okuda and S. and Takishita and S. and Shigematsu and A. and Komota and T. and Fujishima and M. and Matsukuma and A. | Renal failure due to cholesterol embolization following percutaneous transluminal renal angioplasty | Japanese Journal of Medicine | Case report
Case report, old | 2234255 | M. K. O’Donohoe and Donohoe and J. and Corrigan and T. P. | Acute renal failure of renovascular origin: cure by aortorenal reconstruction after 25 days of anuria | Nephron | Case report
Case report, old | 2398582 | R. A. McCready and Siderys and H. and Foster and P. R. and Goens and B. M. | Combined coronary artery bypass grafting and bilateral renal revascularization for unstable angina and impeding renal failure | Journal of Vascular Surgery | Case report
Case report, old | 2523265 | J. E. Scoble and Maher and E. R. and Hamilton and G. and Dick and R. and Sweny and P. and Moorhead and J. F. | Atherosclerotic renovascular disease causing renal impairment--a case for treatment | Clinical Nephrology | Case report
Case report, old | 2532661 | J. J. Beraud and Calvet and B. and Dura and A. and Mimran and A. | Reversal of acute renal failure following percutaneous transluminal recanalization of an atherosclerotic renal artery occlusion | Journal of Hypertension | Case report
Case report, old | 3158624 | D. Modai and Cohen and N. and Weissgarten and J. and Segal and B. and Pik and A. | Symptomatic renal artery stenosis superimposed on chronic glomerulonephritis | Israel Journal of Medical Sciences | Case report
Case report, old | 3218663 | A. Cases and Campistol and J. M. and Abad and C. and Botey and A. and Torras and A. and Revert and L. | Reversal of renal failure after revascularization in atheromatous renovascular disease. Report of two cases | American Journal of Nephrology | Case report
Case report, old | 3336930 | R. D. MacMillan and Uldall and R. and Lipton and I. H. | Simultaneous aortic and renal artery reconstruction for acute arterial occlusion in solitary kidney | Urology | Case report
Case report, old | 3688666 | B. A. Perler | Emergency gastroduodenal-renal artery bypass. An extra-anatomic approach for salvage of the solitary kidney | American Surgeon | Case report
Case report, old | 6223006 | J. P. Sheehan | Percutaneous transluminal renal artery angioplasty (PTRA) in hypertensive encephalopathy | Irish Medical Journal | Case report
Case report, old | 6368463 | F. Mosca and Brai and L. S. and Carmellini and M. and Ferrari and M. and Cei and A. and Giulianotti and P. C. and Medi and F. | Successful treatment of recurrent renovascular hypertension by solitary kidney autotransplantation | Italian Journal of Surgical Sciences | Case report
Case report, old | 6650591 | A. G. Ramsay and D’Agati and V. and Dietz and P. A. and Svahn and D. S. and Pirani and C. L. | Renal functional recovery 47 days after renal artery occlusion | American Journal of Nephrology | Case report
Case report, old | 6986478 | J. Stessman and Drukker and A. and Dolberg and M. and Pfau and A. and Merin and G. | Orthotopic renal autotransplantation in the treatment of renovascular hypertension | Journal of Urology | Case report
Case report, old | 7015851 | N. E. Madias and Ball and J. T. and Millan and V. G. | Percutaneous transluminal renal angioplasty in the treatment of unilateral atherosclerotic renovascular hypertension | American Journal of Medicine | Case report
Case report, old | 7035691 | J. Kawamura and Okada and Y. and Nishibuchi and S. and Yoshida and O. | Transient anuria following administration of angiotensin I-converting enzyme inhibitor (SQ 14225) in a patient with renal artery stenosis of the solitary kidney successfully treated with renal autotransplantation | Journal of Urology | Case report
Case report, old | 7469726 | R. J. Manly and Belzer and F. O. | Spontaneous reversal of renal failure by renal artery recanalization | Archives of Surgery | Case report
Case report, old | 7629207 | M. Wengrovitz and Healy and D. A. and Diamo and J. R. and Atnip and R. G. | Renal revascularization in patients on dialysis | Journal of Cardiovascular Surgery | Case report
Case report, old | 7703578 | C. P. Harker and Steed and M. and Althaus and S. J. and Coldwell and D. | Flash pulmonary edema: an acute and unusual complication of renal angioplasty | Journal of Vascular & Interventional Radiology | Case report
Case report, old | 8099389 | C. G. Missouris and Buckenham and T. and Vallance and P. J. and MacGregor and G. A. | Renal artery stenosis masqunderading as congestive heart failure | Lancet | Case report
Case report, old | 8238011 | Z. Roche and Rutecki and G. and Cox and J. and Whittier and F. C. | Reversible acute renal failure as an atypical presentation of ischemic nephropathy | American Journal of Kidney Diseases | Case report
Case report, old | 8264029 | E. Ascer and Gennaro and M. and Rogers and D. | Unilateral renal artery revascularization can salvage renal function and terminate dialysis in selected patients with uremia | Journal of Vascular Surgery | Case report
Case report, old | 8285186 | L. E. Schlanger and Haire and H. M. and Zuckerman and A. M. and Loscalzo and C. E. and Mitch and W. E. | Reversible renal failure in an elderly woman with renal artery stenosis | American Journal of Kidney Diseases | Case report
Case report, old | 8596600 | | Case records of the Massachusetts General Hospital. Weekly Clinicopathological Exercises. Case 11-1996. A 69-year-old man with progressive renal failure and the abrupt onset of dyspnea | New Engla Journal of Medicine | Case report
Case report, old | 8862385 | J. M. Reilly and Rubin and B. G. and Thompson and R. W. and Allen and B. T. and Flye and M. W. and Aerson and C. B. and Sicard and G. A. | Revascularization of the solitary kidney: a challenging problem in a high risk population | Surgery | Case report
Case report, old | 9230557 | D. M. Little and Burke and P. E. and O’Callaghan and J. and Vella and J. and Donoghue and J. and Sami and T. and Hickey and D. P. | Renal revascularisation by gastroduodenal-renal bypass as treatment of renal artery stenosis | Irish Medical Journal | Case report
Case report, old | 9247781 | D. Ducloux and Jamali and M. and Chalopin and J. M. | Chronic congestive heart failure associated with bilateral renal artery stenosis | Clinical Nephrology | Case report
Case report, old | 9497208 | T. M. Sullivan and Hertzer and N. R. | Stenting of the renal artery to improve renal function prior to thoracoabdominal aneurysm repair | Journal of Endovascular Surgery | Case report
Case report, old | 9507232 | S. C. Textor | Revascularization in atherosclerotic renal artery disease | Kidney International | Case report
Case report, old | 9713602 | D. J. Goldsmith and Hamilton and G. | Hypertension and renal failure | Postgraduate Medical Journal | Case report
Case report, old | 10648486 | C. G. Missouris and Belli and A. M. and MacGregor and G. A. | Apparent heart failure: a syndrome caused by renal artery stenoses | Heart | Case report
Case report, old | 10742424 | D. Eton and Terramani and T. T. and Katz and M. | Staged thoracic and abdominal aortic aneurysm repair using stent graft technology and surgery in a patient with acute renal failure | Annals of Vascular Surgery | Case report
Case report, old | 11032259 | R. L. Yue and Collins and T. J. and Sternbergh and W. C. and 3rd and Ramee and S. R. and White and C. J. | Acute renal failure after redo thoracoabdominal aortic aneurysm repair in a patient with a solitary kidney: successful percutaneous treatment | Journal of Endovascular Therapy | Case report
Case report, old | 11136196 | D. L. Cohen and Townse and R. R. and Kobrin and S. and Genega and E. M. and Tomaszewski and J. E. and Fairman and R. | Dramatic recovery of renal function after 6 months of dialysis depeence following surgical correction of total renal artery occlusion in a solitary functioning kidney | American Journal of Kidney Diseases | Case report
Case report, old | 11274271 | J. R. Wright and Duggal and A. and Thomas and R. and Reeve and R. and Roberts and I. S. and Kalra and P. A. | Clinicopathological correlation in biopsy-proven atherosclerotic nephropathy: implications for renal functional outcome in atherosclerotic renovascular disease | Nephrology Dialysis Transplantation | Case report
Case report, old | 12025924 | H. Takakuwa and Shimizu and Kazuaki and Izumiya and Yoshiaki and Kato and Tamayo and Yokoyama and Hitoshi and Kobayashi and Kenichi and Matsui and Osamu and Ise and Takuyuki | Unilateral stent implantation for renal function in bilateral atherosclerotic renovascular hypertension--a case report | Angiology | Case report
Case report, old | 12082500 | B. Agroyannis and Chatziioannou and A. and Mourikis and D. and Patsakis and N. and Katsenis and K. and Kalliafas and S. and Dimakakos and P. and Vlachos and L. | Abdominal aortic aneurysm and renal artery stenosis: renal function and blood pressure before and after endovascular treatment | Journal of Human Hypertension | Case report
Case report, old | 12087578 | K. M. Dwyer and Vrazas and John I. and Lodge and Robert S. and Humphery and Timothy J. and Schlicht and Stephen M. and Murphy and Brean F. and Mossop and Peter J. and Goodman and David J. | Treatment of acute renal failure caused by renal artery occlusion with renal artery angioplasty | American Journal of Kidney Diseases | Case report
Case report, old | 12611127 | G. Tarantini and Romano and Silvia and Cardaioli and Paolo and Ramoo and Angelo | Effect of renal artery stenting on the progression of renovascular renal failure: a case of intravascular ultrasound-confirmed renovascular disease | Italian Heart Journal: Official Journal of the Italian Federation of Cardiology | Case report
Case report, old | 12943603 | D. C. Choo and Fisher and Daniel Z. | Renal artery stenosis: when to intervene? | Cardiology in Review | Case report
Case report, old | 14685757 | A. A. Kiykim and Boz and Murat and Ozer and Caner and Camsari and Ahmet and Yildiz and Altan | Two episodes of anuria and acute pulmonary edema in a losartan-treated patient with solitary kidney | Heart & Vessels | Case report
Case report, old | 14989566 | M. Rajacharan and Altin and Robert | The Goldblatt kidney revisited | Vascular Medicine | Case report
Case report, old | 15065618 | R. J. Cook and Young and Timothy J. and McDonald and Furman S. | 81-year-old woman with nausea, fatigue, and shortness of breath | Mayo Clinic Proceedings | Case report
Case report, old | 15150371 | B. G. Han and Kim and Jang Young and Choi and Jong Uk and Lee and Seung Hwan and Choi and Seung Ok | An acute renal failure patient successfully stented for bilateral renal artery occlusion with a distal embolism protection device | Nephrology Dialysis Transplantation | Case report
Case report, old | 15960152 | E. Svarstad and Urheim and L. and Iversen and B. M. | Critical renal artery stenoses may cause a spectrum of cardiorenal failure and associated thromboembolic events | Clinical Nephrology | Case report