# Search Strategy

The search from the 2006 report was updated and run in MEDLINE, Cochrane, and Embase on July 21, 2014, December 31, 2014, March 20, 2015, and March 16, 2016:

1. exp Hypertension, Renal/
2. exp Renal Artery Obstruction/
3. renal arter$ stenosis.tw.
4. renal arter$ dis$.tw.
5. renovascular dis$.tw.
6. reno vascular dis$.tw.
7. renal vascular dis$.tw.
8. (arvd or “atherosclerotic renovascular dis$”).tw.
9. renal steno$.tw.
10. steno$ kidney.tw.
11. renovascular steno$.tw.
12. or/1–11
13. limit 12 to humans
14. limit 13 to english language
15. limit 14 to (addresses or bibliography or biography or case reports or congresses or consensus development conference or consensus development conference, nih or dictionary or directory or editorial or festschrift or government publications or interview or lectures or legal cases or legislation or letter or news or newspaper article or patient education haout or periodical index or “review of reported cases”)
16. 14 not 15
17. limit 16 to “all adult (19 plus years)”
18. 16 not 17
19. limit 18 to “all child (0 to 18 years)”
20. 16 not 19
21. limit 20 to (guideline or practice guideline or “review” or review, academic or “review literature” or review, multicase or review, tutorial)
22. limit 20 to meta analysis
23. 20 not (21 or 22)
24. follow-up studies/
25. (follow-up or followup).tw.
26. exp Case-Control Studies/
27. (case adj20 control).tw.
28. exp Longitudinal Studies/
29. longitudinal.tw.
30. exp Cohort Studies/
31. cohort.tw.
32. (Random$ or rct).tw.
33. exp Randomized Controlled Trials/
34. exp Random allocation/
35. exp Double-Blind Method/
36. exp Single-Blind Method/
37. randomized controlled trial.pt.
38. clinical trial.pt.
39. controlled clinical trial.pt.
40. (clin$ adj trial$).tw.
41. ((singl$ or doubl$ or trebl$ or tripl$) adj (bli$ or mask$)).tw.
42. exp PLACEBOS/
43. placebo$.tw.
44. exp Research Design/
45. exp Evaluation Studies/
46. exp Prospective Studies/
47. exp Comparative Study/
48. or/24–47
49. 23 and 48
50. (2007$ or 2008$ or 2009$ or 2010$ or 2011$ or 2012$ or 2013$ or 2014$).ed.
51. 49 and 50

At the suggestion of the Technical Expert Panel, we ran a separate search for a selection of case studies of more severe patients, who were likely to benefit from stenting and would have been excluded from the RCTs. This search was run only in MEDLINE on August 14, 2014.

1. exp Hypertension, Renal/
2. exp Renal Artery Obstruction/
3. renal arter$ stenosis.af.
4. renal arter$ dis$.af.
5. renovascular dis$.af.
6. reno vascular dis$.af.
7. renal vascular dis$.af.
8. (arvd or “atherosclerotic renovascular dis$”).af.
9. renal steno$.af.
10. steno$ kidney.af.
11. renovascular steno$.af.
12. or/1–11
13. High risk.af.
14. Critical stenosis.af.
15. Critical lesion.af.
16. exp Acute Kidney Injury/
17. (Subacute and (renal failure or renal insufficiency or kidney failure)).af.
18. (Renovascular and crisis).af.
19. exp Kidney Failure, Chronic/
20. (Acute and ischemic nephropathy).af.
21. (Acute and (renal failure or renal insufficiency or kidney failure)).af.
22. ((chronic kidney disease or CKD) and (stage IV or stage V)).af.
23. Rescue.af. and (RRT.af. or exp renal replacement therapy/ or renal replacement therapy.af. or dialysis.af.)
24. Flash pulmonary edema.af.
25. (Acute adj diastolic dysfunction).af.
26. exp Heart Failure/
27. Acute heart failure.af.
28. Hypertensive crisis.af.
29. exp Hypertension, Malignant/
30. exp Hypertensive encephalopathy/
31. (Hospitalization adj10 hypertension).af.
32. (Bilateral and severe).af.
33. (Single and functioning and kidney).af.
34. hypertensive emergency.af.
35. or/13–34
36. 12 and 35
37. limit 36 to english language
38. limit 37 to humans
39. case.af.
40. 38 and 39