# Abbreviations

AAA: abdominal aortic aneurysm
ABPM: 24 hour ambulatory blood pressure monitoring
ACCF: American College of Cardiology Foundation
ACEi: angiotensin converting enzyme inhibitor
ACS: acute coronary syndrome
AE: adverse events
AFib: atrial fibrillation
AHA: American Heart Association
AHRQ: Agency for Healthcare Research and Quality
AMI: acute myocardial infarction
ARAS: atherosclerotic renal artery stenosis
ARB: angiotensin-receptor blocker
ASTRAL: Angioplasty and Stenting for Renal Artery Lesions
BNP: brain natriuretic protein
BP: blood pressure
CAD: coronary artery disease
CHF: congestive heart failure
CI: confidence interval
CKD: chronic kidney disease
COPD: chronic obstructive pulmonary disease
CORAL: Cardiovascular Outcomes in Renal Atherosclerotic Lesions
CrCl: creatinine clearance
CRF: chronic renal failure
CRP: C reactive protein
CT: computed tomography
CV: cardiovascular
DBP: diastolic blood pressure
DCM: dilated cardiomyopathy
DEP: distal embolic protection device
DM: diabetes mellitus
EPC: Evidence-based Practice Centers
ESRD: end stage renal disease
FPE: flash pulmonary edema
GFR: glomerular filtration rate
HR: hazard ratio
HTN: hypertension
ICTRP: International Clinical Trials Registry Platform
LDL: low density lipoprotein
LVEF: left ventricular ejection fraction
LVF: left ventricular failure
MAP: mean arterial pressure
MetS: metabolic syndrome
MI: myocardial infarction
MR: mitral regurgitation
MRI: magnetic resonance imaging
NRCS: nonrandomized comparative studies
NYHA: New York Heart Association class
OR: odds ratio
PAD: peripheral artery disease
PFTE: polytetrefluoroethylene
PTRA: percutaneous transluminal renal angioplasty (without stent placement)
PTRAS: percutaneous transluminal renal angioplasty with stent placement
PVD: peripheral vascular disease
RA: renal artery
RAS: renal artery stenosis
RCA: right coronary artery stenosis
RCT: randomized controlled trial
RI: resistance index
RR: Risk ratio
RRT: renal replacement therapy
SBP: systolic blood pressure
SCAI: Society for Cardiovascular Angiography and Interventions
SCr: serum creatinine
SoE: strength of evidence
SRDR: Systematic Review Data Repository
TEP: technical expert panel
TIA: transient ischemic attack