# Introduction

## Background

Benign Prostatic Hyperplasia (BPH) is a “histologic diagnosis that refers to the proliferation of smooth muscle and epithelial cells within the prostatic transition zone.”1 Half of men over the age of 40 develop histologic BPH.2

About half of men with BPH develop an enlarged prostate gland, called benign prostatic enlargement (BPE); among these, about half develop some degree of bladder outlet obstruction (BOO).3 BOO and/or changes in smooth muscle tone and resistance that can accompany BPH may result in lower urinary tract symptoms (LUTS).1 LUTS include storage disturbances (such as daytime urinary urgency and nocturia) and/or voiding disturbances (such as urinary hesitancy, weak urinary stream, straining to void, and prolonged voiding).2 LUTS affect an estimated 3 percent of men ages 45–49 years old increasing to around 30 percent of men over 85 years old.2 Urinary hesitancy, weak stream, and nocturia are the most commonly reported LUTS.4 LUTS attributed to BPH may negatively impact quality of life2,3 and cost the United States over $1 billion annually.3

Usually, BPH diagnosis is based on clinical presentation of bothersome LUTS or enlarged prostate on digital rectal exam. However, an enlarged prostate may not cause any urinary symptoms, so when LUTS are present, causes other than BPH still should be ruled out.3 Consensus recommendations from the 6th International Consultation on New Developments in Prostate Cancer and Prostate Diseases presented guidance for evaluation of older men with LUTS attributed to BPH.5 Treatment decisions can typically be based on symptoms and degree of bother without need to perform specialized tests such as uroflowmetry and postvoid residual urine (PVR) measurement.1,3

Lifestyle interventions such as modifying fluid intake or toileting behavior are typically the first-line treatments to reduce symptoms in patients with LUTS/BPH. When necessary, pharmacological treatment also may be initiated to reduce symptoms and prevent or delay disease progression. Pharmacological management of LUTS attributed to BPH has evolved over the last 25 years. Table 1 provides a list of drugs commonly used to treat LUTS attributed to BPH. Alpha blockers (ABs) and 5-alpha reductase inhibitors (5-ARIs) have been used to treat LUTS attributed to BPH for decades and their efficacy has been established. Recently, newer drugs in these classes and drugs in other classes approved for other indications have shown promise in treating LUTS attributed to BPH (Table 1). A new AB, silodosin, was approved for BPH in 2008.^6^ Several anticholinergics drugs approved for overactive bladder (OAB) symptoms, including urinary urgency, frequency and nocturia, have the potential to alleviate LUTS attributed to BPH.7 These anticholinergic drugs work directly on the bladder smooth muscle as opposed to ABs and 5-ARIs, which target the prostate.

Table 1 Medications used to treat LUTS attributed to BPH

Drug Class - Mechanism of Action (FDA) | Medication
Alpha 1 blockers (ABs): Inhibit smooth muscle contraction by blocking alpha-1 receptors and decreasing resistance to urinary flow. | Silodosin^a^ [Rapaflo]
Alpha 1 blockers (ABs): Inhibit smooth muscle contraction by blocking alpha-1 receptors and decreasing resistance to urinary flow. | Terazosin^a^ [Hytrin] Alfuzosin^a^ [Uroxatral] Doxazosin^a^ [Cardura] Tamsulosin^a^ [Flomax]
5 alpha reductase inhibitors (5-ARIs): Inhibit 5-alpha reductase, an isoenzyme metabolizing testosterone to DHT, blocking conversion of testosterone to DHT and reducing DHT. | Finasteride^a^ [Proscar]
5 alpha reductase inhibitors (5-ARIs): Inhibit 5-alpha reductase, an isoenzyme metabolizing testosterone to DHT, blocking conversion of testosterone to DHT and reducing DHT. | Dutasteride^a^ [Avodart]
Anticholinergic agent: Relaxes smooth muscle in urinary bladder. | Oxybutynin^b^ [Oxytrol] Fesoterodine^b^ [Toviaz] Darifenacin^b^ [Enablex] Tolterodine^b^ [Detrol, Detrol LA] Solifenacin^b^ [Vesicare] Trospium^b^ [Sanctura]
Beta-3 adrenergic agonist: Increases bladder capacity by relaxing the smooth muscle of the bladder. | Mirabegron^b^ [Myrbetriq]
Phospodiesterase type 5 (PDE-5) inhibitors: Exact mechanism unclear, presumed to selectively inhibit PDE-5, increasing cyclic guanosine monophosphate (cGMP) and causes smooth muscle relaxation. | Tadalafil a, d [Cialis] Sildenafil^c^ [Viagra] Avanafil^d^ [Stendra] Vardenafil^d^ [Staxyn, Levitra]

BPH=benign prostatic hyperplasia; cGMP=cyclic guanosine monophosphate; DHT= dihydrotestosterone; FDA=Food and Drug Administration, LUTS=lower urinary tract symptoms;

a FDA approved to treat BPH;

b FDA approved to treat overactive bladder;

c FDA approved to treat erectile dysfunction and pulmonary artery hypertension;

d FDA approved to treat erectile dysfunction.

Bolded medications are the medications that are the focus of this review.

Source: Micromedex9

A new class of drugs, beta-3 adrenoceptor agonists, was recently developed to treat OAB. Their proposed advantages over anticholinergics include potentially lower rates of adverse effects and potentially smaller risk of urinary retention.7 Preliminary evidence suggests that these drugs may effectively treat LUTS attributed to BPH, and this usage may increase in the future.8

Tadalafil, a phosphodiesterase type 5 inhibitor (PDE-5), was approved by the Food and Drug Administration (FDA) for the treatment of erectile dysfunction (ED) in 2003 and for the treatment of BPH in 2011. Other PDE-5 inhibitors have been used off-label for LUTS attributed to BPH, both alone and in combination with ABs.

Based on the wide variety of medications available to treat LUTS attributed to BPH, it is possible that tailoring treatment with single medications or medication combinations can maximize efficacy or effectiveness and minimize adverse effects. Some patients are more bothered by specific symptoms that may be preferentially improved by certain medications. Men with LUTS attributed to BPH often have other health conditions or are taking other medications that should be considered in choice of pharmacologic therapy for LUTS attributed to BPH.

The primary goals of LUTS attributed to BPH treatment are to reduce LUTS, improve prostate-related quality of life, and prevent or delay disease progression. The two most widely used, validated instruments for assessment of LUTS are the American Urological Association Symptom Index (AUA-SI) and the International Prostate Symptom Score (I-PSS).6 These two instruments are identical with the exception of an additional question in the I-PSS regarding global bother.

Intermediate outcomes such as specific urodynamic parameters (i.e., peak flow, detrusor pressure) are often reported in research. However, these outcomes are not patient centered, are not relevant to primary care settings, and it is unclear whether they should guide treatment decisions.

Clinical practice guidelines play an important role in guiding evidence-based clinical practice. According to Institute of Medicine standards, they need to be based on high quality systematic reviews of the entire body of evidence and there is an important need to provide an up-to-date systematic review that accounts for more recently approved medications for LUTS attributed to BPH. Our review comprehensively assesses medications for LUTS attributed to BPH that have been newly used in the last 10 years. In this report, we synthesized available data regarding efficacy, comparative effectiveness, and adverse effects of one new AB (silodosin); all anticholinergics, beta-3 agonists, and PDE-5 inhibitors; and medication combinations that include these agents. The addition of this evidence synthesis to what already is understood about the earlier developed ABs, 5-ARIs, and AB/5-ARI combinations will provide a comprehensive assessment of all medical management options for LUTS attributed to BPH (Table 1).

We address the following Key Questions (KQs) as they pertain to the PICOTS (population, interventions, comparisons, outcomes, timing, and setting) (Table 2):

Table 2 PICOTS (population, interventions, comparisons, outcomes, timing, and setting)

PICOTS Element | Description
Population(s) | Adult men (age 45 years and over) with LUTS attributed to BPH, overall and in subgroups defined by BMI, erectile dysfunction, LUTS severity, and previous LUTS treatment.
Interventions | Medications recently FDA approved for BPH or newly studied off-label for LUTS attributable to BPH
Comparators | Placebo or “older” LUTS attributed to BPH medication (i.e., previously FDA approved for BPH) (Table 1).
Outcomes | Primary Outcomes: LUTS scores (I-PSS, AUA-SS); Prostate-related bother or quality of life (QoL) (I-PSS QoL question, BPH/LUTS impact (BII) scale); Disease Progression/Treatment Failure (prevention/delay of need for surgical intervention, AUR, 3-point increase in I-PSS score). Adverse effects: Common and serious medication side effects.
Timing | Short term: treatment duration of 1 to less than 6 months. Intermediate: treatment duration of at least 6 months and less than 1 year. Long term: treatment duration of 1 year or more.
Setting | Outpatient settings.

AUA-SI=American Urological Association Symptom score; AUR=Acute urinary retention; BII-BPH Impact Index; BMI=Body mass index; BPH=Benign prostatic hyperplasia; FDA=Food and Drug Administration; I-PSS=International Prostate Symptom Scale; LUTS=Lower urinary tract symptoms

## Key Questions (KQs)

KQ 1: What are the efficacy and comparative effectiveness of newer medications alone or in combination for LUTS attributed to BPH?

KQ 2: What are the harms and comparative harms of newer medications for LUTS attributed to BPH?

KQ 3: Do the comparative benefits and harms of newer medications for LUTS attributed to BPH differ according to demographic or clinical characteristics?