# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Michael J. Barry, M.D.^*^
  Department of Medicine
  Harvard Medical School
  Boston, MA
- Robert R. Byrne, M.D.
  Ellison, Walton and Byrne
  Athens, GA
- Harris Foster, Jr., M.D.
  Department of Urology
  Yale School of Medicine
  New Haven, CT
- Richard M. Hoffman, M.D., M.P.H.
  Professor of Internal Medicine and Epidemiology
  Director, Division of General Internal Medicine
  University of Iowa Carver College of Medicine/Iowa City VA Medical Center
  Iowa City, IA
- John M. Hollingsworth, M.D., M.S.^*^
  Department of Urology
  University of Michigan Medical School
  Ann Arbor, MI
- Ziya Kirkali, M.D.^*^
  Program Director
  Division of Kidney, Urology and Hematology
  National Institute of Diabetes and Digestive and Kidney Diseases
  Bethesda, MD
- Michael LeFevre, M.D., M.S.P.H.
  Professor, Future of Family Medicine
  University of Missouri Family and Community Medicine
  Columbia, MO
- Kevin T. McVary, M.D.^*^
  Division of Urology
  Southern Illinois University School of Medicine
  Springfield, IL
- Justin Sherman, M.C.S., Pharm.D.^*^
  School of Pharmacy
  University of Mississippi
  Jackson, MS

* Provided input on draft report.