# Acknowledgments

We thank Marilyn Eells, Cheryl Cole-Hill, and Jeannine Ouellette for their editorial help bringing the report to completion. We thank Carla Foster and Abid Khan of the American Urologic Association for their contributions. We also thank Dr. Aysegul Gozu and Dr. Jonathan Treadwell for their helpful editorial comments.