# Discussion

We conducted a systematic review with meta-analyses to assess the efficacy and comparative effectiveness of drugs recently proposed to treat LUTS attributed to BPH including one new AB, several anticholinergics, one beta-3 agonist, and several PDE-5s. We sought to evaluate whether these drugs offered advantages over established treatments, primarily older ABs (i.e., tamsulosin, alfuzosin, doxazosin). Overall, we found that several newly used drugs or drug combinations (silodisin, fesoterodine/AB combination, and tadalafil) showed improved outcomes in LUTS attributed to BPH when compared with placebo but offered no benefit over traditional AB treatment, primarily with tamsulosin. Some drugs raised increased safety concerns, although the adverse effects were generally not severe and the event rate was low. These newly used drugs should therefore best be viewed as offering alternative treatment options rather than superior management options, although oftentimes associated with greater uncertainty with regards to associated harmsNewer and additional medications are typically associated with increased resource utilization that must be considered by the provider and patient in deciding on a course of treatment.

The new AB, silodosin, was more effective for LUTS attributed to BPH than placebo. However, it was not more effective than the older AB, tamsulosin, and associated with an increased rate of adverse events. The most common adverse effect associated with silodosin was abnormal ejaculation. This was consistent with reported adverse effects from longer term observational studies.

Anticholinergics (including tolterodine and solifenacin) combined with established ABs improved LUTS attributed to BPH more than placebo. However, neither tolterodine, solifenacin, nor fesoterodine combined with AB offered additional benefits in reducing LUTS over AB monotherapy. Evidence suggests that adverse effects with combination therapy may be higher than with AB monotherapy. AB combinations with oxybutynin, darifenacin, and trospium were also studied in eligible trials, but these comparisons provided insufficient evidence to draw conclusions with regard to any outcome or adverse effect.

Another new agent, the beta-3 agonist mirabegron that has primarily been used for OAB, has been tested in populations of men with LUTS attributed to BPH. However, evidence was insufficient to draw conclusions about efficacy, comparative effectiveness, or adverse effects.

Tadalafil, the single FDA-approved PDE-5 for BPH, was more effective than placebo in treating LUTS attributed to BPH. The associated adverse effects were higher based (high SoE). However, efficacy of tadalafil was similar or inferior to AB monotherapy (tamsulosin or alfuzosin, respectively). Trials did not report how the combination therapy affected blood pressure. Evidence was insufficient to assess efficacy and adverse effects of sildenafil and vardenafil. Evidence was insufficient to draw conclusions about the tadalafil and AB combination therapy compared with AB monotherapy in treating LUTS attributed to BPH. Most trials making this comparison were high risk of bias because they were open label or inadequately blinded and pooled estimates were imprecise. Reductions in blood pressure with this combination is a concern. FDA labeling suggests that patients be stable on AB therapy before starting PDE-5 inhibitor therapy and lower doses of the medications be used.109 Our review did not find evidence of dangerous lowering of blood pressure. Occasional reports of hypotension were reported. However, this also occurs with AB monotherapy and data were too limited for comparison. The potential adverse effect should be taken into consideration by the provider and the patient.

Using the established AHRQ strength of evidence rating system to describe our confidence in conclusions, we arrived at few “high” strength evidence assessments. Precision and study limitations components most frequently weakened the evidence base. Study limitations such as lack of blinding raised the concern for performance and detection bias. Imprecise estimates with lower and upper confidence interval estimates that would be interpreted differently were also common.

Our approach to random effects meta-analysis may also have contributed to the wider confidence intervals and greater imprecision. We initially pooled data with the classic DerSimonian-Laird random effects method. We revised our analysis because this method is likely to underestimate the error in parameter estimates, especially when the number of trials pooled is small.110 Our data were not amenable to random effects estimation with a profile likelihood approach given the low level of statistical heterogeneity, so we opted to use the Hartung-Knapp-Sidik-Jonkman method. This method is conservative and lowers the possibility of false positive meta-analysis results common with DerSimonian-Laird, but can overestimate confidence intervals in some situations. Therefore, when one end of a confidence interval was close to a threshold and on the side of equivalence, we assessed the evidence as insufficient. Had the CI been slightly narrower, we likely would have drawn a conclusion with at least low strength of evidence.

## Limitations

Our review sought to assess the short-, intermediate-, and long-term efficacy and comparative effectiveness of drugs newly used to treat LUTS attributed to BPH. All RCTs were of short duration and therefore provided no data on intermediate- and long-term outcomes and adverse effects. The lack of trials with longer durations prevented analysis of other important outcomes such as disease progression (measured as increases in I-PSS scores or need for surgical intervention). Given that LUTS attributed to BPH is a chronic and progressive condition, we can say little about treatments for the entire course of the disease. This may have implications for patients and clinicians decision whether to initiate these agents long term.

In the body of evidence summarized in this report, acute urinary retention was a relatively rare adverse effect. However, not only were most trials short in duration (12 weeks or less) but participants in trials of drugs known to affect bladder contractility often excluded those with higher postvoid residual urine volumes, thereby possibly removing patients at greatest risk and lowering the incidence of acute urinary retention in the trial population.

This review used prespecified patient important outcomes that were believed to reflect important to patients and critical to decisionmaking about treatment. These outcomes were typically measured with valid and reliable instruments, most commonly the I-PSS/AUA instruments. This instrument creates a summary score aggregating an individual's LUTS symptoms. We used established thresholds to determine clinical significance of the differences between treatments in these instrument scores. To the extent that patients or providers are interested in alleviating specific individual symptoms such as nocturia, thresholds indicating clinical significance are unclear and our report does not analyze that evidence.

While the instrument most commonly used across trials (I-PSS/AUA) has an anchor-based MDD, this was not used consistently in the original research to conduct responder analyses. Pooling responder analyses across trials would have provided the ideal efficacy outcome. Applying this MDD (3 point reduction from baseline) to the weighted mean difference between treatment groups in systematic review is not straightforward because it was derived from individual participant changes from baseline in response to treatment. Comparing differences between treatment groups differs by requiring the weighted mean difference to equal or exceed the mean MDD established from a pre- and post-treatment analysis can be misleading. This approach does not account for any placebo effect and can lead to similar conclusions when both or neither treatment group achieves MDD. We therefore tried to report mean changes from baseline per group in order to provide context regarding improvement relative to the MDD. We also reported the confidence intervals associated with the difference between treatments because means do not accurately describe the range of the effects in the study population and can be misleading, especially when distributions are not standard (i.e., bimodal). We used the established MDD in assessing the precision of estimates and used guidance in interpreting the weighted mean difference. While we believe this to be the appropriate interpretation, statements such as “an appreciable number of patients” achieved clinically significant improvements suggested by the guidance may be considered vague and of limited value. Additionally, others suggest that a higher threshold be used to judge efficacy and comparative effectiveness. Blanker et al. suggests at least a moderate or marked improvement (i.e., 5 and 9 points on the I-PSS) should be the threshold.111 The same WMD and this higher threshold would likely change our interpretation about whether an appreciable number of patients achieved benefits.

Another significant limitation was the number of unblinded trials. These were most often PDE-5 trials that compared PDE-5/AB combination therapy to AB monotherapy. This is especially concerning because our primary efficacy outcomes are subjective; therefore, improvements in ED symptoms could influence perception and responses without meaningful improvements in LUTS attributed to BPH symptoms. However, participant blinding in these trials is difficult in sexually active patients given the efficacy of PDE-5s in treating ED. We did not examine correlations between LUTS outcomes and ED outcomes because extracting ED outcomes was beyond the scope of this review.

There is growing interest in identifying which treatments for LUTS attributed to BPH work best for which patients. However, we identified few trials that examined effects within our prespecified subgroup. Data on subgroups were scattered across comparisons and provide no actionable information based upon patient demographic and clinical characteristics. Most of these analyses were posthoc, limiting the validity and reliability of the evidence.

## Applicability

The body of evidence that we reviewed in this report is largely based on randomized clinical trials that enrolled patients that may differ from the general population. Specifically, most men enrolled in these trials were age 50 – 70 years of age, thereby most notably excluding older men who may be at higher risk for drug-related adverse events. In trials of drugs known to decrease bladder contractility such as anticholinergics, participants were often screened for increased postvoid residuals and often excluded those above a certain threshold. The incidence of acute urinary retention in an unscreened population may therefore be higher.

Additionally, trials of anticholinergics and PDE-5s may not be applicable to the broader population of males with LUTS attributable to BPH. Enrollment criteria for these trials typically involved select symptoms (storage symptoms or ED) to be present. PDE-5s have an established role in the treatment of ED which is a prevalent condition in aging men; potential benefits of the daily use of these drugs of sexual domain-related quality of life were outside the scope of this review. Most PDE-5 trials enrolled males who had not benefited from AB monotherapy and ED history. At the same time, long-term use that exceeds the time-horizon of randomized controlled trials may also increase the of adverse events such as hypotensive episodes, drug interactions, and myocardial infarction, thereby raising safety concerns. It is also important to note that the FDA-approved dose of tadalafil for LUTS is 5 mg, whereas doses of up to 20 mg were used in some trials.

## Future Research Needs

Additional research would add valuable information on the treatment of LUTS attributed to BPH. Trials with longer duration of treatment and followup would provide valuable information on disease progression and long-term outcomes as it progresses with age. Longer time frames would provide important information to assess disease-related complications and drug-related adverse effects, which would be of great value to decisionmakers. Additionally, trials examining subgroups (i.e., BMI status, age, comorbid conditions) and how they respond to various treatments might provide important information useful for decision-making for individual patient. While we found little benefit from the newer drugs, it is possible that they provide benefits to select groups of patients. However, such benefits should be substantiated in appropriately designed that prospectively stratify patients accordingly to allow such inferences.

Trials, especially those conducted in Asian countries, using tamsulosin as a comparator often used 0.2 mg dosage. The standard dosage in the U.S. is 0.4 mg. We compared results of those trials with those using the U.S. standard dose of 0.4 mg and results were very similar.

Trials using drugs traditionally used to treat OAB or ED often enrolled males with LUTS attributed to BPH and the other condition. Results may apply most directly to those patients. Because these medications offered little additional benefit over traditional medications even in these populations, it is not likely results would be different in males with LUTS attributed solely to BPH.

Future studies would benefit from consistently conducting responder analysis (comparing the rates of response using MDD threshold) in addition to analysis of I-PSS scores. While providing complementary information, information from a responder analyses may provide data that are intuitively easier to understand, for example through NNT (number needed to treat) and NNH (number needed to harm), which can be calculated from dichotomous variables, but not continuous variables.

## Conclusion

None of the drugs or drug combinations newly used to treat LUTS attributed to BPH showed outcomes superior to traditional AB treatment. Monotherapy with silodosin and tadalafil improved short-term LUTS more than placebo. Silodosin was equivalent to tamsulosin in improving LUTS and had higher adverse effects. Combination therapies adding an anticholinergic to an established AB offered no benefit over AB monotherapy in improving LUTS and often increased the rate of adverse effects. Silodosin and tadalafil were equivalent to tamsulosin in improving LUTS, but silodosin and tadalafil were associated with higher adverse effects. Data were not available to assess long-term maintenance, prevention of disease progression (including acute urinary retention or need for surgical intervention), and adverse effects.