# Appendix H References for Appendixes

1 Seki N, Takahashi R, Yamaguchi A, et al. (2015). Non-inferiority of silodosin 4mg once daily to twice daily for storage symptoms score evaluated by the International Prostate Symptom Score in Japanese patients with benign prostatic hyperplasia: A multicenter, randomized, parallel-group study. Int J Urol.
2 Choo MS, Song M, Kim JH, et al. (2014). Safety and efficacy of 8-mg once-daily vs 4-mg twice-daily silodosin in patients with lower urinary tract symptoms suggestive of benign prostatic hyperplasia (SILVER Study): a 12-week, double-blind, randomized, parallel, multicenter study. Urology.
3 Pande S, Hazra A, Kundu AK. (2014). Evaluation of silodosin in comparison to tamsulosin in benign prostatic hyperplasia: a randomized controlled trial. Indian J Pharmacol.
4 Yokoyama T, Hara R, Fujii T, et al. (2012). Comparison of Two Different alpha1-Adrenoceptor Antagonists, Tamsulosin and Silodosin, in the Treatment of Male Lower Urinary Tract Symptoms Suggestive of Benign Prostatic Hyperplasia: A Prospective Randomized Crossover Study. LUTS: Lower Urinary Tract Symptoms.
5 Chapple CR, Montorsi F, Tammela TL, et al. (2011). Silodosin therapy for lower urinary tract symptoms in men with suspected benign prostatic hyperplasia: results of an international, randomized, double-blind, placebo- and active-controlled clinical trial performed in Europe. Eur Urol.
6 Watanabe T, Ozono S, Kageyama S. (2011). A randomized crossover study comparing patient preference for tamsulosin and silodosin in patients with lower urinary tract symptoms associated with benign prostatic hyperplasia. Journal of International Medical Research.
7 Yokoyama T, Hara R, Fukumoto K, et al. (2011). Effects of three types of alpha-1 adrenoceptor blocker on lower urinary tract symptoms and sexual function in males with benign prostatic hyperplasia. Int J Urol.
8 Yu HJ, Lin AT, Yang SS, et al. (2011). Non-inferiority of silodosin to tamsulosin in treating patients with lower urinary tract symptoms (LUTS) associated with benign prostatic hyperplasia (BPH). BJU Int.
9 Miyakita H, Yokoyama E, Onodera Y, et al. (2010). Short-term effects of crossover treatment with silodosin and tamsulosin hydrochloride for lower urinary tract symptoms associated with benign prostatic hyperplasia. Int J Urol.
10 Marks LS, Gittelman MC, Hill LA, et al. (2009). Rapid efficacy of the highly selective alpha1A-adrenoceptor antagonist silodosin in men with signs and symptoms of benign prostatic hyperplasia: pooled results of 2 phase 3 studies. J Urol.
11 Kawabe K, Yoshida M, Homma Y, et al. (2006). Silodosin, a new alpha1A-adrenoceptor-selective antagonist for treating benign prostatic hyperplasia: results of a phase III randomized, placebo-controlled, double-blind study in Japanese men. BJU Int.
12 Eisenhardt A, Schneider T, Cruz F, et al. (2014). Consistent and significant improvement of nighttime voiding frequency (nocturia) with silodosin in men with LUTS suggestive of BPH: pooled analysis of three randomized, placebo-controlled, double-blind phase III studies. World J Urol.
13 Novara G, Chapple CR, Montorsi F. (2014). A pooled analysis of individual patient data from registrational trials of silodosin in the treatment of non-neurogenic male lower urinary tract symptoms (LUTS) suggestive of benign prostatic hyperplasia (BPH). BJU Int.
14 Marks LS, Gittelman MC, Hill LA, et al. (2013). Rapid efficacy of the highly selective alpha(1A)-adrenoceptor antagonist silodosin in men with signs and symptoms of benign prostatic hyperplasia: pooled results of 2 phase 3 studies. J Urol.
15 Gittelman MC, Marks LS, Hill LA, et al. (2011). Effect of silodosin on specific urinary symptoms associated with benign prostatic hyperplasia: Analysis of international prostate symptom scores in 2 phase III clinical studies. Open Access Journal of Urology.
16 Kaplan SA, Roehrborn CG, Hill LA, et al. (2011). Effect of estimated prostate volume on silodosin-mediated improvements in the signs and symptoms of BPH: does prostate size matter?. Open Access Journal of Urology.
17 Roehrborn CG, Kaplan SA, Lepor H, et al. (2011). Symptomatic and urodynamic responses in patients with reduced or no seminal emission during silodosin treatment for LUTS and BPH. Prostate Cancer and Prostatic Diseases.
18 Homma Y, Kawabe K, Takeda M, et al. (2010). Ejaculation disorder is associated with increased efficacy of silodosin for benign prostatic hyperplasia. Urology.
19 Liao CH, Kuo HC. (2015). How to choose first-line treatment for men with predominant storage lower urinary tract symptoms: a prospective randomised comparative study. Int J Clin Pract.
20 Singh I, Garg G, Agarwal V. (2015). 'Tamsulosin and darifenacin versus ‘tamsulosin monotherapy’ for ‘BPH with accompanying overactive bladder’. Journal of Clinical and Diagnostic Research.
21 Ko K, Yang DY, Lee WK, et al. (2014). Effect of improvement in lower urinary tract symptoms on sexual function in men: Tamsulosin monotherapy vs. combination therapy of tamsulosin and solifenacin. Korean Journal of Urology.
22 Lee SH, Byun SS, Lee SJ, et al. (2014). Effects of initial combined tamsulosin and solifenacin therapy for overactive bladder and bladder outlet obstruction secondary to benign prostatic hyperplasia: a prospective, randomized, multicenter study. Int Urol Nephrol.
23 Memon I, Javed A, Pirzada AJ, et al. (2014). Efficacy of Alfuzosin with or without Tolterodine, in Benign Prostatic Hyperplasia (BPH) having irritative (overactive bladder) symptoms. Rawal Medical Journal.
24 Kaplan SA, He W, Koltun WD, et al. (2013). Solifenacin plus tamsulosin combination treatment in men with lower urinary tract symptoms and bladder outlet obstruction: a randomized controlled trial. European Urology.
25 Van Kerrebroeck P, Haab F, Angulo JC, et al. (2013). Efficacy and safety of solifenacin plus tamsulosin OCAS in men with voiding and storage lower urinary tract symptoms: results from a phase 2, dose-finding study (SATURN). Eur Urol.
26 van Kerrebroeck P, Chapple C, Drogendijk T, et al. (2013). Combination therapy with solifenacin and tamsulosin oral controlled absorption system in a single tablet for lower urinary tract symptoms in men: efficacy and safety results from the randomised controlled NEPTUNE trial. Eur Urol.
27 Ceylan C, Ertas K, Dogan S, et al. (2012). alpha-Bloker Monoterapisi ile alpha-Bloker+M3 Selektif Antimuskarinik Kombine Tedavisinin Karsi{dotless}lasti{dotless}ri{dotless}lmasi{dotless}. Journal of Clinical and Analytical Medicine.
28 Konstantinidis C, Samarinas M, Andreadakis S, et al. (2013). Lower urinary tract symptoms associated with benign prostatic hyperplasia: combined treatment with fesoterodine fumarate extended-release and tamsulosin--a prospective study. Urol Int.
29 Malkoc E, Ates F, Senkul T, et al. (2012). Additive role of trospium chloride in the management of men with voiding and storage symptoms. Turkiye Klinikleri Journal of Medical Sciences.
30 Chung SD, Chang HC, Chiu B, et al. (2011). The efficacy of additive tolterodine extended release for 1-year in older men with storage symptoms and clinical benign proastatic hyperplasia. Neurourol Urodyn.
31 Kaplan SA, Roehrborn CG, Gong J, et al. (2011). Add-on fesoterodine for residual storage symptoms suggestive of overactive bladder in men receiving alpha-blocker treatment for lower urinary tract symptoms. BJU Int.
32 Lee SH, Chung BH, Kim SJ, et al. (2011). Initial combined treatment with anticholinergics and alpha-blockers for men with lower urinary tract symptoms related to BPH and overactive bladder: a prospective, randomized, multi-center, double-blind, placebo-controlled study. Prostate Cancer Prostatic Dis.
33 Seo DH, Kam SC, Hyun JS. (2011). Impact of lower urinary tract symptoms/benign prostatic hyperplasia treatment with tamsulosin and solifenacin combination therapy on erectile function. Korean Journal of Urology.
34 Yamaguchi O, Kakizaki H, Homma Y, et al. (2011). Solifenacin as add-on therapy for overactive bladder symptoms in men treated for lower urinary tract symptoms--ASSIST, randomized controlled study. Urology.
35 Chapple C, Herschorn S, Abrams P, et al. (2009). Tolterodine treatment improves storage symptoms suggestive of overactive bladder in men treated with alpha-blockers. Eur Urol.
36 Kaplan SA, McCammon K, Fincher R, et al. (2009). Safety and tolerability of solifenacin add-on therapy to alpha-blocker treated men with residual urgency and frequency. J Urol.
37 MacDiarmid SA, Peters KM, Chen A, et al. (2008). Efficacy and safety of extended-release oxybutynin in combination with tamsulosin for treatment of lower urinary tract symptoms in men: randomized, double-blind, placebo-controlled study. Mayo Clin Proc.
38 Kaplan SA, Roehrborn CG, Rovner ES, et al. (2006). Tolterodine and tamsulosin for treatment of men with lower urinary tract symptoms and overactive bladder: a randomized controlled trial. Jama.
39 Singh DV, Mete UK, Mandal AK, et al. (2014). A comparative randomized prospective study to evaluate efficacy and safety of combination of tamsulosin and tadalafil vs. tamsulosin or tadalafil alone in patients with lower urinary tract symptoms due to benign prostatic hyperplasia. Journal of Sexual Medicine.
40 Kaplan SA, McCammon K, Fincher R, et al. (2013). Safety and tolerability of solifenacin add-on therapy to alpha-blocker treated men with residual urgency and frequency. J Urol.
41 Kaplan SA, Roehrborn CG, Chancellor M, et al. (2008). Extended-release tolterodine with or without tamsulosin in men with lower urinary tract symptoms and overactive bladder: effects on urinary symptoms assessed by the International Prostate Symptom Score. BJU Int.
42 Roehrborn CG, Kaplan SA, Kraus SR, et al. (2008). Effects of serum PSA on efficacy of tolterodine extended release with or without tamsulosin in men with LUTS, including OAB. Urology.
43 Roehrborn CG, Kaplan SA, Jones JS, et al. (2009). Tolterodine extended release with or without tamsulosin in men with lower urinary tract symptoms including overactive bladder symptoms: effects of prostate size. Eur Urol.
44 Ichihara K, Masumori N, Fukuta F, et al. (2014). A randomized controlled study of the efficacy of tamsulosin monotherapy and its combination with mirabegron for overactive bladder induced by benign prostatic obstruction. J Urol.
45 Nitti VW, Rosenberg S, Mitcheson DH, et al. (2013). Urodynamics and safety of the beta3-adrenoceptor agonist mirabegron in males with lower urinary tract symptoms and bladder outlet obstruction. J Urol.
46 Casabe A, Roehrborn CG, Da Pozzo LF, et al. (2014). Efficacy and safety of the coadministration of tadalafil once daily with finasteride for 6 months in men with lower urinary tract symptoms and prostatic enlargement secondary to benign prostatic hyperplasia. J Urol.
47 Kumar S, Kondareddy C, Ganesamoni R, et al. (2014). Randomized controlled trial to assess the efficacy of the combination therapy of alfuzosin and tadalafil in patients with lower urinary tract symptoms due to benign prostatic hyperplasia. LUTS: Lower Urinary Tract Symptoms.
48 Takeda M, Yokoyama O, Lee SW, et al. (2014). Tadalafil 5 mg once-daily therapy for men with lower urinary tract symptoms suggestive of benign prostatic hyperplasia: results from a randomized, double-blind, placebo-controlled trial carried out in Japan and Korea. Int J Urol.
49 Abolyosr A, Elsagheer GA, Abdel-Kader MS, et al. (2013). Evaluation of the effect of sildenafil and/or doxazosin on Benign prostatic hyperplasia-related lower urinary tract symptoms and erectile dysfunction. Urology Annals.
50 Regadas RP, Reges R, Cerqueira JBG, et al. (2013). Urodynamic effects of the combination of tamsulosin and daily tadalafil in men with lower urinary tract symptoms secondary to benign prostatic hyperplasia: A randomized, placebo-controlled clinical trial. International Urology and Nephrology.
51 Yokoyama O, Yoshida M, Kim SC, et al. (2013). Tadalafil once daily for lower urinary tract symptoms suggestive of benign prostatic hyperplasia: a randomized placebo- and tamsulosin-controlled 12-week study in Asian men. Int J Urol.
52 Egerdie RB, Auerbach S, Roehrborn CG, et al. (2012). Tadalafil 2.5 or 5 mg administered once daily for 12 weeks in men with both erectile dysfunction and signs and symptoms of benign prostatic hyperplasia: results of a randomized, placebo-controlled, double-blind study. Journal of Sexual Medicine.
53 Gacci M, Vittori G, Tosi N, et al. (2012). A randomized, placebo-controlled study to assess safety and efficacy of vardenafil 10 mg and tamsulosin 0.4 mg vs. tamsulosin 0.4 mg alone in the treatment of lower urinary tract symptoms secondary to benign prostatic hyperplasia. Journal of Sexual Medicine.
54 Goldfischer E, Kowalczyk JJ, Clark WR, et al. (2012). Hemodynamic effects of once-daily tadalafil in men with signs and symptoms of benign prostatic hyperplasia on concomitant alpha1-adrenergic antagonist therapy: results of a multicenter randomized, double-blind, placebo-controlled trial. Urology.
55 Madani AH, Afsharimoghaddam A, Roushani A, et al. (2012). Evaluation of Tadalafil effect on lower urinary tract symptoms of benign prostatic hyperplasia in patients treated with standard medication. Int Braz J Urol.
56 Oelke M, Giuliano F, Mirone V, et al. (2012). Monotherapy with tadalafil or tamsulosin similarly improved lower urinary tract symptoms suggestive of benign prostatic hyperplasia in an international, randomised, parallel, placebo-controlled clinical trial. Eur Urol.
57 Ozturk MI, Kalkan S, Koca O, et al. (2012). Efficacy of alfuzosin and sildenafil combination in male patients with lower urinary tract symptoms. Andrologia.
58 Takeda M, Nishizawa O, Imaoka T, et al. (2012). Tadalafil for the Treatment of Lower Urinary Tract Symptoms in Japanese Men with Benign Prostatic Hyperplasia: Results from a 12-week Placebo-controlled Dose-finding Study with a 42-week Open-label Extension. LUTS: Lower Urinary Tract Symptoms.
59 Kim SC, Park JK, Kim SW, et al. (2011). Tadalafil Administered Once Daily for Treatment of Lower Urinary Tract Symptoms in Korean men with Benign Prostatic Hyperplasia: Results from a Placebo-Controlled Pilot Study Using Tamsulosin as an Active Control. LUTS: Lower Urinary Tract Symptoms.
60 Porst H, Kim ED, Casabe AR, et al. (2011). Efficacy and safety of tadalafil once daily in the treatment of men with lower urinary tract symptoms suggestive of benign prostatic hyperplasia: results of an international randomized, double-blind, placebo-controlled trial. Eur Urol.
61 Dmochowski R, Roehrborn C, Klise S, et al. (2010). Urodynamic effects of once daily tadalafil in men with lower urinary tract symptoms secondary to clinical benign prostatic hyperplasia: a randomized, placebo controlled 12-week clinical trial. J Urol.
62 Tuncel A, Nalcacioglu V, Ener K, et al. (2010). Sildenafil citrate and tamsulosin combination is not superior to monotherapy in treating lower urinary tract symptoms and erectile dysfunction. World J Urol.
63 Liguori G, Trombetta C, De Giorgi G, et al. (2009). Efficacy and safety of combined oral therapy with tadalafil and alfuzosin: an integrated approach to the management of patients with lower urinary tract symptoms and erectile dysfunction. Preliminary report. Journal of Sexual Medicine.
64 Roehrborn CG, McVary KT, Elion-Mboussa A, et al. (2008). Tadalafil administered once daily for lower urinary tract symptoms secondary to benign prostatic hyperplasia: a dose finding study. J Urol.
65 Stief CG, Porst H, Neuser D, et al. (2008). A randomised, placebo-controlled study to assess the efficacy of twice-daily vardenafil in the treatment of lower urinary tract symptoms secondary to benign prostatic hyperplasia. Eur Urol.
66 McVary KT, Monnig W, Camps JL, et al. (2007). Sildenafil Citrate Improves Erectile Function and Urinary Symptoms in Men With Erectile Dysfunction and Lower Urinary Tract Symptoms Associated With Benign Prostatic Hyperplasia: A Randomized, Double-Blind Trial. J Urol.
67 McVary KT, Roehrborn CG, Kaminetsky JC, et al. (2007). Tadalafil relieves lower urinary tract symptoms secondary to benign prostatic hyperplasia. J Urol.
68 Kaplan SA, Gonzalez RR, Te AE. (2007). Combination of Alfuzosin and Sildenafil is Superior to Monotherapy in Treating Lower Urinary Tract Symptoms and Erectile Dysfunction. Eur Urol.
69 Lee SW, Paick JS, Park HJ, et al. (2014). The Efficacy and Safety of Tadalafil 5 mg Once Daily in Korean Men with Lower Urinary Tract Symptoms Suggestive of Benign Prostatic Hyperplasia: An Integrated Analysis. World j.
70 Roehrborn CG, Chapple C, Oelke M, et al. (2014). Effects of tadalafil once daily on maximum urinary flow rate in men with lower urinary tract symptoms suggestive of benign prostatic hyperplasia. J Urol.
71 Porst H, Roehrborn CG, Secrest RJ, et al. (2013). Effects of tadalafil on lower urinary tract symptoms secondary to benign prostatic hyperplasia and on erectile dysfunction in sexually active men with both conditions: analyses of pooled data from four randomized, placebo-controlled tadalafil clinical studies. Journal of Sexual Medicine.
72 Porst H, Oelke M, Goldfischer ER, et al. (2013). Efficacy and safety of tadalafil 5 mg once daily for lower urinary tract symptoms suggestive of benign prostatic hyperplasia: subgroup analyses of pooled data from 4 multinational, randomized, placebo-controlled clinical studies. Urology.
73 Brock GB, McVary KT, Roehrborn CG, et al. (2014). Direct effects of tadalafil on lower urinary tract symptoms versus indirect effects mediated through erectile dysfunction symptom improvement: Integrated data analyses from 4 placebo controlled clinical studies. J Urol.
74 Oelke M, Weiss JP, Mamoulakis C, et al. (2014). Effects of tadalafil on nighttime voiding (nocturia) in men with lower urinary tract symptoms suggestive of benign prostatic hyperplasia: a post hoc analysis of pooled data from four randomized, placebo-controlled clinical studies. World J Urol.
75 Oelke M, Giuliano F, Baygani SK, et al. (2014). Treatment satisfaction with tadalafil or tamsulosin vs placebo in men with lower urinary tract symptoms (LUTS) suggestive of benign prostatic hyperplasia (BPH): results from a randomised, placebo-controlled study. BJU Int.
76 Brock G, Broderick G, Roehrborn CG, et al. (2013). Tadalafil once daily in the treatment of lower urinary tract symptoms (LUTS) suggestive of benign prostatic hyperplasia (BPH) in men without erectile dysfunction. BJU Int.
77 Dmochowski R, Roehrborn C, Klise S, et al. (2013). Urodynamic effects of once daily tadalafil in men with lower urinary tract symptoms secondary to clinical benign prostatic hyperplasia: a randomized, placebo controlled 12-week clinical trial. J Urol.
78 Broderick GA, Brock GB, Roehrborn CG, et al. (2010). Effects of tadalafil on lower urinary tract symptoms secondary to benign prostatic hyperplasia in men with or without erectile dysfunction. Urology.
79 McVary KT, Siegel RL, Carlsson M. (2008). Sildenafil Citrate Improves Erectile Function and Lower Urinary Tract Symptoms Independent of Baseline Body Mass Index or LUTS Severity. Urology.