# Appendix G Supporting Tables and Figures: PDE-5 Inhibitors

Table G1 Risk of bias assessments: PDE-5 trials

Study | Overall Risk of Bias Assessment | Rationale
Casabe, 2014^46^ | Low
Kumar, 2014^47^ | High | Randomization methods not reported, different pills taken at different times, inadequate patient and provider blinding; assessors likely unblinded, no attrition
Singh, 2014^39^ | High | Allocation methods unclear, open label
Takeda, 2014^48^ | Low | Randomization and allocation methods unclear.
Abolyosr, 2013^49^ | High | Randomization and allocation methods unclear, unblinded and no placebo, no between group analyses, attrition unclear
Regadas, 2013^50^ | Moderate | Allocation methods unclear, small sample size, attrition unclear
Yokoyama, 2013^51^ | Moderate | Allocation methods unclear, baseline reported with standard deviation but results reported with standard error
Egerdie, 2012^52^ | Low
Gacci, 2012^53^ | Moderate
Goldfischer, 2012^54^ | Low
Madani, 2012^55^ | Moderate | Allocation methods unclear, “standard therapy” differed between treatment groups, no between group analyses, no attrition
Oelke, 2012^56^ | Low
Ozturk, 2012^57^ | High | Allocation methods unclear, unblinded and no placebo, moderate sample size, some results not reported
Takeda, 2012^58^ | Low
Kim, 2011^59^ | Moderate | Allocation methods unclear. groups similar at baseline except for history of erectile dysfunction, pilot study, baseline reported with standard deviation but results reported with standard error
Porst, 2011^60^ | Low
Dmochowski, 2010^61^ | Moderate | Completer analysis
Tuncel, 2010^62^ | Moderate | Randomization methods not reported, unblinded and no placebo, small sample size, some key outcomes reported in figures only
Liguori, 2009^63^ | High | Allocation methods unclear, open label, no between group analyses, completer analysis
Roehrborn, 2008^64^ | Low
Stief, 2008^65^ | Low
McVary, 2007a66 | Low
McVary, 2007b67 | Moderate | Allocation methods unclear, one-sided alpha level used, unclear how attrition handled
Kaplan, 2007^68^ | High | Randomization and allocation methods unclear, unblinded and no placebo, small sample size

Table G2 Summary of PDE-5 Trials: Tadalafil

Characteristic | Mean (range) Unless Otherwise Noted | Number of Studies Reporting
Total randomized | 5786 (40 to 1058) | 15
Percentage randomized based on # screened | 70 (54 to 87) | 13
Received placebo, # randomized (% all randomized) | 1641 (28) (51 to 304) | 10
Received alpha-blocker, #randomized (% all randomized) | 481 (8) (20 to 168) | 7
Received combined tadalafil and alpha-blocker, # randomized (% all randomized) | 112 (2) (20 to 44) | 4
Received 5-ARI, # randomized (% all randomized) | 350 (6) | 1
Received combined tadalafil and 5-ARI, # randomized (% all randomized) | 346 (6) | 1
Age of subjects, years | 62 (59 to 65) | 14
Percentage white race | 55 (0^a^ to 93) | 13
Baseline I-PSS | 18 (15 to 22) | 15
Percentage with over active bladder symptoms | 1- 7%^b^ | 2
Percentage with erectile dysfunction | 72 (59 to 100) | 9^c^

a All subjects from trials conducted in Asia (Korea, Japan, India: k=6; n=2003) presumed to be non-European white

b Reported as previously received OAB therapy

c One trial did not report percentage with ED but change in the Index of Erectile Function score was an outcome; Another trial only reported report percentage with ED in men who were sexually active.

Table G3 Characteristics of BPH treatment, comparison, and population: PDE-5 trials

Study Country Number Randomized | Intervention Comparisons | Duration | Inclusion/Exclusion Criteria | Population Characteristics
Casabe, 2014^46^ North America, South America, Europe N=696 | T: Tadalafil 5 mg qd; finasteride 5 mg qd C: Finasteride qd | 12 wk | I: Age >45 yr; I-PSS ≥13; LUTS/BPH >6 mo; prostate volume ≥30 mL; Qmax 5-15 mL/s; naïve to 5-ARIs E: NR | Mean age: 64 Race: 86% white Baseline I-PSS: 17.3
Kumar, 2014^47^ India N=75 | T_1_: Tadalafil 10 mg qd; afluzosin 10 mg qd T_2_: Tadalafil 10 mg qd C_1_: Afluzosin 10 mg qd | 12 wk | I: Age >50 yr; I-PSS ≥8 E: According to the specified contraindications of both the drugs | Mean age: 62 Race: NR Baseline I-PSS: 17.8
Singh, 2014^39^ India N=133 | T_1_: Tadalafil 10 mg qd; tamsulosin 0.4 mg qd T_2_: Tadalafil 10 mg qd C: Tamsulosin 0.4 mg qd | 13 wk | I: Age >45 yr; I-PSS ≥8; LUTS/BPH ≥6 mo; PSA ≤4.0 ng/mL; Qmax 5-15 mL/s; voided volume >125 mL E: Contraindications to drugs in study; use of finasteride/dutasteride or prohibited medications like alpha agonists; syncope, orthostatic hypotension; BOO due to cancer, calculi or stricture; previous TURP; any neurological disorders affecting storage and voiding; prostatitis or cancer; recent AUR; UTI; poorly controlled diabetes mellitus or hypertension | Mean age: 61 Race: NR Baseline I-PSS: 21.0
Takeda, 2014^48^ Lee, 2014^69^ Japan, Korea N=610 | T: Tadalafil 5 mg qd C: Placebo | 12 wk | I: Age ≥45 yr; I-PSS ≥13; Qmax 4-15 mL/s; prostate volume >20 mL; PVR <300 mL E: PSA >10 ng/mL (or ≥4 ng/mL if prostate cancer could not be ruled out); sugary on pelvic urinary tract; recent finasteride, dutasteride, anti-androgenic hormone therapy, or other BPH, ED or OAB therapies | Mean age: 61 Race: NR Baseline I-PSS: 18.7
Abolyosr, 2013^49^ Egypt N=150 | T_1_: Sildenafil 50 mg; doxazosin 2 mg T_2_: Sildenafil 50 mg C: Doxazosin 2 mg | 17 wk | I: Age ≥45 yr; I-PSS >7; LUTS/ BPH ≥3; ED ≥3 mo; IIEF-EF <25 E: Previous prostatic surgery or other surgery for BPH; cystitis or bladder stones; PSA >10; contraindications for medical treatment for ED (cardiac problems which contraindicate the use of PDE-5 inhibitors, needing surgery); previous unresponsiveness to PDE‑5s | Mean age: NR Race: NR Baseline I-PSS: 16.7
Regadas, 2013^50^ Brazil N= 40 | T: Tadalafi 5 mg qd; tamsulosin 0.4 mg qd C: Placebo; tamsulosin 0.4 mg qd | 4 wk | I: Age ≥45 yr; I-PSS >14; LUTS secondary to BPH; BOOI >20 E: Prostate cancer, LUTS not related to BPH, hypotension, retinitis pigmentosa; recent 5-ARIs, ABs, anticholinergics, PDE-5s; surgery of the prostate, urethra, or bladder; neurological disease, urinary retention, bladder stones; use of nitrates; cardiovascular, hepatic, or renal insufficiency | Mean age: 61 Race: NR Baseline I-PSS: 20.5
Yokoyama, 2013^51^ Lee, 2014^69^ Japan, Korea, Taiwan N=1224 | T_1_: Tadalafil 2.5 mg qd T_2_: Tadalafil 5 mg qd C_1_: Placebo C_2_: Tamsulosin 0.2 mg qd | 12 wk | I: Age ≥45 yr; I-PSS ≥13; Qmax 4 - 15 mL/s; prostate volume ≥20 mL; LUTS >6 mo; PVR <300 mL E: PSA >10 ng/mL (or PSA 4 - 10 ng/mL, unless clinically negative for prostate cancer); history of symptomatic orthostatic hypotension, dizziness, vertigo, LOC, or syncope; clinical prostate cancer or urinary tract conditions affecting LUTS; severe renal or hepatic insufficiency; recent finasteride or dutasteride; cardiac conditions or nitrate use | Mean age: 63 Race: NR Baseline I-PSS: 16.8
Egerdie, 2012^52^ Roehrborn, 2014^70^ Porst, 2013^71^ Porst, 2013^72^ Brock, 2014^73^ Oelke, 2014^74^ Europe, Mexico, USA N=806 | T_1_: Tadalafil 2.5 mg qd T_2_: Tadalafil 5 mg qd C: Placebo | 12 wk | I: Age ≥45 yr; I-PSS ≥13; LUTS >6 mo and ED ≥3 mo; Qmax 4-15 mL/s; ≥4 intercourse attempts; 70% compliant during run-in; PVR <300 mL E: PSA >10 ng/mL (or PSA 4-10 ng/mL, unless cancer ruled out); ED due to other primary sexual disorders or endocrine disease; prior nonresponsiveness to PDE 5s; certain cardiac conditions; recent finasteride or dutasteride; recent lower urinary tract instrumentation; urethral or intravesicle obstruction; recent urinary retention or stones; neurogenic bladder, renal insufficiency, or hepatic impairment | Mean age: 63 Race: 93% white Baseline I-PSS: 18.3
Gacci, 2012^53^ Italy N=60 | T: Vardenafil 10 mg qd; tamsulosin 0.4 mg qd C: Placebo; tamsulosin 0.4 mg qd | 12 wk | I: Age 40–80 yr; LUTS ( I-PSS ≥12, OAB questionnaire-Short Form ≥8); voided volume <400 mL; Qmax >5 mL/s (with a voided volume >150 mL) E: Hypersensitivity to vardenafil or tamsulosin; drugs incompatible with vardenafil or tamsulosin; bladder failure (abnormal urodynamic assessment in men with PVR >250 mL); neurogenic bladder (multiple sclerosis, Parkinson, spinal cord injury), UTI, LUT disease/treatment (urethral stenosis, 5-ARI, or BPH surgery); severe systemic disease (hepatic, cardiac, hematological, or neoplastic); unable to complete the protocol | Mean age: 68 Race: 100% white Baseline I-PSS: 19.6
Goldfischer, 2012^54^ USA N= 318 | T: Tadalafil 5 mg qd; AB C: Placebo; AB | 12 wk | I: Age ≥45 yr; LUTS from BPH >6 mo; stable dose of AB for BPH ≥4 wk E: PSA >10 ng/mL (or PSA ≥4 to <10 ng/mL, unless malignancy ruled out; PVR ≥300 mL; AB for hypertension | Mean age: 67 Race: 89% white Baseline I-PSS: 13.6
Madani, 2012^55^ Iran N=132 | T: Tadalafil 10 mg qd; standard treatment (AB or finasteride) C: Placebo; standard treatment (AB or finasteride) | 13 wk | I: I-PSS ≥8; LUTS/BPH; Qmax 5-15 mL/s; no indication for surgical intervention; had reached plateau levels of response to standard treatment E: History of fefractory urinary retention, persistent gross hematuria, recurrent UTI renal insufficiency, bilateral hydronephrosis or bladder stones due to BPH; spinal cord injury, prostatitis, bladder or prostate malignancy, bladder neck or urethral stricture, PVR >120; pelvic trauma or surgery; recent myocardial infarction, unstable angina; use of nitrates or nitric oxide donors, androgens or anti-androgens, anticoagulants, cytochrome p-450 3A4 inhibitors | Mean age: 65 Race: NR Baseline I-PSS: 13.4
Oelke, 2012^56^ Oelke, 2014^75^ Roehrborn, 2014^70^ Porst, 2013^71^ Porst, 2013^72^ Brock, 2013^76^ Brock, 2014^73^ Oelke, 2014^74^ Europe, Mexico, Australia N=682 | T: Tadalafil 5 mg qd C_1_: Placebo C_2_: Tamsulosin 0.4 mg qd | 12 wk | I: Age ≥45 yr; I-PSS ≥13; history of LUTS secondary to BPH for >6 mo; Qmax 4 - 15 mL/s; compliance during run-in ≥70% E: PSA >10 ng/mL (PSA 4-10 ng/mL, unless negative biopsy); recent finasteride or dutasteride, recent lower urinary tract instrumentation or stones, or urinary retention; history of urethral or bladder neck obstruction; neurogenic bladder; creatinine clearance <30 mL/min; severe hepatic impairment; certain cardiovascular conditions; current nitrate therapy; planned cataract surgery; symptomatic orthostatic hypotension, recurrent dizziness, vertigo, loss of consciousness, syncope | Mean age: 64 Race: 77% white Baseline I-PSS: 17.1
Ozturk, 2012^57^ Turkey N=100 | T: Sildenafil 50 mg; alfuzosin XL 10 mg C: Alfuzosin XL 10 mg | 13 wk | I: Age >45 yr; I-PSS ≥12, QoL ≥3; moderate-to-severe LUTS; naïve to treatment for LUTS or ED E: Contraindications to alfuzosin or sildenafil; bladder stones or previous prostatic operations; history of AUR; urethral strictures, PVR >200 mL; prostate cancer, chronic renal or liver insufficiency | Mean age: NR Race: NR Baseline I-PSS: 19.9
Takeda, 2012^58^ Japan N=562 | T_1_: Tadalafil 2.5 mg qd T_2_: Tadalafil 5 mg qd C: Placebo | 12 wk | I: Age ≥45 yr; I-PSS ≥13; Qmax 4 - 15 mL/s; prostate volume >20 mL; PVR <300 mL E: PSA >10 ng/mL (or PSA 4-10 ng/mL, unless clinically negative for prostate cancer); sugary on pelvic urinary tract; clinical prostate cancer or urinary tract conditions affecting LUTS; renal insufficiency; recent dutasteride | Mean age: 67 Race: NR Baseline I-PSS: 16.4
Kim, 2011^59^ Lee, 2014^69^ Korea N= 202 | T: Tadalafil 5 mg qd C_1_: Tamsulosin 0.2 mg qd C_2_: Placebo | 12 wk | I: Age ≥45 yr; I-PSS ≥13; Qmax 4-15 mL/s; LUTS >6 mo; PVR ≤300 mL E: PSA >10 ng/mL (PSA 4-10 ng/mL, unless negative biopsy); history of symptomatic orthostatic hypotension, dizziness, vertigo, LOC, or syncope; recent finasteride or dutasteride; other BPH, ED or OAB therapies | Mean age: 62 Race: NR Baseline I-PSS: 17.4
Porst, 2011^60^ Roehrborn, 2014^70^ Porst, 2013^71^ Porst, 2013^72^ Brock, 2013^76^ Brock, 2014^73^ Oelke, 2014^74^ Argentina, Germany, Italy, Mexico, US N=325 | T: Tadalafil 5 mg qd C: Placebo | 12 wk | I: Age ≥45 yr; I-PSS ≥13; history of LUTS secondary to BPH for >6 mo; Qmax 4 - 15 mL/s; PVR ≤300 mL; compliance during run-in ≥70% E: PSA >10 ng/mL (PSA 4-10 ng/mL, unless negative biopsy); recent finasteride or dutasteride, recent lower urinary tract instrumentation or stones, or urinary retention; history of urethral or bladder neck obstruction; neurogenic bladder; creatinine clearance <30 mL/min; severe hepatic impairment; certain cardiovascular conditions; current nitrate therapy | Mean age: 65 Race: 92% white Baseline I-PSS: 16.8
Dmochowski, 2010^61^ Dmochowski, 2013^77^ USA, Canada N=200 | T: Tadalafil 20 mg qd C: Placebo | 12 wk | I: Age ≥40 yr; I-PSS ≥13; LUTS >6 mo; PVR <350 mL E: PSA >10 ng/mL (PSA 4-10 ng/mL, unless negative biopsy); recent 5-ARIs; penile or pelvic surgery, radiotherapy, malignancy, trauma, instrumentation; urinary retention or stones; urethral obstruction; atonic, decompensated or hypocontractile bladder; detrusor-sphincter dyssynergia; intravesical obstruction; urinary tract inflammation or infection | Mean age: 59 Race: 77% white Baseline I-PSS: 21.7
Tuncel, 2010^62^ Turkey N= 60 | T_1_: Sildenafil 25 mg qd 4d/wk; tamsulosin 0.4 mg qd T_2_: Sildenafil 25 mg qd 4 d/wk C: Tamsulosin 0.4 mg qd | 8 wk | I: I-PSS ≥12; SHIM ≤20; BPH/LUTS and ED E: Drugs or surgery for BPH or ED, recent prostate biopsy or 5-ARIs; any urologic cancer, prostate or bladder/pelvic radiation or surgery, urinary stone, active UTI, recent AUR; recent urethral catheter; acute or chronic hepatic failure, renal dysfunction; poorly controlled diabetes, nitrates use | Mean age: NR Race: NR Baseline I-PSS: 15.3
Liguori, 2009^63^ Italy N=66 | T_1_: Tadalafil 20 mg every other day; alfuzosin extended release 10 mg qd T_2_: Tadalafil 20 mg qd C: Alfuzosin extended release 10 mg qd | 12 wk | I: Age 50–75 yr; I-PSS >8; LUTS/BPH ≥6 mo; untreated ED of any grade E: Contraindications of either drug; medications to control bladder symptoms; bladder tumors, urethral strictures, neurogenic bladder dysfunction, prostatitis, prostate cancer, PSA >20 ng/mL; prostate surgery or radiotherapy, AUR or indwelling catheter; acute UTI; ever used 5-ARIs, ABs, or PDE-5s | Mean age: 62 Race: NR Baseline I-PSS: 14.9
Roehrborn, 2008^64^ Broderick, 2010^78^ Roehrborn, 2014^70^ Porst, 2013^71^ Porst, 2013^72^ Brock, 2013^76^ Brock, 2014^73^ Oelke, 2014^74^ 10 countries N=1689 | T_1_: Tadalafil 2.5 mg qd T_2_: Tadalafil 5 mg qd T_3_: Tadalafil 20 mg qd C: Placebo | 12 wk | I: Age ≥45 yr; I-PSS ≥13; history of LUTS secondary to BPH for ≥6 mo; Qmax 4 - 15 mL/s; PVR ≤300 mL E: PSA >10 ng/mL (PSA 4 - 10 ng/mL, unless negative biopsy); recent finasteride or dutasteride, antiandrogens, or potent cytochrome P450 3A4 inhibitor; penile or pelvic problems other than LUTS/BPH; clinically significant renal, hepatic, cardiovascular, or diabetic disease; spinal cord injury, cancer chemotherapy | Mean age: 62 Race: 85% white Baseline I-PSS: 17.3
Stief, 2008^65^ Germany N=222 | T: Vardenafil 10 mg bid C: Placebo | 8 wk | I: Age 45–64 yr; I-PSS ≥12; LUTS ≥6 mo E: Contraindications to vardenafil; spinal cord injury; prostatitis; history of prostate or bladder cancer; bladder or urethra stricture; PVR ≥100 mL; pelvic trauma or surgery; any malignancies; life expectancy of <3 yr; use of nitrates or nitric oxide donors, androgens or anti-androgens, anticoagulants, cytochrome P-450 3A4 inhibitors, alpha1-blockers, or any treatment for ED | Mean age: 56 Race: 99% white Baseline I-PSS: 16.8
McVary, 2007a66 McVary, 2008^79^ USA N=370 | T: Sildenafil 50-100 mg C: Placebo | 12 wk | I: Age ≥45 yr; I-PSS ≥12; IIEF-EF ≤25 E: PSA >10 ng/mL (or PSA 4-10 ng/mL, unless clinically negative for prostate cancer), prostate cancer, prostate/bladder/pelvic radiation or surgery; causes of symptoms other than BPH (urinary tract disease, recent cystoscopy, urinary calculi, AUR, recurrent UTIs, recent catheterization for outflow obstruction); hypotension, hypertension, orthostatic hypotension, or significant cardiovascular disease; hepatic or renal disease, poorly-controlled diabetes, retinitis pigmentosa; use of nitrates, antimuscarinics, recent 5-ARIs, recent ABs | Mean age: 60 Race: 82% white Baseline I-PSS: NR
McVary, 2007b67 USA N= 543 | T_1_: Tadalafil 5 mg T_2_: Tadalafil 20 mg C: Placebo | 6 wk | I: Age ≥45 yr; LUTS/BPH ≥6 mo; agreed not to use other BPH meds E: PSA >10 ng/mL (PSA 4 - 10 ng/mL, unless negative biopsy); recent finasteride or dutasteride; radical prostatectomy or other pelvic surgery; neurological condition affecting bladder function; recent lower urinary tract instrumentation, retention or stones; past urethral obstruction; detrusor-sphincter dyssynergia; UTI or urinary tract inflammation; intravesical obstruction due to the prostate median lobe; prostate cancer; PVR ≥ 200 mL at visit 2; certain cardiovascular diseases, clinically significant renal or hepatic insufficiency, recent stroke or spinal cord injury; current nitrates, cancer chemotherapy, antiandrogens or a potent cytochrome P450 3A4 inhibitor; or HbA1c >9% | Mean age: 62 Race: 81% white Baseline I-PSS: 17.9
Kaplan, 2007^68^ USA N= 124 | T_1_: Sildenafil 25 mg qd; alfuzosin 10 mg qd T_2_: Sildenafil 25 mg qd C: Alfuzosin 10 mg qd | 12 wk | I: Age 50-76 yr; moderate to severe untreated LUTS and self-reported ED E: NR | Mean age: 64 Race: NR Baseline I-PSS: 17.3

AB=alpha blocker; ARI=alpha-reductase inhibitor; AUR=acute urinary retention; bid=twice daily; BOO=bladder outlet obstruction; BOOI=bladder outlet obstruction index; BPH=benign prostatic hyperplasia; d=days; C=comparator group; C_1_=comparator group 1; C_2_=comparator group 2; dL=deciliters; E=exclusion criteria; ED=erectile dysfunction; HbA1c= glycated haemoglobin; HRQL=health-related quality of life; I=inclusion criteria; IIEF-EF=international index of erectile function questionnaire-erectile function subscale; I-PSS=International Prostate Symptom Score; LOC=loss of consciousness; LUTS=lower urinary tract symptoms; mg=milligrams; min=minute; mL=milliliters; ng=nanograms; NR=not reported; OAB=overactive bladder; PDE-5=phosphodiesterase-5 inhibitors; prn=as needed; PSA=prostate-specific antigen; PVR= postvoid residual urine; qd=daily; Qmax=maximum urinary flow rate; QoL=quality of life; s=seconds; SHIM=sexual health inventory for men; T=treatment group; T_1_=treatment group 1; T_2_=treatment group 2; TURP=transurethral resection of the prostate; UTI=urinary tract infection; wk=weeks; yr=years

Table G4 Strength of evidence assessments: tadalafil

Comparison | Outcome | # Trials (n) | Summary Statistics, [95% CI] | Study Limitations | Directness | Precision | Consistency | Reporting Bias | Optional Components | Evidence Rating
Tadalafil 5 mg vs. placebo | I-PSS/AUA-SI, mean change from baseline | 9 (3024) | WMD = -1.79 [-2.29 to -1.29] | Low | Direct | Imprecise | Consistent | Undetected^a^ | NA | Moderate
Tadalafil 5 mg vs. placebo | Responders – change from baseline of ≥3 points in I-PSS scores | 1 (281) | RR = 1.36 [1.03 to 1.78] | Low | Direct | Precise | Unknown | Undetected^a^ | NA | Low
Tadalafil 5 mg vs. placebo | BII, mean change from baseline | 7 (2161) | WMD = -0.52 [-0.78 to -0.26] | Low | Direct | Imprecise | Consistent | Undetected^a^ | NA | Moderate
Tadalafil 5 mg vs. placebo | I-PSS QoL, mean change from baseline | 8 (2605) | WMD = -0.27 27 [-0.31 to -0.23] | Low | Direct | Precise | Consistent | Undetected^a^ | NA | High
Tadalafil 5 mg vs. placebo | Overall withdrawals | 9 (3082) | RR = 1.00 [0.77 to 1.3] | Low | Direct | Precise | Consistent | Undetected^a^ | NA | High
Tadalafil 5 mg vs. placebo | Withdrawals due to adverse effects | 9 (3082) | RR = 1.80 [1.03 to 3.44] | Low | Direct | Precise | Consistent | Undetected^a^ | NA | High
Tadalafil 5 mg vs. placebo | Participants with ≥1 adverse effect | 9 (3082) | RR = 1.25 [1.09 to 1.44] | Low | Direct | Precise | Consistent | Undetected^a^ | NA | High
Combined tadalafil 5-20 mg with any alpha-blocker vs. any alpha-blocker | I-PSS/AUA-SI, mean change from baseline | 4 (214) | WMD = -2.01 [-4.03 to -0.00] | High | Direct | Imprecise | Consistent | Undetected^a^ | NA | Insufficient
Combined tadalafil 5-20 mg with any alpha-blocker vs. any alpha-blocker | I-PSS QoL, mean change from baseline | 3 (174) | WMD = -0.44 [-0.73 to -0.15] | High | Direct | Precise | Consistent | Undetected^a^ | Confounding | Low (Clinically Equivalent)
Combined tadalafil 5-20 mg with any alpha-blocker vs. any alpha-blocker | Overall withdrawals | 4 (224) | RR = 0.80 [0.12 to 5.29] | High | Direct | Imprecise | Consistent | Undetected^a^ | NA | Insufficient
Combined tadalafil 5-20 mg with any alpha-blocker vs. any alpha-blocker | Withdrawals due to adverse effects | 4 (224) | RR = 1.13 [0.12 to 11.03] | High | Direct | Imprecise | Consistent | Undetected^a^ | NA | Insufficient
Combined tadalafil 5-20 mg with any alpha-blocker vs. any alpha-blocker | Participants with ≥1 adverse effect | NR | | | | | | | NA | Insufficient
Tadalafil 5 mg vs. tamsulosin 0.2-0.4 mg | I-PSS/AUA-SI, mean change from baseline | 3 (742) | WMD = 0.07 07 [-2.12 to 2.23] | Moderate | Direct | Precise | Consistent | Undetected^a^ | NA | Moderate
Tadalafil 5 mg vs. tamsulosin 0.2-0.4 mg | BII, mean change from baseline | 3 (731) | WMD = -0.02 [-1.52 to 1.48] | Moderate | Direct | Imprecise | Inconsistent | Undetected^a^ | NA | Low
Tadalafil 5 mg vs. tamsulosin 0.2-0.4 mg | I-PSS QoL, mean change from baseline | 3 (742) | WMD = -0.01 [-0.75 to 0.73] | Moderate | Direct | Precise | Inconsistent | Undetected^a^ | NA | Low
Tadalafil 5 mg vs. tamsulosin 0.2-0.4 mg | Overall withdrawals | 3 (742) | RR = 1.35 (0.30 to 6.05) | Moderate | Direct | Imprecise | Consistent | Undetected^a^ | NA | Low
Tadalafil 5 mg vs. tamsulosin 0.2-0.4 mg | Withdrawals due to adverse effects | 3 (742) | RR = 2.68 (1.09 to 6.60) | Moderate | Direct | Precise | Consistent | Undetected^a^ | NA | Moderate
Tadalafil 5 mg vs. tamsulosin 0.2-0.4 mg | Participants with ≥1 adverse effect | 3 (742) | RR = 0.99 (0.38 to 2.54) | Moderate | Direct | Imprecise | Consistent | Undetected^a^ | NA | Low
Tadalafil 10-20 mg vs. alfuzosin 10 mg | I-PSS/AUA-SI, mean change from baseline | 2 (87) | Kumar, 2014 MD = 3.20 [1.71, 4.69] Liguori, 2009 MD = 3.90 [0.72, 7.08] | High | Direct | Imprecise | Consistent | Undetected^a^ | NA | Low
Tadalafil 10-20 mg vs. alfuzosin 10 mg | I-PSS QoL, mean change from baseline | 2 (87) | Kumar, 2014 MD = 0.80 [0.35, 1.25] Liguori, 2009 MD = 0.30 [-0.35, 0.95] | High | Direct | Imprecise | Consistent | Undetected^a^ | NA | Low
Tadalafil 10-20 mg vs. alfuzosin 10 mg | Overall withdrawals | 2 (93) | Kumar, 2014 RR not estimable Liquori, 2009 RR = 0.52 [0.11, 2.56] | High | Direct | Imprecise | Consistent | Undetected^a^ | NA | Insufficient
Tadalafil 10-20 mg vs. alfuzosin 10 mg | Withdrawals due to adverse effects | 2 (93) | Kumar, 2014 RR not estimable Liquori, 2009 RR = 0.35 [0.04, 3.10] | High | Direct | Imprecise | Consistent | Undetected^a^ | NA | Insufficient
Tadalafil 10-20 mg vs. alfuzosin 10 mg | Participants with ≥1 adverse effect | NR | | | | | | | NA | Insufficient
Tadalafil 5 mg & finasteride 5 mg vs. Placebo & finasteride 5 mg | I-PSS/AUA-SI, mean change from baseline | 1 (696) | MD = -1.0 (-1.9 to -0.2) | Low | Direct | Precise | Unknown | Undetected | NA | Low
Tadalafil 5 mg & finasteride 5 mg vs. Placebo & finasteride 5 mg | I-PSS QoL, mean change from baseline | 1 (696) | MD = -0.2 (-0.4 to 0.0) | Low | Direct | Precise | Unknown | Undetected | NA | Low
Tadalafil 5 mg & finasteride 5 mg vs. Placebo & finasteride 5 mg | Overall withdrawals | 1 (696) | RR = 0.63 [0.44, 0.91] | Low | Direct | Precise | Unknown | Undetected | NA | Low
Tadalafil 5 mg & finasteride 5 mg vs. Placebo & finasteride 5 mg | Withdrawals due to adverse effects | 1 (696) | RR = 1.50 [0.44, 5.06] | Low | Direct | Imprecise | Unknown | Undetected | NA | Insufficient
Tadalafil 5 mg & finasteride 5 mg vs. Placebo & finasteride 5 mg | Participants with ≥1 adverse effect | 1 (696) | RR = 1.15 [0.91, 1.45] | Low | Direct | Imprecise | Unknown | Undetected | NA | Insufficient
Tadalafil 10 mg & AB OR finasteride vs. Placebo & AB OR finasteride | I-PSS/AUA-SI, mean change from baseline | 1 (132) | MD = -3.1 (-4.5 to -1.7) | Moderate | Direct | Imprecise | Unknown | Undetected | NA | Insufficient
Tadalafil 10 mg & AB OR finasteride vs. Placebo & AB OR finasteride | I-PSS QoL, mean change from baseline | 1 (132) | MD = -0.6 (-0.9 to -0.3) | Moderate | Direct | Imprecise | Unknown | Undetected | NA | Insufficient
Tadalafil 10 mg & AB OR finasteride vs. Placebo & AB OR finasteride | Withdrawals due to adverse effects | 1 (132) | RR = 1.50 [0.44, 5.07] | Moderate | Direct | Imprecise | Unknown | Undetected | NA | Insufficient

a We searched and screened results from clinicaltrials.gov. We identified 14 eligible trials; 12 had been published and included in our review. The two that are not yet published have only recently completed. We detected no publication bias.

AUR=acute urinary retention; BII = BPH Impact Index; I-PSS/AUA-SI= International Prostate Symptom Scale/American Urological Association Symptom Index; MD=mean difference; QoL=quality of life; RR=risk ratio; SMD=standardized mean difference; WMD=weighted mean difference

* As a rule, tests for funnel plot asymmetry should be used only when there are at least 10 studies included in the meta-analysis, because when there are fewer studies the power of the tests is too low to distinguish chance from real asymmetry ( (2011). Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. )

## Efficacy of Tadalafil

Figure G1 I-PSS scores, mean change from baseline: tadalafil vs. placebo

Figure G1 is a Forrest plot comparing the mean change in I-PSS scores between tadalafil and placebo. The pooled WMD shows tadalafil improves mean I-PSS scores more than placebo.

## Adjunctive Efficacy of Tadalafil

Figure G2 I-PSS scores, mean change from baseline: combined tadalafil + alpha-blocker vs. alpha-blocker

Figure G2 is a Forrest plot comparing the mean change in I-PSS scores between tadalafil plus alpha-blocker and alpha-blocker alone. The pooled WMD shows tadalafil plus alpha-blocker improves mean I-PSS scores more than alpha-blocker alone.

## Comparative Effectiveness of Tadalafil Versus Tamsulosin

Figure G3 I-PSS scores, mean change from baseline: tadalafil vs. tamsulosin

Figure G3 is a Forrest plot comparing the mean change in I-PSS scores between tadalafil and tamsulosin. The pooled WMD shows no significant difference.

Table G5 Strength of evidence assessments: sildenafil

Comparison | Outcome | # Trials (n) | Summary Statistics, [95% CI] | Risk of Bias | Directness | Precision | Consistency | Reporting Bias | Optional Components | Evidence Rating
Sildenafil 50-100 mg vs. placebo | I-PSS/AUA-SI, mean change from baseline | 1 (341) | MD -4.40 (-6.87 to -1.93) | Low | Direct | Precise | Unknown | Undetected^a^ | Strong strength of association | Low
Sildenafil 50-100 mg vs. placebo | BII, mean change from baseline | 1 (351) | MD -1.1 [CI NR, P <.0001)] | Low | Direct | Precision unclear | Unknown | Undetected^a^ | NA | Insufficient
Sildenafil 50-100 mg vs. placebo | I-PSS QoL, mean change from baseline | 1 (351) | MD -0.7 [CI NR, P <.0001)] | Low | Direct | Precision unclear | Unknown | Undetected^a^ | NA | Insufficient
Sildenafil 50-100 mg vs. placebo | Overall withdrawals | 1 (369) | RR 0.80 (0.46 to 1.38) | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Sildenafil 50-100 mg vs. placebo | Withdrawals due to adverse effects | 1 (369) | RR 1.59 (0.59 to 4.28) | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Sildenafil 50-100 mg vs. placebo | Participants with ≥1 adverse effect | 1 (369) | RR 1.22 (0.99 to 1.51) | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Combined sildenafil 25-50 mg with any alpha-blocker vs. any alpha-blocker | I-PSS/AUA-SI, mean change from baseline | 3 (233) | WMD -1.73 [-4.76 to 1.30]3 trials MD -1 [CI NR] 1 trial | High | Direct | Imprecise | Consistent | Undetected^a^ | NA | Insufficient
Combined sildenafil 25-50 mg with any alpha-blocker vs. any alpha-blocker | I-PSS QoL, mean change from baseline | 2 (132) | Ozturk 2012 MD = -0.10 [-0.47, 0.27] Tuncel 2010 MD = -1.20 [-1.51, -0.89] | High | Direct | Imprecise | Inconsistent | Undetected^a^ | NA | Insufficient
Combined sildenafil 25-50 mg with any alpha-blocker vs. any alpha-blocker | Overall withdrawals | 2 (141) | Ozturk 2012 RR = 1.67 [0.42, 6.60] Kaplan 2007 RR = 1.43 [0.27, 7.67] | High | Direct | Imprecise | Consistent | Undetected^a^ | NA | Insufficient
Combined sildenafil 25-50 mg with any alpha-blocker vs. any alpha-blocker | Withdrawals due to adverse effects | 2 (141) | Ozturk 2012 RR not estimable Kaplan 2007 RR = 1.43 [0.27, 7.67] | High | Direct | Imprecise | Consistent | Undetected^a^ | NA | Insufficient
Sildenafil 25-50 mg vs. any alpha-blocker | I-PSS/AUA-SI, mean change from baseline | 2 (181) | Abolyosr 2013 MD = 1.10 [-0.70, 2.90] Kaplan 2004 MD = 0.70 [-1.72, 3.12] | High | Direct | Imprecise | Consistent | Undetected^a^ | NA | Insufficient
Sildenafil 25-50 mg vs. any alpha-blocker | I-PSS QoL, mean change from baseline | 1 (40) | MD = 0.80 (-1.18 to -0.42) | High | Direct | Precise | Unknown | Undetected^a^ | NA | Insufficient
Sildenafil 25-50 mg vs. any alpha-blocker | Overall withdrawals | 1 (45) | RR 0.95 (0.15 to 6.13) | High | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Sildenafil 25-50 mg vs. any alpha-blocker | Withdrawals due to adverse effects | 1 (45) | RR 0.95 (0.15 to 6.13) | High | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Sildenafil 25-50 mg vs. any alpha-blocker | Participants with ≥1 adverse effect | NR | | | | | | | NA | Insufficient

a We searched and screened results from clinicaltrials.gov. We identified one eligible trial. This trial has been included, so we detected no publication bias.

AUR=acute urinary retention; BII = BPH Impact Index; I-PSS/AUA-SI= International Prostate Symptom Scale/American Urological Association Symptom Index; MD=mean difference; QoL=quality of life; RR=risk ratio; SMD=standardized mean difference; WMD=weighted mean difference

* As a rule, tests for funnel plot asymmetry should be used only when there are at least 10 studies included in the meta-analysis, because when there are fewer studies the power of the tests is too low to distinguish chance from real asymmetry ( (2011). Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. )

## Adjunctive Efficacy of Sildenafil

Figure G4 I-PSS scores, mean change from baseline: combined sildenafil + alpha-blocker vs. alpha-blocker

Figure G4 is a Forrest plot comparing the mean change in I-PSS scores between sildenafil plus alpha-blocker and alpha-blocker alone. The pooled WMD shows no significant difference.

Table G6 Strength of evidence assessments: vardenafil

Comparison | Outcome | # Trials (n) | Summary Statistics, [95% CI] | Risk of Bias | Directness | Precision | Consistency | Reporting Bias | Optional Components | Evidence Rating
Vardenafil 20 mg vs. placebo | I-PSS/AUA-SI, mean change from baseline | 1 (214) | MD -2.3 (-3.64 to -0.90) | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Low
Vardenafil 20 mg vs. placebo | Overall withdrawals | 1 (222) | RR = 0.96 (0.47 to 1.95) | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Vardenafil 20 mg vs. placebo | Withdrawals due to adverse effects | 1 (222) | RR = 4.67 (1.03 to 21.11) | Low | Direct | Precise | Unknown | Undetected^a^ | NA | Low
Vardenafil 20 mg vs. placebo | Participants with ≥1 adverse effect | 1 (222) | RR = 1.86 (1.11 to 3.11) | Low | Direct | Precise | Unknown | Undetected^a^ | NA | Low
Combined vardenafil 10 mg with any alpha-blocker vs. any alpha-blocker | I-PSS/AUA-SI, mean change from baseline | 1 (60) | MD = -2.10 (-4.76 to 0.56) | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Combined vardenafil 10 mg with any alpha-blocker vs. any alpha-blocker | Overall withdrawals | 1 (60) | RR = 0.32 (0.01 to 7.61) | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Combined vardenafil 10 mg with any alpha-blocker vs. any alpha-blocker | Withdrawals due to adverse effects | 1 (60) | RR = 0.32 (0.01 to 7.61) | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Combined vardenafil 10 mg with any alpha-blocker vs. any alpha-blocker | Participants with ≥1 adverse effect | 1 (60) | RR = 1.50 (0.27 to 8.34) | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient

a We searched and screened results from clinicaltrials.gov. We identified one eligible trial that has been included. We detected no publication bias.

AUR=acute urinary retention; BII = BPH Impact Index; I-PSS/AUA-SI= International Prostate Symptom Scale/American Urological Association Symptom Index; MD=mean difference; QoL=quality of life; RR=risk ratio; SMD=standardized mean difference; WMD=weighted mean difference

* As a rule, tests for funnel plot asymmetry should be used only when there are at least 10 studies included in the meta-analysis, because when there are fewer studies the power of the tests is too low to distinguish chance from real asymmetry ( (2011). Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. )