# Appendix F Supporting Tables: Mirabegron

Table F1 Risk of bias assessments: mirabegron trials

Study | Overall Risk of Bias Assessment | Rationale
Ichihara, 2015^44^ | High | Open label, outcome blinding not described, moderate attrition
Nitti, 2013^45^ | Low

Table F2 Characteristics of BPH treatment, comparison, and population: mirabegron trials

Study Country Number Randomized | Intervention Comparisons | Duration | Inclusion/Exclusion Criteria | Population Characteristics
Ichihara, 2015^44^ Japan N=94 | T: Mirabegron 50 mg qd; tamsulosin 0.2 mg qd C: Tamsulosin 0.2mg qd | 8 wk | I: Persistent OAB symptoms after tamsulosin 0.2 mg qd ≥8 wk; OABSS ≥3; urinary urgency ≥1 per wk E: PVR >100 mL; Qmax <5 mL/s; history of urinary retention neurogenic bladder, clean intermittent catheterization, severe bladder diverticulum, or urethral stricture; planning to have a child; suspected malignant disease; previous intrapelvic irradiation; suspected UTI; renal or hepatic impairment; taking medicine contraindicated to combination with mirabegron | Mean age: 75 Race: NR Baseline I-PSS: 13.5
Nitti, 2013^45^ USA and Canada N=200 | T_1_: Mirabegron 100 mg qd T_2_: Mirabegron 50 mg qd C: Placebo | 12 wk | I: Age >45 yr; voiding/LUTS ≥3 mo; I-PSS ≥8; BOOI ≥20; Qmax ≤12 mL/s; voided volume ≥120 mL during free flow E: History of urinary retention in prior 12 mo; history of carcinoma, prostate cancer, pelvic radiation therapy in prior 5 yr; neurogenic bladder; UTI or recurrent UTIs; previous or planned prostate surgery or other invasive procedures (excluding prostate biopsy) within 12 mo; chronic inflammation such as chronic prostatitis; stone in bladder or ureter; other causes of BOO such as bladder neck stenosis or urethral stricture | Mean age: 63 Race: 54% white Baseline I-PSS: 19.9

BOO=bladder outlet obstruction; BOOI=bladder outlet obstruction index; BPH=benign prostatic hyperplasia; C=comparator group; E=exclusion criteria; I=inclusion criteria; I-PSS=International Prostate Symptom Score; LUTS=lower urinary tract symptoms; mg=milligrams; mL=milliliters; NR=not reported; OAB=overactive bladder; OABSS=overactive bladder symptoms score; PVR= postvoid residual urine; qd=daily; Qmax=maximum urinary flow rate; s=second; T=treatment group; T_1_=treatment group 1; T_2_=treatment group 2; UTI=urinary tract infection; wk=weeks; yr=years

Table F3 Strength of evidence assessments: mirabegron

Comparison | Outcome | # Trials (n) | Summary Statistics, [95% CI] | Study Limitations | Directness | Precision | Consistency | Reporting Bias | Optional Components | Evidence Rating
Mirabegron 50 mg vs. placebo | I-PSS score, mean change from baseline | 1 (135) | MD = -5.7 [NR] | Low | Direct | Unknown | Unknown | Undetected^a^ | NA | Insufficient
Mirabegron 50 mg vs. placebo | AUR | 1 (135) | RR = 0 [0.01, 7.47] | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Mirabegron 50 mg vs. placebo | Overall withdrawals | 1 (135) | RR = 1.39 [0.24, 8.07] | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Mirabegron 50 mg vs. placebo | Withdrawals due to adverse effects | 1 (135) | RR = 0.93 [0.13, 6.40] | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Mirabegron 100 mg vs. placebo | I-PSS score, mean change from baseline | 1 (130) | MD = -4.3 [NR] | Low | Direct | Unknown | Unknown | Undetected^a^ | NA | Insufficient
Mirabegron 100 mg vs. placebo | AUR | 1 (130) | RR = 1 [0.06, 15.65] | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Mirabegron 100 mg vs. placebo | Overall withdrawals | 1 (130) | RR = 3.5 [0.76, 16.22] | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Mirabegron 100 mg vs. placebo | Withdrawals due to adverse effects | 1 (130) | RR = 1 [0.15, 6.89] | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Mirabegron 50 mg qd plus alpha-blocker vs. alpha-blocker | I-PSS/AUA-SI, mean change from baseline | 1 (94) | MD = 2.08 [NR] | High | Direct | Unknown | Unknown | Undetected^a^ | NA | Insufficient
Mirabegron 50 mg qd plus alpha-blocker vs. alpha-blocker | I-PSS QoL, mean change from baseline | 1 (94) | MD = -0.71 [NR] | High | Direct | Unknown | Unknown | Undetected^a^ | NA | Insufficient
Mirabegron 50 mg qd plus alpha-blocker vs. alpha-blocker | AUR | 1 (94) | RR = 2.66 [0.11, 63.40] | High | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Mirabegron 50 mg qd plus alpha-blocker vs. alpha-blocker | Overall withdrawals | 1 (94) | RR = 9.75 [0.56, 170.43] | High | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Mirabegron 50 mg qd plus alpha-blocker vs. alpha-blocker | Withdrawals due to adverse effects | 1 (94) | RR = 9.75 [0.56, 170.73] | High | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient

a We searched and screened results from clinicaltrials.gov. We identified one eligible trial that has not yet been completed. We detected no publication bias.

AUR=acute urinary retention; I-PSS/AUA-SI= International Prostate Symptom Scale/American Urological Association Symptom Index; MD=mean difference; QoL=quality of life; RR=risk ratio; SMD=standardized mean difference; WMD=weighted mean difference

* As a rule, tests for funnel plot asymmetry should be used only when there are at least 10 studies included in the meta-analysis, because when there are fewer studies the power of the tests is too low to distinguish chance from real asymmetry ( (2011). Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. )