# Appendix E Supporting Tables and Figures: Anticholinergics

Table E1 Risk of bias assessments: anticholinergic trials

Study | Overall Risk of Bias Assessment | Rationale
Liao, 2015^19^ | High | Not blinded
Singh, 2015^20^ | Low
Ko, 2014^21^ | High | Randomization and allocation methods unclear, open label, outcome assessor blinding not described, moderate attrition, attrition higher in treatment group
Lee, 2014^22^ | Low
Memon, 2014^23^ | High | Participants purposively selected, blinding methods not described, outcome assessor blinding not reported, attrition not reported
Kaplan, 2013^24^ | Low
Van Kerrebroeck, 2013a25 | Moderate | Randomization and allocation concealment unclear.
Van Kerrebroeck, 2013b26 | Low
Ceylan, 2012^27^ | Moderate | Randomization and allocation methods unclear, outcome assessor blinding not reported, attrition not reported
Konstantinidis, 2012^28^ | High | Randomization and allocation not mentioned, blinding not mentioned, attrition unclear, small sample size
Malkoc, 2012^29^ | Moderate | Randomization and allocation methods unclear, outcome assessor blinding not reported, moderate attrition, patients with severe side effects excluded, small sample size
Chung, 2011^30^ | High | Allocation methods unclear, blinding methods not reported
Kaplan, 2011^31^ | Moderate | Randomization and allocation concealment unclear.
Lee, 2011^32^ | Low
Seo, 2011^33^ | Moderate | Randomization and allocation methods unclear, blinding methods unclear, adverse events not reported
Yamaguchi, 2011^34^ | Low
Chapple, 2009^35^ | Low
Kaplan, 2009^36^ | Moderate | Randomization and allocation methods unclear, outcome assessor blinding not reported
MacDiamid, 2008^37^ | Low
Kaplan, 2006^38^ | Low

Table E2 Summary of anticholinergic trials: tolterodine

Characteristic | Mean (range) Unless Otherwise Noted | Number of Studies Reporting
Total randomized | 1777 (70 to 879) | 4
Percentage randomized based on # screened | 66 (57 to 77) | 3
Received placebo, # randomized (% all randomized) | 222 (12) | 1
Received alpha-blocker, # randomized (% all randomized) | 664 (37) (35 to 323) | 4
Age of subjects, years | 63 (61 to 65) | 4
Percentage white race | 67 (0^a^ to 83) | 4
Baseline I-PSS | 20 (19 to 24) | 4
Percentage with over active bladder symptoms | 100 | 4
Percentage with erectile dysfunction | 27 | 1

a All subjects from trials conducted in Asia (Korea, India: k=2; n=246) presumed to be non-European white

I-PSS=International Prostate Symptom Score

Table E3 Summary of anticholinergic trials: solifenacin

Characteristic | Mean (range) Unless Otherwise Noted | Number of Studies Reporting
Total randomized | 3710 (60 to 1334) | 7
Percentage randomized based on # screened | 80 (56 to 93) | 5
Received placebo, # randomized (% all randomized) | 433 (12) (92 to 341) | 2
Received tamsulosin^a^, #randomized (% all randomized) | 1106 (30) (30 to 327) | 7
Age of subjects, years | 66 (58 to 70) | 7
Percentage white race | 70 (0^a^ to 99.6) | 7
Baseline I-PSS | 17 (14 to 19) | 7
Percentage with over active bladder symptoms | 100^b^ | 3
Percentage with erectile dysfunction | 56 (28 to 100) | 3

a All subjects from trials conducted in Asia (Korea, Japan: k=4; n=1041) presumed to be non-European white

b The inclusion criteria or baseline parameters for 3 additional trials noted participants were to have ≥8 micturitions/day and ≥1 or 2 urgency episodes/day

I-PSS=International Prostate Symptom Score

Table E4 Summary of anticholinergic trials: fesoterodine

Characteristic | Mean (range) Unless Otherwise Noted | Number of Studies Reporting
Total randomized | 990 (47 to 943) | 2
Percentage randomized based on # screened | 70 (27 to 71) | 2
Received placebo, # randomized (% all randomized) | 0 | 2
Received alpha-blocker, # randomized (% all randomized) | 496 (50) (23 to 473) | 2
Age of subjects, years | 66 (64 to 66) | 2
Percentage white race | 81 | 1
Baseline I-PSS | 19 (16 to 19) | 2
Percentage with over active bladder symptoms | 100 | 2
Percentage with erectile dysfunction | NR

I-PSS=International Prostate Symptom Score

Table E5 Characteristics of BPH treatment, comparison, and population: anticholinergic trials

Study Country Number Randomized | Intervention Comparisons | Duration | Inclusion/Exclusion Criteria | Population Characteristics
Liao, 2015^19^ Taiwan N=202 | T: Tolterodine 4 mg C: Doxazosin 4 mg | 12 wk | I: Age ≥40 yr; I-PSS ≥8; predominant storage LUTS (I-PSS-S ≥I-PSS-V); PVR ≤250 mL E: PSA level >10 ng/mL; history of urinary retention, urodynamically proven detrusor underactivity, active UTI, urinary stone, documented genitourinary cancer, or previous transurethral surgery; antimuscarinics or 5a-reductase inhibitors within 6 mo | Mean age: 69 Race: NR Baseline I-PSS: 11.5
Singh, 2015^39^ India N=60 | T: Darifenacin 7.5 mg qd; tamsulosin 0.4 mg C: Tamsulosin 0.4 mg qd; placebo | 8 wk | I: LUTS/BPH with at least one OOB symptom: urinary frequency (>8 micturitions/d), nocturnal frequency (> 2/d) urgency > 1/d, with or without urge incontinence E: Qmax < 5 mL/s; voided volume < 50 mL/s; PVR >150 mL/s (by ultrasound); progressively rising PVR; renal failure; untreated UTI; vesical stones; contraindications to alpha-1-adrenergic receptor antagonist or antimuscarinic agent | Mean age: 61 Race: NR Baseline I-PSS: 18.9
Ko, 2014^21^ Korea N=187 | T: Solifenacin 5 mg; tamsulosin 0.2 mg C: Tamsulosin 0.2 mg | 12 wk | I: Age >40 yr; LUTS (I-PSS >12); urinary frequency (≥8/d), urgency (≥1/d), and symptoms on 3 d voiding diary E: Urologic malignancy; UTI; medical renal disease; medical liver disease; clinically significant BOO (residual urine >100 mL) | Mean age: 61 Race: NR Baseline I-PSS: 19.3
Lee, 2014^22^ Korea N=156 | T: Solifenacin 5 mg; tamsulosin 0.2 mg C: Tamsulosin 0.2 mg qd | 12 wk | I: Age ≥50 yr; total I-PSS ≥14; IPPS-V ≥8; I-PSS-S ≥6; QoL-I ≥3; micturition frequency ≥8 micturitions per 24 hr; urgency (≥1 micturition with urgency rating 3 per 24 hr); prostate volume ≥20; Qmax ≤15 mL/s; voided volume ≤125 mL E: Neurogenic bladder dysfunction; confirmed prostate cancer; acute or chronic urinary retention status; acute or chronic prostatitis within the previous 3 mo; PSA levels >10 ng/mL; history of recurrent UTI or bladder stones; previous BPH treatment; previous surgical intervention related to BOO | Mean age: 61 Race: NR Baseline I-PSS: 17.9
Memon, 2014^23^ Pakistan N=70 | T: Tolterodine 2 mg bd; alfuzosin 10 mg hs C: Alfuzosin 10 mg hs | 12 wk | I: Age >40 yr; BPH diagnosed on ultrasound scan having OAB symptoms; I-PSS = 15-30 for >3 mo E: PVR >100 mL; Qmax <5 mL; conditions affecting bladder function like multiple sclerosis, spinal cord injury, or Parkinson's disease; history of Parkinson's disease, prostatic cancer, indwelling catheter, or use of anti-muscarinic or Abs | Mean age: NR Race: NR Baseline I-PSS: 23.7
Kaplan, 2013^24^ USA N=222 | T: Solifenacin 6 mg; tamsulosin 0.4 mg T_2_: Solifenacin 9 mg; tamsulosin 0.4 mg C: Placebo | 12 wk | I: Age ≥45 yr; completed 3 d micturition diary; voiding and storage LUTS ≥3 mo; I-PSS ≥8; BOOI ≥20; Qmax ≤12 mL/s, maximum voided volume ≥120 mL E: Indwelling urinary catheter; history of urinary retention >12 mo, carcinoma or pelvic radiation therapy, neurogenic bladder, chronic inflammation, stone in bladder/ureter, outflow tract obstruction, uncontrolled narrow-angle glaucoma, myasthenia gravis, urinary or gastric retention, bladder neck surgery, or diabetic neuropathy; contraindicated for use of anticholinergics; current UTI; recurrent UTI >3 episodes within 12 mo; previous/planned prostate surgery; hypersensitivity to solifenacin succinate or other anticholinergics, or tamsulosin hydrochloride | Mean age: 64 Race: 98% white Baseline I-PSS: 17.8
Van Kerrebroeck, 2013a25 Netherlands N=937 | T_1_: Solifenacin 3 mg; tamsulosin 0.4 mg T_2_: Solifenacin 6 mg; tamsulosin 0.4 mg T_3_: Solifenacin 9 mg; tamsulosin 0.4 mg T_4_: Solifenacin 3 mg T_5_: Solifenacin 6 mg T_6_: Solifenacin 9 mg C_1_: Tamsulosin 0.4 mg C_2_: Placebo | 12 wk | I: I-PSS ≥13; Qmax = 4–15 mL/s; volume voided during free flow ≥120 mL E: PVR >200 mL; UTI; history of specific urinary conditions (including urinary retention); previous bladder neck or prostate surgery | Mean age: 65 Race: 100% white Baseline I-PSS: 18.5
Van Kerrebroeck, 2013b26 Netherlands N=1334 | T_1_: Solifenacin 6 mg; tamsulosin 0.4 mg T_2_: Solifenacin 9 mg; tamsulosin 0.4 mg C_1_: Placebo C_2_: Tamsulosin 0.4 mg | 12 wk | I: Age ≥45 yr; storage and voiding symptoms; LUTS ≥3 mo; I-PSS ≥ 13; Qmax = 4–12 mL/s; voided volume ≥120 mL during free flow; ≥2 urgency episodes per 24 hr (PPIUS grade 3 or 4); ≥ 8 micturitions per 24 hr before randomization E: Ultrasound-estimated prostate weight ≥75 g; UTI; history of specific urinary conditions; PVR >150 mL | Mean age: 65 Race: 99% white Baseline I-PSS: 18.7
Ceylan, 2012^27^ Turkey N=101 | T: Darifenacin 7.5 mg; doxazosin 4 mg C: Doxazosin 4 mg | 12 wk | I: Age >50 yr; I-PSS >12; >8 micturitions per 24 hr; urgency >3 episodes per 24 hr; some moderate problems related to their bladder condition reported E: PVR >150 mL; Qmax <5 mL/s; previous prostatic surgery; PSA >10 ng/mL; bladder stone; diverticula; UTI; urethral stricture; neurogenic bladder; diabetes mellitus; previously treated with α-adrenergic antagonist, antimuscarinic agents, or diuretic medicine; histopathological prostate cancer diagnosis; PSA = 4-10 ng/mL; transrectal ultrasound guided prostatic biopsy | Mean age: 64 Race: NR Baseline I-PSS: 16.3
Konstantinidis, 2012^28^ Greece N=47 | T: Fesoterodine 4 mg; tamsulosin 0.4 mg C: Tamsulosin 0.4 mg | 6 wk | I: Age ≥50 yr; LUTS storage symptoms from suspected OAB and BOO E: PVR ≥200 mL; I-PSS <12; Qmax ≤10 mL/s; prostate volume ≤60 cm^3^; PSA ≥4 ng/mL; history of neurological diseases, other medications for LUTS (e.g. 5 α-reductase agents), bladder surgical interventions, AUR, glaucoma, and hepatic or renal failure | Mean age: 64 Race: NR Baseline I-PSS: 16.0
Malkoc, 2012^29^ Turkey N=58 | T: Trospium chloride 45 mg; terazosin 5 mg C: Placebo; terazosin 5 mg | 12 wk | I: Age >45 yr; OAB symptoms (urgency and mean urinary frequency ≥8 times per 24 hr with or without urinary incontinence) E: History of neurologic diseases, previous use of anticholinergic or alpha adrenergic blocker, PVR ≥100 mL, prostate volume >50 mL; history of AUR requiring catheterization; prostatic surgery; prostate cancer; PSA >4 ng/mL; UTI; diabetes | Mean age: 58 Race: NR Baseline I-PSS: 15.3
Chung, 2011^30^ Taiwan N=137 | T: Tolterodine ER 4 mg qd; doxazosin ER 4 mg qd and or dutasteride 0.5 mg qd C: Doxazosin ER 4 mg qd and or dutasteride 0.5 mg qd | 52 wk | I: Age ≥70 yr; I-PSS >8; I-PSS-S >5; QoL-I >3; prostate volume >20 mL; Qmax <15 mL/s; urodynamic confirmed BPH/BOO E: Abnormal digital rectal examination; history of medical therapy or surgery for BPH; past or current use of ABs, finasteride or antimuscarinic agents; UTI; indwelling urethral catheter and previous urinary retention; PVR >250 mL; history of malignancy of genitourinary tract, neurological diseases (stroke, diabetes, multiple sclerosis, Parkinson's disease), symptomatic congestive heart failure, or chronic kidney disease | Mean age: 75 Race: NR Baseline I-PSS: NR
Kaplan, 2011^31^ USA N=943 | T: Flexible-dose fesoterodine 4 or 8 mg alpha blocker C: Placebo; alpha blocker | 12 wk | I: Age ≥40 yr; use of ABs for LUTS >6 wk; storage symptoms of frequency and urgency (≥8 micturitions and ≥3 urgency episodes per 24 hr); PPBC ≥3 E: PVR >200 mL; poor tolerability of ABs; history of AUR requiring catheterization; history or evidence of clinically significant BOO; prostate cancer; PSA >10 ng/mL; neurological conditions (stroke, multiple sclerosis, spinal cord injury, Parkinson's disease); UTI; >3 episodes UTI in prior 12 mo; history of prostatic, urethral, or bladder surgery; antimuscarinic within 3 wk or 5-ARIs within 6 mo | Mean age: 66 Race: 81% white Baseline I-PSS: 19.0
Lee, 2011^32^ Korea N=176 | T_1_: Tolterodine SR 4 mg; doxazosin GITS 4 mg T_2_: Doxazosin GITS 4 mg; placebo | 4 wk | I: Age ≥50 yr; I-PSS ≥14; I-PSS-V ≥8; I-PSS-S ≥6; QoL-I ≥3; ≥8 micturition per 24 hr; ≥1 micturition with urgency rating 3 per 24 hr; prostate volume ≥20; Qmax ≤15 mL/s; voided volume ≥125 mL E: History of neurogenic bladder dysfunction, prostate cancer, acute or chronic urinary retention, acute or chronic prostatitis within the prior 3 mo; PSA >10 ng/mL; recurrent UTI or bladder stones; previous medication history for BPH; previous surgical intervention related to BPO | Mean age: 61 Race: NR Baseline I-PSS: 21.4
Seo, 2011^33^ Korea N=56 | T: Solifenacin 5 mg qd; tamsulosin 0.2 mg qd C: Tamsulosin 0.2 mg qd | 12 wk | I: Age ≥40 yr; concurrent LUTS and ED; I-PSS >12; QoL-I >3; IIEF-5 <20 E: Anti-androgens, sex hormone agents, PDE-5s in prior 4 wk; prostate or urethra surgery; urethral stricture; UTI; prostatitis; prostate cancer; bladder cancer; PSA >4 mg/dL; severe renal or hepatic dysfunction; PVR >100 mL | Mean age: 58 Race: NR Baseline I-PSS: 17.8
Yamaguchi, 2011^34^ Japan N=638 | T: Solifenacin 2.5 mg; tamsulosin 0.2 mg T_2_: Solifenacin 5 mg; tamsulosin 0.2 mg C: Tamsulosin 0.2 mg; placebo | 12 wk | I: Age ≥50 yr; LUTS and residual OAB symptoms; urgency episodes ≥2 per 24 hr; micturitions ≥8 per 24 hr; Qmax ≥5 mL/s; PVR ≥50 mL E: Polyuria (≥3000 mL per 24 hr); urethral stricture; bladder neck stricture; prostate cancer or other malignancy; any disease other than LUTS that would affect voiding; surgery affecting urinary tract function; contraindicates for antimuscarinic or alpha-1 blocker therapy | Mean age: 70 Race: NR Baseline I-PSS: 13.5
Chapple, 2009^35^ North America, Asia, Europe, South Africa N=652 | T: Tolterodine ER 4 mg; alpha blocker (od 4 hr before bedtime) C: Placebo; alpha blocker (od 4 hr before bedtime) | 12 wk | I: Age ≥40 yr; 8 micturitions per 24 hr (including 1 urgency episodes per 24 hr with or without urgency); urinary incontinence moderate bladder-related problems despite use of AB ≥1 mo E: PVR ≤200 mL; history of AUR requiring catheterization; poor detrusor function; presumed clinically significant BOO; prostate cancer; PSA ≥10 ng/mL; UTI; neurological disease or injury; antimuscarinic use in prior 30 d | Mean age: 65 Race: 70% white Baseline I-PSS: 18.5
Kaplan, 2009^36^ Kaplan, 2013^40^ USA N=398 | T: Solifenacin 5 mg qd; tamsulosin 0.4 mg qd C: Tamsulosin 0.4 mg qd; placebo | 12 wk | I: Age >45 yr; residual OAB symptoms (>8 micturitions and >1 urgency episodes per 24 hr); history of LUTS >3 mo; I-PSS ≥13; PPBC ≥3; PVR ≤200 mL; PFR ≥5 mL/s E: Antimuscarinic therapy or participation in trials involving investigational drug in prior 30 d; urinary or gastric retention; ≥3 recurrent UTI episodes in prior 12 mo; prior or planned prostate surgery; 5-ARIs use with prior 3 mo; PSA >10 ng/mL | Mean age: 65 Race: 84% white Baseline I-PSS: 16.9
MacDiarmid, 2008^37^ USA N=420 | T: Oxybutynin 10 mg od; tamsulosin 0.4 mg od C: Tamsulosin 0.4 mg od; placebo | 12 wk | I: Age ≥45 yr; LUTS (I-PSS ≥13, I-PSS-S ≥8); PFR ≥4 mL/s; void volumes ≥125 mL; PVR ≤200 mL on ≥2 occasions E: History of urinary retention, bladder or prostate cancer, PSA ≥4 ng/mL (unless prostate cancer ruled out), angle-closure glaucoma, prostate surgery, or serious medical comorbidity; current medications for LUTS (α1-blockers other than tamsulosin, or 5α-reductase agents initiated within the past 4 months, and antimuscarinic agents) | Mean age: 63 Race: 90% white Baseline I-PSS: 20.4
Kaplan, 2006^38^ Kaplan, 2008^41^ Roehrborn, 2008^42^ Roehrborn, 2009^43^ USA N=879 | T: Tolterodine ER 4 mg T_2_: Tolterodine ER 4 mg; tamsulosin 0.4 mg C_1_: Placebo C_2_: Tamsulosin 0.4 mg | 12 wk | I: Age ≥40 yr; I-PSS ≥12; I-PSS QoL ≥3; OAB (≥8 voids/24 hr with urgency, ≥3 episodes/24 hr with or without urgency); reported ‘some moderate problems’ on PPBC E: PVR >200 mL; Qmax <5 mL/s; PSA >10 ng/mL and risk of prostate cancer | Mean age: 62 Race: 81% white Baseline I-PSS: 19.9

AB=alpha blocker; ARI=alpha-reductase inhibitor; AUR=acute urinary retention; bid=twice daily; BOO=bladder outlet obstruction; BOOI=bladder outlet obstruction index; BPH=benign prostatic hyperplasia; BPO=benign prostate obstruction; cm^3^=cubic centimeters; d=days; C=comparator group; C_1_=comparator group 1; C_2_=comparator group 2; dL=deciliters; E=exclusion criteria; ED=erectile dysfunction; g=grams; HbA1c= glycated haemoglobin; hr=hour; HRQL=health-related quality of life; I=inclusion criteria; IIEF-5=5-item International Index of Erectile Function; I-PSS=International Prostate Symptom Score-Total; I-PSS-S=International Prostate Symptom Score-Storage Subscale; I-PSS-V=International Prostate Symptom Score-Voiding Subscale; LUTS=lower urinary tract symptoms; mg=milligrams; min=minute; mL=milliliters; ng=nanograms; NR=not reported; OAB=overactive bladder; PFR=urine peak flow rate; PPBC=patient perception of bladder condition questionnaire; PPIUS=Patient Perception of Intensity of Urgency Scale; PSA=prostate-specific antigen; PVR=postvoid residual urine; qd=daily; Qmax=maximum urinary flow rate; QoL=quality of life; QoL-I=International Prostate Symptom Score-QoL Item; s=second; T=treatment group; T_1_=treatment group 1; T_2_=treatment group 2; UTI=urinary tract infection; wk=weeks; yr=years

Table E6 Strength of evidence assessments: tolterodine

Comparison | Outcome | # Trials (n) | Summary Statistics, [95% CI] | Study Limitations | Directness | Precision | Consistency | Reporting Bias | Optional Components | Evidence Rating
Tolterodine 4 mg vs. placebo | I-PSS score, mean change from baseline | 1 (419) | WMD = -0.70 [-1.88, 0.48] | Low | Direct | Precise | Unknown | Undetected^a^ | NA | Low
Tolterodine 4 mg vs. placebo | BII, mean change from baseline | 0 | | | | | | | NA | Insufficient
Tolterodine 4 mg vs. placebo | I-PSS QoL, mean change from baseline | 1 (419) | WMD = -0.10 [-0.40, 0.20] | Low | Direct | Precise | Unknown | Undetected^a^ | NA | Low
Tolterodine 4 mg vs. placebo | Overall withdrawals | 1 (439) | RR 0.84 [0.53, 1.34] | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Tolterodine 4 mg vs. placebo | Withdrawals due to adverse effects | 1 (439) | RR = 0.73 [0.24, 2.27] | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Tolterodine 4 mg vs. placebo | Participants with ≥1 adverse effect | 0 | | | | | | | NA | Insufficient
Tolterodine, 4 mg plus alpha-blocker vs. placebo | I-PSS/AUA-SI , mean change from baseline | 1 (416) | WMD=-1.80 [-2.92, -0.68] | Low | Direct | Precise | Unknown | Undetected^a^ | NA | Low
Tolterodine, 4 mg plus alpha-blocker vs. placebo | I-PSS QoL, mean change from baseline | 1 (418) | WMD=-0.40 [-0.66, -0.14] | Low | Direct | Precise | Unknown | Undetected^a^ | NA | Low
Tolterodine, 4 mg plus alpha-blocker vs. placebo | AUR | 1 (445) | OR=0.65 [0.11, 3.80] | Low | Indirect | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Tolterodine, 4 mg plus alpha-blocker vs. placebo | Overall withdrawals | 1 (447) | RR=0.99 [0.64, 1.53] | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Tolterodine, 4 mg plus alpha-blocker vs. placebo | Withdrawals due to adverse effects | 1 (447) | RR=2.82 [1.22, 6.53] | Low | Direct | Precise | Unknown | Undetected^a^ | NA | Low
Tolterodine, 4 mg plus alpha-blocker vs. alpha-blocker | Responders | 1 (70) | RR = 2.7 [1.55, 4.70] | High | Direct | Precise | Unknown | Undetected^a^ | NA | Insufficient
Tolterodine, 4 mg plus alpha-blocker vs. alpha-blocker | I-PSS score, mean change from baseline | 4 (1249) | WMD = -0.19 [-1.08 to 0.69] | Low-Moderate | Direct | Precise | Consistent | Undetected^a^ | NA | Moderate
Tolterodine, 4 mg plus alpha-blocker vs. alpha-blocker | I-PSS QoL, mean change from baseline | 3 (1182) | WMD= -0.34 [-1.14, 0.46] | Low | Direct | Imprecise | Inconsistent | Undetected^a^ | NA | Low
Tolterodine, 4 mg plus alpha-blocker vs. alpha-blocker | AUR | 3 (1268) | OR= 2.69 [0.25, 28.96] | Low | Indirect | Imprecise | Consistent | Undetected^a^ | NA | Insufficient
Tolterodine, 4 mg plus alpha-blocker vs. alpha-blocker | Overall withdrawals | 3 (1268) | RR= 1.11 [0.53, 2.34 | Low | Direct | Imprecise (CI not centered around 0) | Consistent | Undetected^a^ | NA | Low
Tolterodine, 4 mg plus alpha-blocker vs. alpha-blocker | Withdrawals due to adverse effects | 3 (1268) | RR= 2.17 [0.93, 5.06 | Low | Direct | Imprecise (CI skewed towards difference, but not statistically significant) | Consistent | Undetected^a^ | NA | Insufficient
Tolterodine, 4 mg plus alpha-blocker vs. alpha-blocker | Participants with ≥1 adverse effect | 1 (652) | RR= 1.26 [1.00, 1.58] | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Tolterodine 4 mg vs. alpha-blocker and or 5ARI | I-PSS score, mean change from baseline | 1 (137) | MD = -2.4 [NR] | High | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Tolterodine 4 mg vs. alpha-blocker and or 5ARI | I-PSS QoL, mean change from baseline | 1 (137) | MD = -0.1 [NR] | High | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Tolterodine 4 mg vs. tamsulosin 0.4 mg | I-PSS score, mean change from baseline | 1 (403) | MD = 0.90 [-0.46, 2.26] | Low | Direct | Precise | Unknown | Undetected^a^ | NA | Low
Tolterodine 4 mg vs. tamsulosin 0.4 mg | I-PSS QoL, mean change from baseline | 1(403) | MD = -0.10 [-0.21, 0.41] | Low | Direct | Precise | Unknown | Undetected^a^ | NA | Low
Tolterodine 4 mg vs. tamsulosin 0.4 mg | Overall withdrawals | 1 (432) | RR 0.96 [0.59, 1.55] | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Tolterodine 4 mg vs. tamsulosin 0.4 mg | Withdrawals due to adverse effects | 1 (439) | RR = 0.71 [0.23, 2.20] | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Tolterodine 4 mg vs. tamsulosin 0.4 mg | Participants with ≥1 adverse effect | 0 | | | | | | | NA | Insufficient
Tolterodine 4 mg vs. doxazosin 4 mg | I-PSS score, mean change from baseline | 1 (89) | MD = -0.20 [-2.32, 1.92] | High | Direct | Precise | Unknown | Undetected^a^ | NA | Insufficient
Tolterodine 4 mg vs. doxazosin 4 mg | I-PSS QoL, mean change from baseline | 1 (89) | MD = -0.20 [-0.61, 0.21] | High | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Tolterodine 4 mg vs. doxazosin 4 mg | Overall withdrawals | 1 (202) | RR = 0.83 [0.47, 1.45] | High | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Tolterodine 4 mg vs. doxazosin 4 mg | Withdrawals due to adverse effects | 1 (202) | RR = 0.65 [0.15, 2.84] | High | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Tolterodine 4 mg vs. doxazosin 4 mg | Participants with ≥1 adverse effect | 0 | | | | | | | NA | Insufficient

a We searched and screened results from clinicaltrials.gov. We identified one eligible tolterodine trial with a completion date of November 2015. We did not considered the lack of publication bias of this trial an indication of publication bias.

AUR=acute urinary retention; I-PSS/AUA-SI= International Prostate Symptom Scale/American Urological Association Symptom Index; QoL=quality of life; RR=risk ratio; SMD=standardized mean difference; WMD=weighted mean difference

* As a rule, tests for funnel plot asymmetry should be used only when there are at least 10 studies included in the meta-analysis, because when there are fewer studies the power of the tests is too low to distinguish chance from real asymmetry ( (2011). Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. )

## Analyses for Combined Tolterodine + α-Blocker Versus α-Blocker Monotherapy

Figure E1 I-PSS scores, mean change from baseline

* Indicates data was extracted and estimated from graph

Figure E1 is a Forrest plot comparing the mean change in I-PSS scores between tolterodine plus alpha-blocker and alpha-blocker alone. The pooled WMD shows no significant difference.

Table E7 Strength of evidence assessments: solifenacin

Comparison | Outcome | # Trials (n) | Summary Statistics, [95% CI] | Study Limitations | Directness | Precision | Consistency | Reporting Bias | Optional Components | Evidence Rating
Solifenacin 6 mg vs. placebo | I-PSS score, mean change from baseline | 1 (215) | MD = -0.30 [-1.74, 2.34] | Moderate | Direct | Precise | Unknown | Undetected^a^ | NA | Low
Solifenacin 6 mg vs. placebo | BII, mean change from baseline | NR | | | Direct | | | Undetected^a^ | NA | Insufficient
Solifenacin 6 mg vs. placebo | I-PSS QoL, mean change from baseline | NR | | | Direct | | | Undetected^a^ | NA | Insufficient
Solifenacin 6 mg vs. placebo | Overall withdrawals | 1 (222) | RR = 1.95 [0.64, 5.92] | Moderate | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Solifenacin 6 mg vs. placebo | Withdrawals due to adverse effects | 1 (222) | RR = 4.97 [0.26, 95.06] | Moderate | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Solifenacin 6 mg vs. placebo | Participants with ≥1 adverse effect | 1 (221) | RR = 1.19 [0.99 to 1.55] | Moderate | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Solifenacin, 3-6 mg plus alpha-blocker vs. placebo | I-PSS/AUA-SI , mean change from baseline | 3 (1023) | WMD= -1.50 [-1.80 to -1.20] | Low | Direct | Precise | Consistent | Undetected^a^ | NA | High
Solifenacin, 3-6 mg plus alpha-blocker vs. placebo | I-PSS QoL, mean change from baseline | 1 (629) | MD= -0.40 [-0.70, -0.10] | Low | Direct | Precise | Unknown | Undetected^a^ | NA | Low
Solifenacin, 3-6 mg plus alpha-blocker vs. placebo | Overall withdrawals | 3 (1857) | RR= 1.20 [0.46 to 3.13] | Low | Direct | Imprecise | Consistent | Undetected^a^ | NA | Low
Solifenacin, 3-6 mg plus alpha-blocker vs. placebo | Withdrawals due to adverse effects | 3 (1857) | RR= 2.17 [0.72 to 6.55] | Low | Direct | Imprecise | Consistent | Undetected^a^ | NA | Insufficient
Solifenacin, 3-6 mg plus alpha-blocker vs. placebo | Participants with ≥1 adverse effect | 3 (1848) | RR = 1.24 [0.99 to 1.55] | Low | Direct | Imprecise | Consistent | Undetected^a^ | NA | Insufficient
Solifenacin, 5 or 6 mg plus alpha-blocker vs. alpha-blocker | I-PSS score, mean change from baseline | 6 (1948) | WMD=-0.29 [-0.88, 0.30] | Low-Moderate | Direct | Precise | Consistent | Undetected^a^ | NA | Moderate
Solifenacin, 5 or 6 mg plus alpha-blocker vs. alpha-blocker | I-PSS QoL, mean change from baseline | 4 (1225) | WMD=-0.18 [-0.39, -0.03] | Low-Moderate | Direct | Precise | Consistent | Undetected^a^ | NA | Moderate
Solifenacin, 5 or 6 mg plus alpha-blocker vs. alpha-blocker | AUR | 4 (2531) | RR=3.75 [0.71, 19.79] | Low-Moderate | Direct | Imprecise | Consistent | Undetected^a^ | NA | Insufficient
Solifenacin, 5 or 6 mg plus alpha-blocker vs. alpha-blocker | Overall withdrawals | 7 (3147) | RR=1.02 [0.74, 1.41] | Low-Moderate | Direct | Imprecise | Consistent | Undetected^a^ | NA | Low
Solifenacin, 5 or 6 mg plus alpha-blocker vs. alpha-blocker | Withdrawals due to adverse effects | 5 (2900) | RR=1.27 [0.81, 2.0] | Moderate | Direct | Imprecise | Consistent | Undetected^a^ | NA | Low
Solifenacin, 5 or 6 mg plus alpha-blocker vs. alpha-blocker | Participants with ≥1 adverse effect | 5 (2918) | RR=1.21 [1.09, 1.35] | Moderate | Direct | Precise | Consistent | Undetected^a^ | NA | Moderate

a We searched and screened results from clinicaltrials.gov. We identified for two eligible solifenacin trials; both have been published and included in our review. We did not detect publication bias.

AUR=acute urinary retention; I-PSS/AUA-SI= International Prostate Symptom Scale/American Urological Association Symptom Index; MD=mean difference; QoL=quality of life; RR=risk ratio; SMD=standardized mean difference; WMD=weighted mean difference

* As a rule, tests for funnel plot asymmetry should be used only when there are at least 10 studies included in the meta-analysis, because when there are fewer studies the power of the tests is too low to distinguish chance from real asymmetry ( (2011). Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. )

## Analyses for Combined Solifenacin + α-Blocker Versus α-Blocker Monotherapy

Figure E2 I-PSS scores, mean change from baseline (solifenacin 5-6 mg + tamsulosin 0.2-0.4 mg versus tamsulosin 0.2-0.4 mg)

Figure E2 is a Forrest plot comparing the mean change in I-PSS scores between solifenacin 5-6 mg plus tamsulosin (any dose) and tamsulosin (any dose) alone. The pooled WMD shows no significant difference.

Figure E3 I-PSS scores, mean change from baseline (solifenacin 5 mg + tamsulosin 0.2 mg vs. tamsulosin 0.2 mg)

Figure E3 is a Forrest plot comparing the mean change in I-PSS scores between solifenacin 5 mg plus tamsulosin 0.2 mg and tamsulosin 0.2 mg alone. The pooled WMD shows no significant difference.

Figure E4 I-PSS scores, mean change from baseline (solifenacin 5-6 mg + tamsulosin 0.4 mg vs. tamsulosin 0.4 mg)

Figure E4 is a Forrest plot comparing the mean change from baseline on the I-PSS scores between solifenacin 5-6 mg plus tamsulosin 0.4 mg and tamsulosin 0.4 mg alone. The pooled WMD shows no significant difference.

Table E8 Strength of evidence assessments: fesoterodine

Comparison | Outcome | # Trials (n) | Summary Statistics, [95% CI] | Study Limitations | Directness | Precision | Consistency | Reporting Bias | Optional Components | Evidence Rating
Fesoterodine 4 mg plus alpha-blocker vs. alpha-blockerAB monotherapy | I-PSS score, mean change from baseline | 2 (990) | [underlined: Konstantinidis, 2013] MD = -1.70 [-5.85, 2.46] [underlined: Kaplan, 2011] MD = 0.00 [-0.83, 0.83] | ModerateLow | Direct | Imprecise | Consistent | Undetected^a^ | NA | Low
Fesoterodine 4 mg plus alpha-blocker vs. alpha-blockerAB monotherapy | AUR | 1 (947) | RR 1.00 [0.06 to 15.91] | Moderate | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Fesoterodine 4 mg plus alpha-blocker vs. alpha-blockerAB monotherapy | Overall withdrawals | 1 (947) | RR 1.49 [1.06 to 2.09] | Moderate | Direct | Precise | Unknown | Undetected^a^ | NA | Low
Fesoterodine 4 mg plus alpha-blocker vs. alpha-blockerAB monotherapy | Withdrawals due to adverse effects | 1 (947) | RR = 2.30 [1.38 to 3.82] | Moderate | Direct | Precise | Unknown | Undetected^a^ | NA | Low
Fesoterodine 4 mg plus alpha-blocker vs. alpha-blockerAB monotherapy | Participants with ≥1 adverse effect | 1 (947) | RR = 1.46 [1.25 to 1.71] | Moderate | Direct | Precise | Unknown | Undetected^a^ | NA | Low

a We searched and screened results from clinicaltrials.gov. We identified for two eligible solifenacin trials; both have been published and included in our review. We did not detect publication bias.

AUR=acute urinary retention; I-PSS/AUA-SI= International Prostate Symptom Scale/American Urological Association Symptom Index; MD=mean difference; QoL=quality of life; RR=risk ratio; SMD=standardized mean difference; WMD=weighted mean difference

* As a rule, tests for funnel plot asymmetry should be used only when there are at least 10 studies included in the meta-analysis, because when there are fewer studies the power of the tests is too low to distinguish chance from real asymmetry ( (2011). Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. )

Table E9 Strength of evidence assessments: other anticholinergics

Comparison | Outcome | # Trials (n) | Summary Statistics, [95% CI] | Study Limitations | Directness | Precision | Consistency | Reporting Bias | Optional Components | Evidence Rating
Oxybutynin 10 mg plus tamsulosin 0.4 mg vs. tamsulosin 0.4 mg plus placebo | I-PSS/AUA-SI, mean change from baseline | 1 (420) | MD = -1.70 [-2.93 to -0.47] | Moderate | Direct | Precise | Unknown | Undetected | NA | Insufficient
Oxybutynin 10 mg plus tamsulosin 0.4 mg vs. tamsulosin 0.4 mg plus placebo | I-PSS QoL, mean change from baseline | NR | | | | | | | NA | Insufficient
Oxybutynin 10 mg plus tamsulosin 0.4 mg vs. tamsulosin 0.4 mg plus placebo | AUR | NR | | | | | | | NA | Insufficient
Oxybutynin 10 mg plus tamsulosin 0.4 mg vs. tamsulosin 0.4 mg plus placebo | Overall withdrawals | NR | | | | | | | NA | Insufficient
Oxybutynin 10 mg plus tamsulosin 0.4 mg vs. tamsulosin 0.4 mg plus placebo | Withdrawals due to adverse effects | 1 (420) | RR = 1.06 [0.60 to 1.90] | Moderate | Direct | Imprecise | Unknown | Undetected | NA | Insufficient
Oxybutynin 10 mg plus tamsulosin 0.4 mg vs. tamsulosin 0.4 mg plus placebo | Participants with ≥1 adverse effect | 1 (420) | RR = 1.00 [0.80 to 1.25] | Moderate | Direct | Imprecise | Unknown | Undetected | NA | Insufficient
Trospium 45 mg plus terazosin 5 mg (alpha-blocker) vs. placebo plus terazosin 5 mg | I-PSS/AUA-SI, mean change from baseline | 1 (58) | Unable to determine MD | Moderate | Direct | Unclear | Unknown | Undetected | NA | Insufficient
Trospium 45 mg plus terazosin 5 mg (alpha-blocker) vs. placebo plus terazosin 5 mg | I-PSS QoL, mean change from baseline | NR | | | | | | | NA | Insufficient
Trospium 45 mg plus terazosin 5 mg (alpha-blocker) vs. placebo plus terazosin 5 mg | AUR | NR | | | | | | | NA | Insufficient
Trospium 45 mg plus terazosin 5 mg (alpha-blocker) vs. placebo plus terazosin 5 mg | Overall withdrawals | NR | | | | | | | NA | Insufficient
Trospium 45 mg plus terazosin 5 mg (alpha-blocker) vs. placebo plus terazosin 5 mg | Withdrawals due to adverse effects | NR | | | | | | | NA | Insufficient
Trospium 45 mg plus terazosin 5 mg (alpha-blocker) vs. placebo plus terazosin 5 mg | Participants with ≥1 adverse effect | 1 (58) | RR = 1.47 [0.56 to 3.88] | Moderate | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Darifenacin 7.5 mg plus doxazosin 4 mg (alpha-blocker) vs. doxazosin 4 mg | I-PSS/AUA-SI, mean change from baseline | Singh, 2015 (60) Ceylan, 2012 (101) | Singh, 2015 MD = -2.6 [NR] Ceylan, 2012 MD = -3.47 [NR] | Low-Moderate | Direct | Unknown | Unknown | Undetected^a^ | NA | Insufficient
Darifenacin 7.5 mg plus doxazosin 4 mg (alpha-blocker) vs. doxazosin 4 mg | I-PSS QoL, mean change from baseline | Singh, 2015 (60) Ceylan, 2012 (101) | Singh, 2015 MD NR Ceylan, 2012 MD = -0.8 [NR] | Low-Moderate | Direct | Unknown | Unknown | Undetected^a^ | NA | Insufficient
Darifenacin 7.5 mg plus doxazosin 4 mg (alpha-blocker) vs. doxazosin 4 mg | AUR | Singh, 2015 (60) Ceylan, 2012 (101) | Singh, 2015 RR = 4.00 [0.47 to 33.73] Ceylan, 2012 NR | Low-Moderate | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Darifenacin 7.5 mg plus doxazosin 4 mg (alpha-blocker) vs. doxazosin 4 mg | Overall withdrawals | Singh, 2015 (60) Ceylan, 2012 (101) | Singh, 2015 RR not calculable Ceylan, 2012 RR = 0.98 [0.020 to 48.50] | Low-Moderate | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Darifenacin 7.5 mg plus doxazosin 4 mg (alpha-blocker) vs. doxazosin 4 mg | Withdrawals due to adverse effects | Singh, 2015 (60) Ceylan, 2012 (101) | Singh, 2015 RR = 9.00 [0.51 to 160.18] Ceylan, 2012 RR = 0.98 [0.020 to 48.50] | Low-Moderate | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient

a We searched and screened results from clinicaltrials.gov. We identified no eligible trials and detected no publication bias.

AUR=acute urinary retention; I-PSS/AUA-SI= International Prostate Symptom Scale/American Urological Association Symptom Index; MD=mean difference; QoL=quality of life; RR=risk ratio; SMD=standardized mean difference; WMD=weighted mean difference

* As a rule, tests for funnel plot asymmetry should be used only when there are at least 10 studies included in the meta-analysis, because when there are fewer studies the power of the tests is too low to distinguish chance from real asymmetry ( (2011). Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. )