# Appendix D Supporting Tables and Figures: Silodosin

Table D1 Risk of bias assessments: silodosin trials

Study | Overall Risk of Bias Assessment | Rationale
Seki, 2015^1^ | High | Randomization and concealment methods not reported, unblinded, groups similar at baseline except for prostate volume, high attrition
Choo, 2014^2^ | Moderate | Randomization and concealment methods not reported, groups similar at baseline except for I-PSS storage, double-blinded, low attrition, PP and ITT analyses
Pande, 2014^3^ | Low
Yokoyama, 2012^4^ | Moderate | Randomization and concealment methods not reported, groups similar at baseline, unblinded, completer analysis, attrition not reported by group
Chapple, 2011^5^ | Low
Watanabe, 2011^6^ | High | Randomization and concealment methods not reported, open label crossover design with no washout, planned analysis not reported, high attrition, only completer baseline and results data reported
Yokoyama, 2011^7^ | Moderate | Randomization and concealment methods not reported, groups similar at baseline except for PVR, unblinded, attrition moderate and similar between groups, unclear how missing data handled
Yu, 2011^8^ | Moderate | Randomization and concealment methods not reported, groups similar at baseline except for prostate volume and acute urinary retention, double-blinded, attrition moderate and similar between groups, PP and ITT analyses
Miyakita, 2010^9^ | High | Randomization and concealment methods not reported, drug dosages differed between groups, groups similar at baseline except for heart rate, unblinded, crossover design with no washout, planned analysis not reported, high attrition which differed by group, both baseline and outcome data reported for per protocol population only
Marks, 2009^10^ | Low
Kawabe, 2006^11^ | Moderate | Randomization and concealment methods not reported, groups similar at baseline except for QoL, different group sizes, attrition not reported but only one patient excluded from analysis, outcome reporting unclear

Table D2 Summary characteristics of BPH treatment, comparison, and population: silodosin trials

Characteristic | Mean (range) Unless Otherwise Noted | Number of Studies Reporting
Total randomized | 2940 (46 to 955) | 9
Percentage randomized based on # screened | 46 (32 to 78) | 2
Received placebo, # randomized (% all randomized) | 736 (25) (89 to 457) | 3
Received tamsulosin^a^, # randomized (% all randomized) | 870 (30) (23 to 384) | 8
Age of subjects, years | 66 (62 to 71) | 9
Percentage white race | 61 (0^a^ to 100) | 9
Baseline I-PSS | 19 (17 to 21) | 9

a For crossover trials includes patients randomized to tamsulosin in the first phase

b All subjects from trials conducted in Asia (Japan, Korea, India: k=7; n=1022) presumed to be non-European white

I-PSS=International Prostate Symptom Score

Table D3 Study characteristics: silodosin

Study Country Number Randomized | Intervention Comparisons | Duration | Inclusion/Exclusion Criteria | Population Characteristics
Seki, 2015^1^ | T_1_: Silodosin 8 mg qd T_2_: Silodosin 4 mg bid | 12 wk | I: Age ≥ 50 yr; LUTS, clinical BPH/OAB; IPSS ≥ 8; QOL ≥ 2; OAB symptom score ≥ 3; urgency score in OAB symptom score ≥ 2 E: Organic illness other than BPH (e.g. prostate cancer, acute or chronic prostatitis, bladder tumor, bladder calculus, bladder neck contracture, urethral stricture); surgical procedure of the lower urinary tract within 6 mo; indwelling urethral catheter; self-catheterization; active UTI; established or suspected neurogenic bladder | Mean age: 72 Race: NR Baseline I-PSS: 20.0
Choo, 2014^2^ Korea N=424 | T_1_: Silodosin 8 mg qd T_2_: Silodosin 4 mg bid | 12 wk | I: Age ≥ 50 yr; LUTS/BPH; I-PSS ≥ 8; QoL-I ≥ 3; prostate volume ≥ 20 mL; Qmax <15 E: PVR ≥200 mL; history of prostatectomy, intrapelvic radiation, prostate cancer, or PSA >10 ng/mL; neurogenic bladder; active UTI; renal impairment, severe hepatic or cardiovascular disease; history of orthostatic hypotension; use of ABs within 2 wk or 5-ARIs within 3 mo | Mean age: 64 Race: NR Baseline I-PSS: 19.0
Pande, 2014^3^ India N=61 | T: Silodosin 8 mg qd C: Tamsulosin 0.4 mg qd | 12 wk | I: Age > 50 yr; LUTS from BPH; I-PSS >7; treatment naïve E: LUTS but not BPH; acute retention of urine within 6 mo; elevated PSA, serious comorbidity; use of anticholinergic, androgenic or estrogenic medications; use of other α-adrenergic antagonists or diuretics; history of prostatic or urethral surgery, or substance abuse | Mean age: 62 Race: NR Baseline I-PSS: 18.4
Yokoyama, 2012^4^ Japan N=46 | T: Silodosin 4 mg bid C: Tamsulosin 0.2 mg qd | 13 wk | I: Age ≥50 yr; I-PSS ≥8; QoL-I ≥3 E: History of prostate cancer, neurogenic bladder, or urethral stricture; active UTI or other complications likely to affect micturition; PSA >4 ng/mL; negative prostatic biopsy | Mean age: 70 Race: NR Baseline I-PSS: 20.2
Chapple, 2011^5^ Eisenhardt, 2014^12^ Novara, 2014^13^ Europe N=1336 | T: Silodosin 8mg qd C_1_: Placebo C_2_: Tamsulosin 0.4 mg qd | 12 wk | I: Age ≥50 yr; LUTS (I-PSS ≥13); BOO (Qmax 4-15 mL/s and voided volume ≥125 mL); compliance 80%-120% during placebo run-in E: Improvement in the I-PSS ≥25% during run-in; PVR ≥250 mL; intravesical obstruction from any cause other than BPH; history of any procedure for BPH, active UTI or recurrent UTIs; current prostatitis or chronic prostatitis; history of prostate or invasive bladder cancer, significant postural hypotension; use of 5-ARIs within 6 mo of an AB or phytotherapy within 2 wk | Mean age: 66 Race: 100% white Baseline I-PSS: 19.1
Watanabe, 2011^6^ Japan N=102 | T: Silodosin 4 mg bid C: Tamsulosin 0.2 mg qd | 4 wk | I: I-PSS ≥8; QoL-I ≥2; LUTS/BPH; previously untreated E: NR | Mean age: 70 Race: NR Baseline I-PSS: 17.3
Yokoyama, 2011^7^ Japan N=90 | T: Silodosin 4 mg bid C: Tamsulosin 0.2 mg qd | 12 wk | I: Age 50-80 yr; I-PSS ≥8 E: PSA >10, unless biopsy-negative for malignancy | Mean age: 71 Race: NR Baseline I-PSS: 18.4
Yu, 2011^8^ Taiwan N=209 | T: Silodosin 4 mg bid C: Tamsulosin 0.2 mg qd; placebo | 12 wk | I: Age ≥40 yr; I-PSS ≥13; HRQL ≥3; prostate volume ≥20 mL; Qmax <15 mL/s; voided volume ≥100 mL E: Previous prostate surgery, prostate cancer, neurogenic bladder, bladder neck constriction, urethral stricture, bladder calculus; active UTI; PVR >250 mL; exposure to sex hormone within 3 mo; serum creatinine >2.0 mg/dL; severe liver or cardiovascular disease, severe hypotension; hypersensitivity; substance or alcohol abuse within 2 yr | Mean age: 67 Race: NR Baseline -I-PSS: 19.6
Miyakita, 2010^9^ Japan N=97 | T: Silodosin 4 mg bid C: Tamsulosin 0.2 mg qd | 4 wk | I: I-PSS ≥8; QoL-I ≥3; prostate volume ≥20 mL; void volume ≥100 mL; Qmax <15 mL/s E: lpha1-blocker use for hypertension, or for BPH within 2 mo; vardenafil use; inappropriate as judged by attending physician | Mean age: 69 Race: NR Baseline I-PSS: 17.4
Marks, 2009^10^ Marks, 2013^14^ Gittelman, 2011^15^ Kapla,n 2011^16^ Roehrborn, 2011^17^ Eisenhardt, 2014^12^ Novara, 2014^13^ USA N=923 | T: Silodosin 8 mg qd C: Placebo | 12 wk | I: Age ≥50 yr; I-PSS ≥13; Qmax 4 -15 mL/s; PVR <250 mL E: Use of alpha-adrenoceptor antagonists or 5-ARIs; intravesical obstruction unrelated to BPH; bladder calculi; history of or current condition affecting bladder function; prior surgical intervention to relieve BPH or bladder neck obstruction; active UTI or history of recurrent UTI within 2 yr; prostatitis within 3 mo; BPH unrelated urinary retention within 3 mo; recurring prostatitis; prior or current prostate cancer or PSA >10 ng/mL; prior invasive bladder cancer; bladder catheterization or bladder or prostate instrumentation within 30 d and history of or current significant postural hypotension, including changes in systolic or diastolic blood pressure or heart rate, and lightheadedness, fainting, blurred vision, profound weakness, or syncope upon change in position | Mean age: 65 Race: 89% white Baseline I-PSS: 21.3
Kawabe, 2006^11^ Homma, 2010^18^ Japan N=631 | T: Silodosin 4 mg bid C_1_: Placebo C_2_: Tamsulosin 0.2 mg qd | 12 wk | I: Age ≥50 yr; I-PSS of ≥8; QoL-I ≥3; LUTS/ BPH (by digital rectal examination or ultrasound); prostate volume ≥20 mL; Qmax <15 mL/s; voided volume ≥100 mL; PVR <100 mL; outpatients E: Use of antiandrogens within 1 yr; prostatectomy, intrapelvic radiation, or prostatic hyperthermia; prostate cancer or suspected prostate cancer; neurogenic bladder, bladder neck constriction, urethral stricture, bladder calculus, severe bladder diverticulum, active UTI, serum creatinine ≥2.0 mg/dL, other complications affecting micturition; severe hepatic or cardiovascular disease; orthostatic hypotension | Mean age: 65 Race: NR Baseline I-PSS: 17.1

AB=alpha blocker; ARI=alpha-reductase inhibitor; bid=twice daily; BOO=bladder outlet obstruction; BPH=benign prostatic hyperplasia; d=days; C=comparator group; C_1_=comparator group 1; C_2_=comparator group 2; dL=deciliters; E=exclusion criteria; HRQL=health-related quality of life; I=inclusion criteria; I-PSS=International Prostate Symptom Score; LUTS=lower urinary tract symptoms; mg=milligrams; mL=milliliters; ng=nanograms; NR=not reported; PSA=prostate-specific antigen; PVR=postvoid residual urine; qd=daily; Qmax=maximum urinary flow rate; QoL=quality of life; QoL-I=International Prostate Symptom Score-QoL Item; s=seconds; T=treatment group; T_1_=treatment group 1; T_2_=treatment group 2; UTI=urinary tract infection; wk=weeks; yr=years

Table D4 Strength of evidence assessments: silodosin versus placebo

Comparison | Outcome | # Trials (n) | Summary statistics [95% CI] | Study Limitations | Directness | Precision | Consistency | Reporting Bias | Optional Components | Evidence Rating
Silodosin, 8 mg vs. placebo | I-PSS/AUA-SI , mean change from baseline | 3 (1743) | Favors silodosin WMD = -2.68 [-3.91 to -1.44] | Low | Direct | Imprecise | Consistent | Undetected^a^ | NA | Moderate
Silodosin, 8 mg vs. placebo | Responders ≥ 25% reduction in I-PSS scores | 2 (819) | Favors silodosin [underlined: Chapple, 2011] RR = 1.32 [1.12 to 1.54] [underlined: Kawabe, 2006] RR = 1.51 [1.21 to 1.89] | Low | Direct | Precise | Consistent | Undetected^a^ | NA | High
Silodosin, 8 mg vs. placebo | I-PSS QoL, reporting “delighted, pleased, or mostly satisfied’ | 2 (1494) | Favors silodosin [underlined: Marks, 2009] RR = 1.42 [1.14 to 1.76] [underlined: Chapple, 2011] RR = 1.29 [1.02 to 1.63] | Low | Direct | Precise | Consistent | Undetected^a^ | NA | High
Silodosin, 8 mg vs. placebo | I-PSS QoL, mean change from baseline | 1 (264) | MD = -0.60 [-0.92 to -0.28] | Low | Direct | Precise | Consistent (w/dichotomous QoL) | Undetected^a^ | NA | Moderate
Silodosin, 8 mg vs. placebo | Overall withdrawals | 2 (1494) | No Difference [underlined: Marks, 2009] RR = 1.37 [0.92 to 2.03] [underlined: Chapple, 2011] RR = 0.69 [0.39 to 1.24] | Low | Direct | Imprecise (CI not centered around 0) | Consistent | Undetected^a^ | NA | Insufficient
Silodosin, 8 mg vs. placebo | Withdrawals due to adverse effects | 3 (1759) | Greater with silodosin RR = 2.41 [1.01 to 5.76] | Low | Direct | Precise | Consistent | Undetected^a^ | NA | High
Silodosin, 8 mg vs. placebo | Participants with ≥1 adverse effect | 3 (1757) | Greater with silodosin RR = 1.38 [1.05 to 1.81] | Low | Direct | Precise | Consistent | Undetected^a^ | NA | High

a We searched and screened results from clinicaltrials.gov. We identified five silodosin trials registered with clinicaltrials.gov; one registered trial could not be traced to a publication (NCT01222650); one included trial could not be traced to registration (Kawabe 2006); also identified a phase 2 trial in FDA documents that we did not identify a publication for. Results for I-PSS appeared consistent with those of published trials. We detected no publication bias.

I-PSS/AUA-SI= International Prostate Symptom Scale/American Urological Association Symptom Index; QoL=quality of life; RR=risk ratio; SMD=standardized mean difference; WMD=weighted mean difference

* As a rule, tests for funnel plot asymmetry should be used only when there are at least 10 studies included in the meta-analysis, because when there are fewer studies the power of the tests is too low to distinguish chance from real asymmetry ( (2011). Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. )

Table D5 Strength of evidence assessments: silodosin versus tamsulosin

Comparison | Outcome | # Trials (n) | Summary Statistics, [95% CI] | Risk of Bias | Directness | Precision | Consistency | Reporting Bias | Optional Components | Evidence Rating
Silodosin, 8 mg vs. tamsulosin 0.2 to 0.4 mg | I-PSS/AUA-, mean change from baseline (Silodosin 8 mg vs. Tamsulosin 0.2 or 0.4 mg, pooled) | 7 (1538) | WMD -0.63 [-1.62 to 0.36] | Moderate | Direct | Precise | Consistent | Undetected^a^ | NA | Moderate
Silodosin, 8 mg vs. tamsulosin 0.2 to 0.4 mg | I-PSS/AUA -, mean change from baseline (Silodosin 8 mg vs. Tamsulosin 0.2) | 5 (738) | WMD -0.69 [-3.00 to 1.66] | Moderate | Direct | Imprecise | Consistent | Undetected^a^ | Plausible Counfounding | Moderate
Silodosin, 8 mg vs. tamsulosin 0.2 to 0.4 mg | I-PSS/AUA -, mean change from baseline (Silodosin 8 mg vs. Tamsulosin 0.4) | [underlined: Pande, 2014] [underlined: (53)] [underlined: Chapple, 2011] (747) | [underlined: Pande, 2014] MD = -0.70 [-2.42 to 1.02] [underlined: Chapple, 2011] MD = -0.30 [-1.03 to 0.43] | Moderate | Direct | Precise | Consistent | Undetected^a^ | NA | Moderate
Silodosin, 8 mg vs. tamsulosin 0.2 to 0.4 mg | Responders – 25% reduction in I-PSS scores (Silodosin 8 mg vs. Tamsulosin 0.2 or 0.4 mg, pooled) | 3 (1283) | RR 1.07 [0.91 to 1.26] | Moderate | Direct | Precise | Consistent | Undetected^a^ | NA | Moderate
Silodosin, 8 mg vs. tamsulosin 0.2 to 0.4 mg | Responders, based on ≥25% reduction in total I-PSS score (Silodosin 8 mg vs. Tamsulosin 0.2) | 2 (536) | [underlined: Yu, 2011] RR = 1.05 [0.92 to 1.20] [underlined: Kawabe, 2006] RR = 1.16 [1.02 to 1.33] | Moderate | Direct | Imprecise | Inconsistent | Undetected^a^ | NA | Insufficient
Silodosin, 8 mg vs. tamsulosin 0.2 to 0.4 mg | Responders, based on ≥25% reduction in total I-PSS score (Silodosin 8 mg vs. Tamsulosin 0.4) | 1 (747) | RR = 1.02 [0.92 to 1.13] | Moderate | Direct | Precise | Unknown | Undetected^a^ | NA | Low
Silodosin, 8 mg vs. tamsulosin 0.2 to 0.4 mg | I-PSS QoL, reporting “delighted, pleased, or mostly satisfied’ | 1 (765) | RR 0.98 [0.83 to 1.15] | Low | Direct | Precise | Unknown | Undetected^a^ | NA | Low
Silodosin, 8 mg vs. tamsulosin 0.2 to 0.4 mg | I-PSS QoL, mean change from baseline (Silodosin 8 mg vs. Tamsulosin 0.2 mg) | 5 (728) | WMD -0.16 [-0.80 to 0.48] | Moderate | Direct | Precise | Inconsistent | Undetected^a^ | Plausible Confounding | Moderate
Silodosin, 8 mg vs. tamsulosin 0.2 to 0.4 mg | I-PSS QoL, mean change from baseline (Silodosin 8 mg vs. Tamsulosin 0.4 mg) | 1 (747) | MD = -0.30 [-1.03 to 0.43] | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Low
Silodosin, 8 mg vs. tamsulosin 0.2 to 0.4 mg | Overall withdrawals (Silodosin 8 mg vs. Tamsulosin 0.2 or 0.4 mg, pooled) | 4 (1125) | RR 1.05 [0.73 to 1.5] | Moderate | Direct | Imprecise | Consistent | Undetected^a^ | NA | Low
Silodosin, 8 mg vs. tamsulosin 0.2 to 0.4 mg | Overall withdrawals (Silodosin 8 mg vs. Tamsulosin 0.4 mg) | [underlined: Pande, 2014] (53) [underlined: Chapple, 2011] (747) | [underlined: Pande, 2014] RR = 2.72 [0.60 to 12.42] [underlined: Chapple, 2011] RR = 1.26 [0.71 to 2.23] | Moderate | Direct | Imprecise | Consistent | Undetected^a^ | NA | Insufficient
Silodosin, 8 mg vs. tamsulosin 0.2 to 0.4 mg | Withdrawals due to adverse effects (Silodosin 8 mg vs. Tamsulosin 0.2 or 0.4 mg, pooled) | 3 (1222) | RR 1.96 [1.04 to 3.71] | Moderate | Direct | Precise | Consistent | Undetected^a^ | Plausible Confounding | Moderate
Silodosin, 8 mg vs. tamsulosin 0.2 to 0.4 mg | Withdrawals due to adverse effects (Silodosin 8 mg vs. Tamsulosin 0.4 mg) | 1 (747) | [underlined: Chapple, 2011] RR = 2.02 [0.61 to 6.64] | Low | Direct | Imprecise | Unknown | Undetected^a^ | NA | Insufficient
Silodosin, 8 mg vs. tamsulosin 0.2 to 0.4 mg | Participants with ≥1 adverse effect (Silodosin 8 mg vs. Tamsulosin 0.2 or 0.4 mg, pooled) | 3 (1338) | RR 1.11 [0.95 to 1.29] | Moderate | Direct | Imprecise | Consistent | Undetected^a^ | NA | Insufficient

a We searched and screened results from clinicaltrials.gov. We identified five silodosin trials registered with clinicaltrials.gov; one registered trial could not be traced to a publication (NCT01222650); one included trial could not be traced to registration (Kawabe 2006); also identified a phase 2 trial in FDA documents that we did not identify a publication for. Results for I-PSS appeared consistent with those of published trials. We detected no publication bias.

I-PSS/AUA-SI= International Prostate Symptom Scale/American Urological Association Symptom Index; QoL=quality of life; RR=risk ratio; SMD=standardized mean difference; WMD=weighted mean difference

* As a rule, tests for funnel plot asymmetry should be used only when there are at least 10 studies included in the meta-analysis, because when there are fewer studies the power of the tests is too low to distinguish chance from real asymmetry ( (2011). Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. )

## Analysis Figures for Silodosin

Figure D1 I-PSS scores, mean change from baseline: silodosin vs. placebo

Figure D1 is a Forrest plot comparing the mean change in I-PSS scores between silodosin and placebo. The pooled WMD shows that silodosin improves mean I-PSS scores more than placebo.

Figure D2 I-PSS responders (≥25 decrease from baseline): silodosin vs. tamsulosin

Figure D2 is a Forrest plot comparing responders to treatment based on I-PSS score (≥25 decrease from baseline) between silodosin and tamsulosin. The risk ratio shows more responders to tamsulosin than silodosin.

Figure D3 I-PSS scores, mean change from baseline: silodosin vs. tamsulosin (0.2 and 0.4 mg doses)

Figure D3 is a Forrest plot comparing the mean change in I-PSS scores between silodosin and all doses of tamsulosin (0.2 and 0.4 mg). The pooled WMD shows no significant difference.

Figure D4 I-PSS scores, mean change from baseline: silodosin vs. tamsulosin (0.2 mg)

Figure D4 is a Forrest plot comparing the mean change in I-PSS scores between silodosin and tamsulosin 0.2 mg. The pooled WMD shows no significant difference.