# Appendix C Excluded Studies

(Reason for exclusion appears in italics following each reference)

1 Abrams P, Kaplan S, De Koning Gans HJ, et al. (2006). Safety and tolerability of tolterodine for the treatment of overactive bladder in men with bladder outlet obstruction. Journal of Urology.
2 Ahmed AF, Maarouf A, Shalaby E, et al. (2015). The impact of adding low-dose oral desmopressin therapy to tamsulosin therapy for treatment of nocturia owing to benign prostatic hyperplasia. World Journal of Urology.
3 Athanasopoulos A, Gyftopoulos K, Giannitsas K, et al. (2003). Combination treatment with an alpha-blocker plus an anticholinergic for bladder outlet obstruction: a prospective, randomized, controlled study. Journal of Urology.
4 Auerbach SM, Gittelman M, Mazzu A, et al. (2004). Simultaneous administration of vardenafil and tamsulosin does not induce clinically significant hypotension in patients with benign prostatic hyperplasia. Urology.
5 Bae JH, Kim SO, Yoo ES, et al. (2011). Efficacy and safety of low-dose propiverine in patients with lower urinary tract symptoms/benign prostatic hyperplasia with storage symptoms: A prospective, randomized, single-blinded and multicenter clinical trial. Korean Journal of Urology.
6 Bechara A, Romano S, Casabe A, et al. (2008). Comparative efficacy assessment of tamsulosin vs. tamsulosin plus tadalafil in the treatment of LUTS/BPH. Pilot study. Journal of Sexual Medicine.
7 Chen JH, Yu QW, Shen J, et al. (2011). Effectiveness of combined therapy with terazosin and tolterodine for patients with benign prostatic hyperplasia. Journal of Shanghai Jiaotong University (Medical Science).
8 Choi H, Kim JH, Shim JS, et al. (2015). Comparison of the efficacy and safety of 5-mg once-daily versus 5-mg alternate-day tadalafil in men with erectile dysfunction and lower urinary tract symptoms. International Journal of Impotence Research.
9 De Rose AF, Giglio M, Traverso P, et al. (2002). Combined oral therapy with sildenafil and doxazosin for the treament of non-organic erectile dysfunction refractory to sildenafil monotherapy. International Journal of Impotence Research.
10 Dimitropoulos K, Gravas S. (2015). Solifenacin/tamsulosin fixed-dose combination therapy to treat lower urinary tract symptoms in patients with benign prostatic hyperplasia. Drug design, development & therapy.
11 Donatucci CF, Brock GB, Goldfischer ER, et al. (2011). Tadalafil administered once daily for lower urinary tract symptoms secondary to benign prostatic hyperplasia: a 1-year, open-label extension study. BJU International.
12 Gacci M, Corona G, Vignozzi L, et al. (2014). Metabolic Syndrome and Benign Prostatic Enlargement: A Systematic Review and Meta-Analysis. BJU international.
13 Gacci M, Sebastianelli A, Salvi M, et al. (2015). Tolterodine in the Treatment of Male LUTS. Current Urology Reports.
14 Giuliano F, Oelke M, Jungwirth A, et al. (2013). Tadalafil once daily improves ejaculatory function, erectile function, and sexual satisfaction in men with lower urinary tract symptoms suggestive of benign prostatic hyperplasia and erectile dysfunction: results from a randomized, placebo- and tamsulosin-controlled, 12-week double-blind study. Journal of Sexual Medicine.
15 Glina S, Roehrborn CG, Esen A, et al. (2015). Sexual function in men with lower urinary tract symptoms and prostatic enlargement secondary to benign prostatic hyperplasia: results of a 6-month, randomized, double-blind, placebo-controlled study of tadalafil coadministered with finasteride. Journal of Sexual Medicine.
16 Guven EO, Balbay MD, Mete K, et al. (2009). Uroflowmetric assessment of acute effects of sildenafil on the voiding of men with erectile dysfunction and symptomatic benign prostatic hyperplasia. International Urology & Nephrology.
17 Hakimi Z, Johnson M, Nazir J, et al. (2015). Drug treatment patterns for the management of men with lower urinary tract symptoms associated with benign prostatic hyperplasia who have both storage and voiding symptoms: a study using the health improvement network UK primary care data. Current Medical Research & Opinion.
18 Jin Z, Zhang ZC, Liu JH, et al. (2011). An open, comparative, multicentre clinical study of combined oral therapy with sildenafil and doxazosin GITS for treating Chinese patients with erectile dysfunction and lower urinary tract symptoms secondary to benign prostatic hyperplasia. Asian Journal of Andrology.
19 Johnson ITM, Markland AD, Goode PS, et al. (2013). Efficacy of adding behavioural treatment or antimuscarinic drug therapy to alpha-blocker therapy in men with nocturia. BJU International.
20 Kaplan SA. (2015). Re: Effect of tadalafil once daily on prostate blood flow and perfusion in men with lower urinary tract symptoms secondary to benign prostatic hyperplasia: a randomized, double-blind, multicenter, placebo-controlled trial. Journal of Urology.
21 Kraus SR, Dmochowski R, Albo ME, et al. (2010). Urodynamic standardization in a large-scale, multicenter clinical trial examining the effects of daily tadalafil in men with lower urinary tract symptoms with or without benign prostatic obstruction. Neurourology and Urodynamics.
22 MacDiarmid SA, Anderson RU, Armstrong RB, et al. (2005). Efficacy and safety of extended release oxybutynin for the treatment of urge incontinence: an analysis of data from 3 flexible dosing studies. Journal of Urology.
23 Marks LS, Gittelman MC, Hill LA, et al. (2009). Silodosin in the treatment of the signs and symptoms of benign prostatic hyperplasia: a 9-month, open-label extension study. Urology.
24 Masumori N. (2015). Editorial Comment from Dr Masumori to Treatment satisfaction and clinically meaningful symptom improvement in men with lower urinary tract symptoms and prostatic enlargement secondary to benign prostatic hyperplasia: Secondary results from a 6-month, randomized, double-blind study comparing finasteride plus tadalafil with finasteride plus placebo. International Journal of Urology.
25 Mathias SD, Crosby RD, Nazir J, et al. (2014). Validation of the Patient Perception of Intensity of Urgency Scale in patients with lower urinary tract symptoms associated with benign prostatic hyperplasia. Value in Health.
26 Ng CF, Wong A, Cheng CW, et al. (2008). Effect of vardenafil on blood pressure profile of patients with erectile dysfunction concomitantly treated with doxazosin gastrointestinal therapeutic system for benign prostatic hyperplasia. Journal of Urology.
27 Nieminen T, Tammela TL, Koobi T, et al. (2006). The effects of tamsulosin and sildenafil in separate and combined regimens on detailed hemodynamics in patients with benign prostatic enlargement. Journal of Urology.
28 Nishizawa O, Yamaguchi O, Takeda M, et al. (2011). Randomized controlled trial to treat benign prostatic hyperplasia with overactive bladder using an alpha-blocker combined with anticholinergics. LUTS: Lower Urinary Tract Symptoms.
29 Oh-Oka H. (2015). Editorial Comment from Dr Oh-oka to Treatment satisfaction and clinically meaningful symptom improvement in men with lower urinary tract symptoms and prostatic enlargement secondary to benign prostatic hyperplasia: Secondary results from a 6-month, randomized, double-blind study comparing finasteride plus tadalafil with finasteride plus placebo. International Journal of Urology.
30 Perumal C, Chowdhury PS, Ananthakrishnan N, et al. (2015). A comparison of the efficacy of naftopidil and tamsulosin hydrochloride in medical treatment of benign prostatic enlargement. Urology annals.
31 Porst H, McVary KT, Montorsi F, et al. (2009). Effects of once-daily tadalafil on erectile function in men with erectile dysfunction and signs and symptoms of benign prostatic hyperplasia. European Urology.
32 Roehrborn CG, Kaminetsky JC, Auerbach SM, et al. (2010). Changes in peak urinary flow and voiding efficiency in men with signs and symptoms of benign prostatic hyperplasia during once daily tadalafil treatment. BJU International.
33 Rovner ES, Kreder K, Sussman DO, et al. (2008). Effect of tolterodine extended release with or without tamsulosin on measures of urgency and patient reported outcomes in men with lower urinary tract symptoms. Journal of Urology.
34 Te AE. (2008). Should vardenafil be used for the treatment of lower urinary tract symptoms associated with BPH?. Nature Clinical Practice Urology.
35 (2011). Oral desmopressin effective for nocturnal polyuria in men with benign prostatic hyperplasia. Journal of the National Medical Association.
36 Wang CJ, Lin YN, Huang SW, et al. (2011). Low dose oral desmopressin for nocturnal polyuria in patients with benign prostatic hyperplasia: a double-blind, placebo controlled, randomized study. Journal of Urology.
37 Yalcinkaya FR, Davarci M, Akcin S, et al. (2012). Urodynamic evaluation of acute effects of sildenafil on voiding among males with erectile dysfunction and symptomatic benign prostate. Turkish Journal of Medical Sciences.
38 Yang Y, Zhao XF, Li HZ, et al. (2007). Efficacy and safety of combined therapy with terazosin and tolteradine for patients with lower urinary tract symptoms associated with benign prostatic hyperplasia: a prospective study. Chinese Medical Journal.
39 Yuan JQ, Mao C, Wong SY, et al. (2015). Comparative Effectiveness and Safety of Monodrug Therapies for Lower Urinary Tract Symptoms Associated With Benign Prostatic Hyperplasia: A Network Meta-analysis. Medicine.