# Appendix A Analytical Framework and Search Strategies

Figure A1 Analytical framework for newer medications for LUTS/BPH

Figure A1 is the analytical framework describing the flow of individuals through the intervention process after initiating medical management for benign prostatic hyperplasia. These patients enter the system and receive a medication or combination of medications. Medications can have associated harms which may lead to treatment discontinuation. Final health outcomes include reduction of symptoms, the impact of symptoms on patient well-being, prostate related quality of life or bother, and disease progression.

## Search Strategies

### BPH Medline RCTs SRs Harms

1. *Prostatic Hyperplasia/
2. (hyperplasia adj3 prostat*).ti,ab.
3. hyperplasia of the prostate.ti,ab.
4. prostatic hyperplasia.ti,ab.
5. (hypertrophy adj3 prostat*).ti,ab.
6. (adenoma* adj3 prostat*).ti,ab.
7. exp *Lower Urinary Tract Symptoms/
8. lower urinary tract.ti,ab.
9. prostatism.ti,ab.
10. exp *Prostatism/
11. exp *Urinary Bladder Neck Obstruction/
12. bladder outlet obstruction.ti,ab.
13. (prostat* adj3 enlarg*).ti,ab.
14. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13
15. silodosin.mp.
16. ‘KMD-3213’.ti,ab.
17. rapaflo.ti,ab.
18. 15 or 16 or 17
19. oxybutynin.ti,ab.
20. oxytrol.ti,ab.
21. 19 or 20
22. fesoterodine.ti,ab.
23. toviaz.ti,ab.
24. 22 or 23
25. darifenacin.ti,ab.
26. enablex.ti,ab.
27. 25 or 26
28. tolterodine.ti,ab.
29. detrol.ti,ab.
30. 28 or 29
31. solifenacin.ti,ab.
32. vesicare.ti,ab.
33. 31 or 32
34. trospium.ti,ab.
35. sanctura.ti,ab.
36. 34 or 35
37. mirabegron.ti,ab.
38. myrbetriq.ti,ab.
39. 37 or 38
40. tadalafil.ti,ab.
41. cialis.ti,ab.
42. 40 or 41
43. sildenafil.ti,ab.
44. viagra.ti,ab.
45. 43 or 44
46. avanafil.ti,ab.
47. stendra.ti,ab.
48. 46 or 47
49. vardenafil.ti,ab.
50. staxyn.ti,ab.
51. levitra.ti,ab.
52. 49 or 50 or 51
53. 18 or 21 or 24 or 27 or 30 or 33 or 36 or 39 or 42 or 45 or 48 or 52
54. 14 and 53
55. meta analysis as topic/
56. meta-analy$.tw.
57. metaanaly$.tw.
58. meta-analysis/
59. (systematic adj (review$1 or overview$1)).tw.
60. exp Review Literature as Topic/
61. or/55-60
62. cochrane.ab.
63. embase.ab.
64. (psychlit or psyclit).ab.
65. (psychinfor or psycinfo).ab.
66. or/62-65
67. reference list$.ab.
68. bibliograph$.ab.
69. hand search.ab.
70. relevant journals.ab.
71. manual search$.ab.
72. or/67-71
73. selection criteria.ab.
74. data extraction.ab.
75. 73 or 74
76. review/
77. 75 and 76
78. comment/
79. letter/
80. editorial/
81. animal/
82. human/
83. 81 not (82 and 81)
84. or/78-80,83
85. 61 or 66 or 72 or 77
86. 85 not 84
87. randomized controlled trials as topic/
88. randomized controlled trial/
89. random allocation/
90. double blind method/
91. single blind method/
92. clinical trial/
93. clinical trial, phase i.pt.
94. clinical trial, phase ii.pt.
95. clinical trial, phase iii.pt.
96. clinical trial, phase iv.pt.
97. controlled clinical trial.pt.
98. randomized controlled trial.pt.
99. multicenter study.pt.
100. clinical trial.pt.
101. exp Clinical trials as topic/
102. or/87-101
103. (clinical adj trial$).tw.
104. ((singl$ or doubl$ or treb$ or tripl$) adj (blind$3 or mask$3)).tw.
105. placebos/
106. placebo$.tw.
107. randomly allocated.tw.
108. (allocated adj2 random$).tw.
109. 103 or 104 or 105 or 106 or 107 or 108
110. 102 or 109
111. case report.tw.
112. case report.tw.
113. letter/
114. historical article/
115. 111 or 112 or 113 or 114
116. 110 not 115
117. 14 and 53
118. (ae or to or po or co).fs.
119. (safe or safety).ti,ab.
120. side effec*.ti,ab.
121. ((adverse or undesirable or harm* or serious or toxic or negative) adj3 (effect* or reaction* or event* or outcome*)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
122. exp Product Surveillance, Postmarketing/
123. exp “Drug-Related Side Effects and Adverse Reactions”/
124. exp Adverse Drug Reaction Reporting Systems/
125. exp Clinical Trials, Phase IV as Topic/
126. exp Poisoning/
127. (toxicity or complication* or noxious or tolerability).ti,ab.
128. 118 or 119 or 120 or 121 or 122 or 123 or 124 or 125 or 126 or 127
129. 117 and (86 or 116 or 128)
130. limit 129 to (addresses or autobiography or bibliography or biography or case reports or clinical conference or comment or congresses or consensus development conference or consensus development conference, nih or dataset or dictionary or directory or editorial or festschrift or historical article or in vitro or interactive tutorial or interview or lectures or legal cases or legislation or letter or news or newspaper article or patient education handout or periodical index or portraits or validation studies or video-audio media or webcasts)
131. 129 not 130
132. limit 131 to “all child (0 to 18 years)”
133. limit 132 to “all adult (19 plus years)”
134. 131 not 132
135. 134 or 133
136. 135 and (“166”.mp. or 128) [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
137. 135 and 86

### BPH Embase RCTs SRs Harms

March 25, 2015

1. *Prostate hypertrophy/
2. (hyperplasia adj3 prostat*).ti,ab.
3. hyperplasia of the prostate.ti,ab.
4. prostatic hyperplasia.ti,ab.
5. (hypertrophy adj3 prostat*).ti,ab.
6. (adenoma* adj3 prostat*).ti,ab.
7. exp *Lower Urinary Tract Symptom/
8. lower urinary tract.ti,ab.
9. prostatism.ti,ab.
10. exp *Prostatism/
11. exp *Bladder Neck stenosis/
12. bladder outlet obstruction.ti,ab.
13. (prostat* adj3 enlarg*).ti,ab.
14. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13
15. silodosin.mp.
16. ‘KMD-3213’.ti,ab.
17. rapaflo.ti,ab.
18. 15 or 16 or 17
19. oxybutynin.ti,ab.
20. oxytrol.ti,ab.
21. 19 or 20
22. fesoterodine.ti,ab.
23. toviaz.ti,ab.
24. 22 or 23
25. darifenacin.ti,ab.
26. enablex.ti,ab.
27. 25 or 26
28. tolterodine.ti,ab.
29. detrol.ti,ab.
30. 28 or 29
31. solifenacin.ti,ab.
32. vesicare.ti,ab.
33. 31 or 32
34. trospium.ti,ab.
35. sanctura.ti,ab.
36. 34 or 35
37. mirabegron.ti,ab.
38. myrbetriq.ti,ab.
39. 37 or 38
40. tadalafil.ti,ab.
41. cialis.ti,ab.
42. 40 or 41
43. sildenafil.ti,ab.
44. viagra.ti,ab.
45. 43 or 44
46. avanafil.ti,ab.
47. stendra.ti,ab.
48. 46 or 47
49. vardenafil.ti,ab.
50. staxyn.ti,ab.
51. levitra.ti,ab.
52. 49 or 50 or 51
53. 18 or 21 or 24 or 27 or 30 or 33 or 36 or 39 or 42 or 45 or 48 or 52
54. 14 and 53
55. meta analysis as topic/
56. meta-analy$.tw.
57. metaanaly$.tw.
58. meta-analysis/
59. (systematic adj (review$1 or overview$1)).tw.
60. or/55-59
61. cochrane.ab.
62. embase.ab.
63. (psychlit or psyclit).ab.
64. (psychinfor or psycinfo).ab.
65. or/61-64
66. reference list$.ab.
67. bibliograph$.ab.
68. hand search.ab.
69. relevant journals.ab.
70. manual search$.ab.
71. or/66-70
72. selection criteria.ab.
73. data extraction.ab.
74. 72 or 73
75. review/
76. 74 and 75
77. comment/
78. letter/
79. editorial/
80. animal/
81. human/
82. 80 not (81 and 80)
83. or/77-79,82
84. 60 or 65 or 71 or 76
85. 84 not 83
86. randomized controlled trials as topic/
87. randomized controlled trial/
88. random allocation/
89. double blind method/
90. single blind method/
91. clinical trial/
92. (clinical adj trial$).tw.
93. ((singl$ or doubl$ or treb$ or tripl$) adj (blind$3 or mask$3)).tw.
94. placebos/
95. placebo$.tw.
96. randomly allocated.tw.
97. (allocated adj2 random$).tw.
98. or/86-97
99. case report.tw.
100. case study.tw.
101. letter/
102. historical article/
103. 99 or 100 or 101 or 102
104. 98 not 103
105. (ae or to or po or co).fs.
106. (safe or safety).ti,ab.
107. side effec*.ti,ab.
108. ((adverse or undesirable or harm* or serious or toxic or negative) adj3 (effect* or reaction* or event* or outcome*)).mp. [mp=title, abstract, subject headings, heading word, drug trade name, original title, device manufacturer, drug manufacturer, device trade name, keyword]
109. exp Product Surveillance, Postmarketing/
110. exp “Drug-Related Side Effects and Adverse Reactions”/
111. exp Adverse Drug Reaction Reporting Systems/
112. exp Clinical Trials, Phase IV as Topic/
113. exp Poisoning/
114. (toxicity or complication* or noxious or tolerability).ti,ab.
115. 105 or 106 or 107 or 108 or 109 or 110 or 111 or 112 or 113 or 114
116. 54 and (85 or 104 or 115)
117. limit 116 to (embryo or infant or child or preschool child <1 to 6 years> or school child <7 to 12 years> or adolescent <13 to 17 years>)
118. limit 117 to (adult <18 to 64 years> or aged <65+ years>)
119. 116 not 117
120. 119 or 118
121. limit 120 to (book or book series or conference abstract or conference proceeding or “conference review” or editorial or letter or note or short survey or trade journal)
122. 120 not 121
123. 122 and (104 or 115)
124. 122 and 85
125. 123 not 124
126. from 125 keep 1-461