# Abbreviations

AB: Alpha blocker
ARI: Alpha reductase inhibitors
AUA-SI: American Urological Association Symptom Index
AUR: Acute urinary retention
BII: BPH Impact Index
BOO: Bladder outlet obstruction
BPE: Benign prostatic enlargement
BPH: Benign prostatic hyperplasia
CENTRAL: Cochrane Central Register of Controlled Trials
CI: Confidence interval
ED: Erectile dysfunction
I-PSS: International Prostate Symptom Score
LUTS: Lower urinary tract symptoms
MDD: Minimal detectable difference
NNH: Number needed to harm
NNT: Number needed to treat
OAB: Overactive bladder
PICOTS: Population, interventions, comparisons, outcomes, timing, and setting
PVR: Postvoid residual urine
QoL: Quality of life
RCT: Randomized controlled trial
RR: Risk ratio
SMD: Standardized mean difference
SOE: Strength of evidence
WMD: Weighted mean difference