# Results

## Literature Search and Screening

Our bibliographic database and hand searching identified 4,855 unique records, of which 410 required full-text review after title and abstract screening (Figure 2). We completed full-text review to identify 129 eligible articles representing 126 unique RCTs.

Figure 2 Literature flow diagram

RCT=Randomized Controlled Trial

Figure 2 is the literature flow diagram describing the number of references identified through our bibliographic literature search (3,109), the number that were identified through title and abstract screening as needing full text review (204), the number from the search eligible for our review (96), the number eligible identified through hand searching (4) to the total number of references included (100) representind 99 unique randomized controlled trials.

We divided the 129 records into four categories for analysis based upon the setting in which the interventions occurred:

1. Patient-level interventions delivered in nursing home and assisted living facility settings (n=68; 67 unique RCTs)
2. Care-delivery level interventions delivered in nursing home and assisted living facility settings (n=28; 27 unique RCTs)
3. Patient-level interventions delivered to community-dwelling individuals with dementia (n=5; 5 unique RCTs)
4. Caregiver-level interventions delivered to caregivers of community-dwelling individuals with dementia (n=28; 27 unique RCTs)

We extracted basic study characteristics into evidence tables. These data will be transformed into the appropriate format, checked for accuracy, and then uploaded to the Systematic Review Data Repository after the final version of this report is posted. Supporting documentation for each category of interventions including risk of bias assessments of individual studies, descriptions of high-risk-of-bias trials, and strength of evidence assessments of unique interventions, comparisons, and outcomes appear in Appendix C for patient-level nursing home and assisted living facility interventions, Appendix D for care delivery-level nursing home and assisted living facility interventions, Appendix E for patient-level community interventions, and Appendix F for caregiver-level community interventions.

## Patient-Level Nonpharmacologic Interventions for Agitation/Aggression in Individuals With Dementia in Nursing Homes and Assisted Living Facilities

### Key Points

- Low strength evidence shows that music interventions, aromatherapy with lavender, and bright light therapy are similar to no intervention, placebo, and/or attention control in decreasing agitation/aggression among nursing home and assisted living facility residents with dementia.
- Low strength evidence shows that interventions tailored to patient skills, interventions tailored to patient interests, and interventions delivered to both skills and interests have similar effects on agitation/aggression among nursing home and assisted living facility residents with dementia.
- Evidence was insufficient for all other outcomes and comparisons.

### Overview

We identified 67 eligible trials that assessed patient-level nonpharmacologic interventions for agitation/aggression in residents of nursing homes and assisted living facilities. Of these, 27 were assessed as having a high risk of bias. These studies are described in Appendix C. Our analysis of the remaining 40 trials is provided below by intervention type (Tables 5 and 6). Trials with acceptable risk of bias examined a wide variety of interventions including therapies delivered directly to patients (e.g., music therapy, aroma therapy, bright light therapy), structured group activities (e.g., exercise), and activities specifically tailored to the individual. We grouped studies by intervention type and comparison. All studies were trials but they differed in the unit of randomization (i.e., at nursing home level, staff, or residents). In many of the studies the intervention was compared with “usual care” but the nature of this care was poorly specified. In some instances the intervention was added to usual care; in others it was offered as an alternative. It was frequently not even clear if psychoactive medications were being given concurrently. Table 5 provides a summary of the results by intervention type and comparison. Table 6 provides results for trials analyzed.

Table 5 Patient-level interventions for agitation/aggression in nursing home and assisted living facility residents with dementia

Intervention-Comparison | Total Number of Studies (Number of Participants) | Strength of Evidence - Summary of Results
Agitation/Aggression
Music vs. no treatment/attention control (for sustained reduction in agitation/aggression) | 4 (233) | Low – agitation/aggression not improved
Music vs. no treatment/attention control (for immediate reduction in agitation/aggression) | 1 (34) | Insufficient – no conclusions drawn
Music vs. comparison intervention (for sustained reduction in agitation/aggression) | 4 (218) | Low – agitation/aggression not improved
Aroma therapy with Lavender vs. no treatment/attention control | 3 (245) | Low – agitation/aggression not improved
Aroma therapy with Melissa vs. no treatment/attention control | 1 (72) | Insufficient – no conclusions drawn
Aroma therapy with Melissa vs. comparison intervention | 1 (77) | Insufficient – no conclusions drawn
Light therapy vs. no treatment/attention control | 4 (225) | Low – agitation/aggression not improved
Therapeutic touch vs. no treatment/attention control | 1 (51) | Insufficient – no conclusions drawn
Massage vs. no treatment/attention control | 1 (34) | Insufficient – no conclusions drawn
Massage vs. comparison intervention | 1 (55) | Insufficient – no conclusions drawn
Tailored activities vs. nontailored activities | 4 (334) | Insufficient – no conclusions drawn
Tailored activities vs. tailored activities | 2 (158) | Low – agitation/aggression not improved
Exercise vs. no treatment/attention control | No studies reporting | Insufficient – no conclusions drawn
Exercise vs. interactive control | No studies reporting | Insufficient – no conclusions drawn
Aroma-acupressure vs. no treatment/attention control | 1 (113) | Insufficient – no conclusions drawn
Multisensory room vs. no treatment/attention control | 1 (32) | Insufficient – no conclusions drawn
Multisensory room vs. interactive control | 1 (32) | Insufficient – no conclusions drawn
Humor therapy vs. no treatment/attention control | 1 (398) | Insufficient – no conclusions drawn
Acupuncture | No studies reporting | Insufficient – no conclusions drawn
Massage vs. ear acupuncture | No studies reporting | Insufficient – no conclusions drawn
Acupressure | 1 (133) | Insufficient – no conclusions drawn
Structured activities | 1 (133) | Insufficient – no conclusions drawn
Acupressure vs. structured activities | 1 (133) | Insufficient – no conclusions drawn
Reminiscence | No studies reporting | Insufficient – no conclusions drawn
Pleasant experiences | No studies reporting | Insufficient – no conclusions drawn
Multisensory vs. recreation | No studies reporting | Insufficient – no conclusions drawn
Activities of daily living vs. psychosocial activity | No studies reporting | Insufficient – no conclusions drawn
Simulated presence | 1 (54) | Insufficient – no conclusions drawn
Enhancing family visits | 1 (66) | Insufficient – no conclusions drawn
Electro stimulation | 1 (27) | Insufficient – no conclusions drawn
Group multistimulation vs. leisure activities | 1 (40) | Insufficient – no conclusions drawn
General Behavior
Music vs. no treatment/attention control (for sustained reduction in agitation/aggression) | 2 (99) | Insufficient – no conclusions drawn
Music vs. no treatment/attention control (for immediate reduction in agitation/aggression) | No studies reported | Insufficient – no conclusions drawn
Music vs. comparison intervention (for sustained reduction in agitation/aggression) | 2(125) | Insufficient – no conclusions drawn
Aroma therapy with Lavender vs. no treatment/attention control | 2 (98) | Insufficient – no conclusions drawn
Aroma therapy with Melissa vs. no treatment/attention control | No studies reported | Insufficient – no conclusions drawn
Aroma therapy with Melissa vs. comparison intervention | 1 (77) | Insufficient – no conclusions drawn
Light therapy vs. no treatment/attention control | 3 (133) | Low – general behavior not improved
Therapeutic touch vs. no treatment/attention control | 2 (108) | Insufficient – no conclusions drawn
Massage vs. no treatment/attention control | 1 (71) | Insufficient – no conclusions drawn
Tailored activities vs. nontailored activities | 1 (87) | Insufficient – no conclusions drawn
Tailored activities vs. tailored activities | No studies reported | Insufficient – no conclusions drawn
Exercise vs. no treatment/attention control | 1 (134) | Insufficient – no conclusions drawn
Exercise vs. interactive control | 1 (170) | Insufficient – no conclusions drawn
Multisensory room + massage + exercise vs. no treatment/attention control | 1 (39) | Insufficient – no conclusions drawn
Multisensory room vs. no treatment/attention control | 1 (32) | Insufficient – no conclusions drawn
Multisensory room vs. interactive control | 1 (32) | Insufficient – no conclusions drawn
Humor therapy vs. no treatment/attention control | 1 (398) | Insufficient – no conclusions drawn
Acupuncture | 1 (76) | Insufficient – no conclusions drawn
Massage vs. ear acupuncture | 1 (75) | Insufficient – no conclusions drawn
Acupressure | No studies reported | Insufficient – no conclusions drawn
Acupressure vs. structured activities | No studies reported | Insufficient – no conclusions drawn
Reminiscence | 1 (40) | Insufficient – no conclusions drawn
Pleasant experiences | 1 (20) | Insufficient – no conclusions drawn
Multisensory vs. recreation | 1 (136) | Insufficient – no conclusions drawn
Activities of daily living vs. psychosocial activity | 1 (127) | Insufficient – no conclusions drawn
Simulated presence | No studies reported | Insufficient – no conclusions drawn
Enhancing family visits | 1 (66) | Insufficient – no conclusions drawn
Electro stimulation | No studies reported | Insufficient – no conclusions drawn
Group Multistimulation vs. leisure activities | 1 (40) | Insufficient – no conclusions drawn

Note: only one study reported an intermediate outcome; data were insufficient – no conclusions drawn

Table 6 Efficacy and comparative effectiveness of patient-level interventions for agitation/aggression in nursing home and assisted living facility residents with dementia

Study Design Country Comparison n Study Risk of Bias | Intervention Description [Intensity, Duration, Qualifications Interventionist] | Primary Outcome-Instrument Results Intermediate Outcome-Instrument Results
Music - Efficacy
Sakamoto, 2013^58^ RCT Japan Music listening vs. interactive music vs. attention control n=39 Moderate risk of bias | Treatment 1: Music listening intervention with participants listening to music via CD Treatment 2: Interactive music intervention with participants listening to music on CD but also participating in an interactive activity (clapping, singing, dancing) Comparison: Attention control; - 30 minutes once/week for 10 weeks; - music facilitator | Agitation/Aggression Behave-AD Aggressiveness, mean (SD) Baseline: 1.5 (1.8) vs. 2.5 (2.4) vs. 2.5 (3.1) Postintervention: 1.5 (0.9) vs. 0.7 (1.0) vs. 3.2 (3.0) 3-week postintervention: 1.3 (2.0) vs. 2.5 (2.2) vs. 2.9 (3.1) General behavior Behave-AD, Global mean (SD) Baseline: 0.9 (0.5) vs. 1.5 (0.7) vs. 1.3 (0.7) Postintervention: 0.8 (0.4) vs. 0.7 (1.0) vs. 1.5 (0.8) 3-week postintervention: 1.1 (0.5) vs. 1.2 (0.6) vs. 2.2 (0.9) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Lin, 2011^59^ RCT Taiwan Group music therapy vs. usual care n=100 Moderate risk of bias | Treatment: Group music therapy intervention Comparison: usual daily activities (not otherwise specified); - 30-minute sessions twice weekly for 6 weeks (12 total sessions); - researcher trained in university music therapy programs | Agitation/Aggression C-CMAI, mean (SD) Baseline: 43.12 (16.32) vs. 37.78 (11.04) Postintervention: 36.37 (10.64) vs. 38.55 (10.27) One month postintervention: 35.69 (9.99) vs. 37.75 (9.70) General behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Raglio, 2010^60^ RCT Italy Cyclical music therapy + standard care vs. standard care alone n=60 Moderate risk of bias | Treatment: In groups of 3 participants, participants and the music therapist interacted through musical improvisation on various instruments and with nonverbal behaviors; group also received standard care (educational activities and entertainment – reading, physical activities) Comparison: standard care; - 3 cycles of 12 interactive sessions, 3 weekly 30-minute sessions; 1 month washout period between each cycle; total of 6 months; - music therapist | Agitation/Aggression NPI Agitation Subscale, mean (SD) Baseline: 3.13 (NR) vs. 3.87 (NR) Postintervention: 1.36(NR) vs. 3.00 (NR) 4-week postintervention: 1.57(NR) vs. 2.92 (NR) General behavior NPI: results presented graphically; authors report lower scores postintervention; between-group MANOVA of treatment effect - (F_1,51_=4.84, p<0.05); difference likely not significant at postintervention. Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Remington, 2002^61^ RCT United States Calming music vs. no treatment n = 26 (for these two groups) Moderate risk of bias | Treatment: taped calming music played from a CD player once Comparison: No treatment; - 1 10-minute session; - trained research assistant | Agitation/Aggression CMAI, mean (SD) Baseline: 18.41 (11.19) vs. 21.76 (9.09) Immediately postintervention: 9.18 (11.11) vs. 21.88 (10.38) 10 minutes postintervention: 7.76 (9.55) vs. 20.88 (8.66) 20 minutes postintervention: 3.06 (5.44) vs. 20.47 (10.90) Repeated measures analysis of variance across all 4 groups: F_3,9_=6.47; p<0.01 General behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Music – Comparative Effectiveness
Sakamoto, 2013^58^ RCT Japan Music listening vs. interactive music n = 26 Moderate risk of bias | Treatment 1: Music listening intervention with participants listening to music via CD Treatment 2: Interactive music intervention with participants listening to music on CD but also participating in an interactive activity (clapping, singing, dancing) Comparison: Attention control; - 30 minutes once/week for 10 weeks; - music facilitator | Agitation/Aggression Behave-AD Aggressiveness, mean (SD) Baseline: 1.5 (1.8) vs. 2.5 (2.4) Postintervention: 1.5 (0.9) vs. 0.7 (1.0) 3-week postintervention: 1.3 (2.0) vs. 2.5 (2.2) General behavior Behave-AD Global, mean (SD) Baseline: 0.9 (0.5) vs. 1.5 (0.7) Postintervention: 0.8 (0.4) vs. 0.7 (1.0) 3-week postintervention: 1.1 (0.5) vs. 1.2 (0.6) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Vink, 2013^63^ RCT The Netherlands Group music therapy vs. recreational activity n=94 Moderate risk of bias | Treatment: Group music therapy Comparison: Recreational activity; - 40 minute sessions twice/week for 4 months (up to 34 sessions); - music therapists, occupational therapists | Agitation/Aggression CMAI Means– shown in figures; AMD NS (F=2.89; p=0.09) General behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Cooke, 2010^62^ RCT-Crossover Australia Music-reading vs. reading-music n = 47 Moderate risk of bias | Treatment: Live, somewhat tailored music program with facilitated engagement and song Comparison: interactive reading intervention with short stories, jokes, and quizzes; - 40 minute sessions 3 times/week for 8 weeks (total of 24 sessions); - musician and reading group facilitator trained in working with persons with dementia | Agitation/Aggression CMAI-SF, mean (95% CI) Baseline: 1.66 (1.42-1.91) vs. 1.54 (1.32-1.77) After first arm: 1.67 (1.49-1.85) vs. 1.66 (1.37-1.96) General behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Remington, 2002^61^ RCT United States Calming music vs. hand massage vs. calming music and hand massage vs. control n = 68 (4 arms) Moderate risk of bias | Treatment 1: taped calming music played from a CD player (new age arrangement of Pachelbel's Canon in D) Treatment 2: hand massage; light pressure and slow strokes to each hand for 5 minutes Treatment 3: music + massage simultaneously Comparison: No treatment; - 1 10-minute session; - trained research assistant | Agitation/Aggression CMAI, mean (SD) Baseline: 18.41 (11.19) vs. 16.47 (9.94) vs. 22.00 (11.94) Immediately postintervention: 9.18 (11.11) vs. 10.35 (11.20) vs. 8.59 (7.87) 10 minutes postintervention: 7.76 (9.55) vs. 7.76 (9.55) vs. 7.06 (7.08) 20 minutes postintervention: 3.06 (5.44) vs. 3.06 (5.44) vs. 3.76 (4.40) General behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Aromatherapy
Yang, 2015^67^ RCT Taiwan Aroma-acupressure vs. aromatherapy vs. treatment as usual n=186 Moderate risk of bias | Treatment: aroma-acupressure (5 acupuncture points pressed for two minutes each with 2.5% lavender oil) Comparison 1: aromatherapy (2.5% lavender oil applied to same 5 points without pressing) Comparison 2: treatment as usual (usual daily care routine, not otherwise specified); - 1 15-minute session (5 points pressed for 2 minutes, plus 5-minute warmup exercise) per day, 5 days per week over 4 weeks; - research assistant, unclear who performed interventions | Agitation/Aggression CMAI, Mean(SD) Postintervention: 43.24(10.00) vs. 41.08(8.24) vs. 41.72 (5.08) 3-week postintervention: 51.21(11.95) vs. 39.80 (7.27) vs. 42.13(5.53); significant decline of treatment effects in aroma-acupressure group (p-value NR) Unclear if significance tested between-group differences. General behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: None Neuroleptic Use: NR
Fu, 2013^64^ RCT Australia Lavender vs. placebo water spray n = 45 (in these two arms) Moderate risk of bias | Treatment: Lavender treatments Comparison: water treatments; - twice/day (morning and afternoon) 7 days/week for 6 weeks; - researcher, trained research assistants | Agitation/Aggression CMAI – aggressive behaviors No overall results reported; no statistically significant difference between groups on individual behaviors reported. General behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Burns, 2011^68^ RCT United Kingdom Active aromatherapy + placebo medication vs. placebo aromatherapy + active medication vs. placebo aromatherapy + placebo medication n=114 Moderate risk of bias | Treatment: Melissa essential oil (200mg dose) + placebo medication Comparison 1: Placebo aromatherapy (sunflower oil) + donepezil (5mg daily for 1 month, then increased to 10mg daily) Comparison 2: Placebos; - aromatherapy/placebo administered twice daily for 1-2 minutes; medication/placebo administered daily; study length was 3 months; - research nurse, caregivers | Agitation/Aggression PAS, median(95% CI) change from baseline 12-week postintervention: -0.7 (-1.7, 0) vs. 0 (-1.7, 0.3) vs. -0.7 (-1.7, 0); p=0.56 General behavior NPI, mean(95% CI) change from baseline at 12-week postintervention: −7.2 (–12.6, −1.7) vs. −2.0 (–7.2, 3.2) vs. −10.0 (–17.2, −3.0); p=0.52 Patient Distress, QoL Blau QoL, mean(97% CI) change from baseline at 12-week postintervention: 17 (–13, 47) vs. −39 (–63, 15) vs. −2 (–34, 30); donepezil group significantly decreased in QoL compared with aromatherapy group (p=0.033) Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Fujii, 2008^65^ RCT Japan Lavender aromatherapy vs. no treatment n = 28 Moderate risk of bias | Treatment: Lavender aromatherapy applied to clothing of the patients Comparison: No treatment; - 3 times/day 1 hour after meals for 4 weeks; - care staff, trained nurse | Agitation/Aggression: NR General Behavior NPI, mean (SD) Baseline: 31 (10) vs. 32 (11) Postintervention: 18 (12) vs. 27 (12) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Lin, 2007^66^ RCT-Crossover Hong Kong Lavender vs. sunflower aromatherapy n = 70 Moderate risk of bias | Treatment: Two drops of the treatment were placed on each side of the pillow of the participant during sleep at night; participants crossed over to the other treatment after a 2 week washout period Comparison: sunflower oil; - 6 weeks (+2 week washout); - care home staff | Agitation/Aggression C-CMAI, mean (SD) Baseline: 63.17 (17.81) vs. 63.94 (SD 17.67) Postintervention: 58.77 (16.74) vs. 63.90 (17.73) General Behavior CNPI, mean (SD) Baseline: 24.68 (10.54) vs. 24.33 (10.08) Postintervention: 17.77 (7.52) vs. 24.41 (10.24) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Ballard, 2002^35^ RCT United Kingdom Melissa essential oil vs. sunflower oil n = 72 Moderate risk of bias | Treatment: Melissa essential oil was combined with a base lotion and applied to patients' faces and arms Comparison: sunflower oil; - twice/day for 4 weeks; - care assistant | Agitation/Aggression CMAI, Proportion making 30% decrease in score Postintervention: 60% vs. 14%, χ^2^=16.3; p<.0001 CMAI, median change Postintervention: -22.0 vs. -6.5; Z=4.1; p<.0001 General Behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: Prescribed additional psychotropic drugs during the study: 6% vs. 8%
Light
Burns, 2009^70^ RCT United Kingdom Bright light vs. standard light n = 48 Moderate risk of bias | Treatment: Bright light Comparison: Standard light; - 2 hours of exposure daily over 2 weeks; - nurse | Agitation/Aggression CMAI, mean (SD) Baseline: 62.0 (18.4) vs. 57.5 (13.8) Week 4: 51.8 (22.8) vs. 50.9 (15.6) Week 8: 49.5 (SD 13.8) vs. 49.5 (SD 10.4) General Behavior Crichton Royal Behavior Rating, mean (SD) Baseline: 34.2 (6.5) vs. 35.6 (7.6) Week 4: 41.3 (2.9) vs. 42.8 (1.4) Week 8: 43.8 (3.4) vs. 44.2 (2.5) MOUSEPAD, mean (SD) Baseline: 13.5 (11.6) vs. 13.4 (8.8) Week 4: 7.8 (7.9) vs. 7.8 (SD 4.3) Week 8: 8.0 (7.8) vs. 7.7 (3.7) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Dowling, 2007^71^ RCT United States Morning light vs. afternoon light vs. control n = 70 Moderate risk of bias | Treatment 1: Morning bright light with usual activities Treatment 2: Afternoon bright light with usual activities Comparison: usual activities with normal indoor light; activities not described; - 1 hour per day on Mondays-Fridays for 10 weeks; - research staff | Agitation/Aggression NPI Agitation/aggression, mean (SD) Baseline: 5.3 (3.5) vs. 3.7 (2.4) vs. 5.8 (3.4) Postintervention: 5.5 (3.3) vs. 4.8 (2.6) vs. 4.3 (2.5) General Behavior NPI, mean (SD) Baseline: 29.4 (20.7) vs. 27.0 (15.7) vs. 24.1 (15.8) Postintervention: 26.3 (13.9) vs. 27.5 (16.5) vs. 19.6 (10.8) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Ancoli-Israel, 2003^69^ RCT United States Morning bright light vs. evening bright light vs. dim light n = 92 Moderate risk of bias | Treatment 1: Morning bright light Treatment 2: Evening bright light Comparison: morning exposure to dim red light; - 2 hours daily for 10 days; - research staff | Agitation/Aggression CMAI Data not provided; text reports no overall difference among treatment groups (F_16,453_=0.99; p=0.46) ABRS Verbal Agitation-morning, mean (SD) Baseline: 0.19 (0.53) vs. 0.34 (0.71) vs. 0.18 (0.55) Days 6-10: 0.22 (0.59) vs. 0.20 (0.56) vs. 0.12 (0.47) Postintervention: 0.12 (0.45) vs. 0.20 (0.53) vs. 0.10 (0.40) Agitation-ABRS Verbal Agitation-evening, mean (SD) Baseline: 0.23 (0.59) vs. 0.27 (0.63) vs. 0.26 (0.59) Days 6-10: 0.27 (0.64) vs. 0.33 (0.68) vs. 0.16 (0.52) Postintervention: 0.25 (0.60) vs. 0.29 (0.67) vs. 0.18 (0.53) General Behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Lyketsos, 1999^72^ RCT-Crossover United States Bright light vs. dim blinking light n = 15 Moderate risk of bias | Treatment: Bright light; 1 week washout then cross-over Comparison: dim, blinking light; - 1 hour every morning for 8 weeks (+ 1 week washout); - nursing staff | Agitation/Aggression Behave-AD Aggression subscale No significant differences, did not present data (p>0.05) General Behavior Behave-AD, mean (SD) Baseline: 14.9 (3.83) vs. 13.7 (3.49) Week 4: 12.6 (SD 4.79) vs. 10.7 (4.85) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Massage
Moyle, 2014^76^ RCT Australia Foot massage vs. attention control n=55 Moderate risk of bias | Treatment: 10-minute foot massage; light pressure with unscented lotion. Crossover. Comparison: attention control – quiet presence (no talking or touching); - 4 hours (1-5pm) Monday-Friday for 3 weeks, 3 week washout, then 3 weeks of crossover treatment (9 weeks total); - research assistants (trained massage therapists) | Agitation/Aggression CMAI, Mean(SD)– p-values reported for between group differences at baseline only Total postintervention: 27.76 (9.63) vs. 36.07 (9.72) Physical non-aggression postintervention: 10.08 (5.01) vs. 12.25 (4.52) Physical aggression postintervention: 5.36 (3.07) vs. 6.43 (3.50) Verbal nonaggression postintervention: 6.40 (3.44) vs. 9.57 (3.82) Verbal aggression postintervention: 5.92 (2.81) vs. 7.82 (3.76) General behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Rodriguez-Mansilla, 2013^75^ RCT Spain Massage therapy vs. no treatment control n = 71 Moderate risk of bias | Treatment: received back and lower limb massages Comparison: no treatment; - 20 minute Monday-Friday for 3 months; - physiotherapist, certified acupuncturist | Agitation/Aggression: NR General Behavior Behavior alterations 3 months: 34/36 vs. 0/35 5 months: 28/35 vs. 32/36 Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Remington, 2002^61^ RCT United States Hand massage vs. no treatment n = 34 (for these two groups) Moderate risk of bias | Treatment: taped calming music played from a CD player Comparison: No treatment; - 1 10-minute session; - trained research assistant | Agitation/Aggression CMAI, mean (SD) Baseline: 16.47 (9.94) vs. 21.76 (9.09) Postintervention: 10.35 (11.20) vs. 21.88 (10.38) 10 minutes postintervention: 7.76 (9.55) vs. 20.88 (8.66) 20 minutes postintervention: 3.06 (5.44) vs. 20.47 (10.90) General Behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Tailored vs. Nontailored Activity
Van Haitsma, 2015^77^ RCT United States Tailored-activity vs. attention control vs. treatment as usual n=180 Moderate risk of bias | Treatment: preference-based activity; one-to-one activity tailored to patients' preferences and abilities; preferences measured by Preferences for Everyday Living Inventory-Nursing Home questionnaire. Activities included exercise, music, reminiscence, snacks, etc. Comparison 1: attention control – one-to-one standard activity (reading magazine, conversing, etc.) Comparison 2: treatment as usual; - approximately 6 10-minute sessions, 3 days per week, over 3 weeks; - certified nursing assistants | Agitation/Aggression Nonverbal Behavior Observations-Aggression, Mean (SE) Postintervention: 0.061 (0.04) vs. 0.117 (0.04) vs. 0.0 (0.02); aggression was significantly lower in usual care compared with attention control (p<0.01), all other comparisons between groups NS General behavior Nonverbal Behavior Observations-General restlessness, Mean (SE) Postintervention: 6.50 (5.66) vs. 5.28 (5.56) vs. 23.47 (3.60); significantly more restless behaviors observed in usual care compared with attention control of intervention (p<0.01), no difference between attention control and intervention groups Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Van der Ploeg, 2013^78^ RCT – Crossover Australia Montessori activities vs. nonpersonalized activity n=44 Moderate risk of bias | Treatment: personalized one-on-one interactions using Montessori based activities Comparison: nonpersonalized activity; - 4 weeks: 30 minute sessions twice weekly; crossover occurred after 2 weeks; - performed by family members | Agitation/Aggression Target behavior present per minute, mean (SD) Baseline: 16.7 (9.9) vs. 17.1 (9.8) During intervention: 8.4 (9.9) vs.10.0 (10.4) Postintervention: 17.6 (10.3) vs. 17.0 (9.4) General Behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Cohen-Mansfield, 2012^79^ RCT United States TREA vs. Staff Training n=125 Moderate risk of bias | Treatment: TREA (Treatment Routes for Exploring Agitation) designed to meet needs based on resident needs, interests, and preferences Comparison: staff training on behavior only; - 2 weeks; - care staff, research assistants, physician | Agitation/Aggression ABMI, mean (SD) Baseline: 8.76 (5.61) vs. 7.16 (7.61) Postintervention: 2.08 (2.68) vs. 7.92 (9.09) 2-way repeated measures ANCOVA shows reduction larger with TREA General Behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Kovach, 2004^80^ RCT United States BACE vs. comparison n=78 Moderate risk of bias | Treatment: BACE (Balancing Arousal Controls Excesses) controls the daily activity schedule so there is a balance between the time a person is in a high-arousal and a low-arousal state; consists of 3 phases: phase 1 is to make an assessment; phase 2 is to diagnose and plan a correction of the arousal imbalance; phase 3 is to implement a new activity schedule. Comparison: NR; - total duration unclear; activities performed in 1-week blocks; - research assistants, geriatric nurse practitioner, staff nurses | Agitation/Aggression Visual Analog Scale (0-100 based upon observation), mean (SD) Baseline: 38.97 (20.54) vs. 32.59 (21.66) Postintervention: 30.54 (15.31) vs. 32.25 (20.16) (Pretest to Postintervention * group: F_1,69_=4.26; p=0.43) General Behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Tailored Activities vs. Tailored Activities
Kolanowski, 2005^82^ RCT – Crossover United States Skill based vs. Interest based vs. Skill and Interest based n=30 Moderate risk of bias | Treatment 1: activities tailored to skill level only Treatment 2: activities tailored to style of interest only Treatment 3: combination of both tailor activities. Comparison: participants served as own controls in crossover design; no specific comparison condition; - up to 20 minutes per day for 12 consecutive days, with a 2-day washout period between treatments.; - trained research assistants | Agitation/Aggression CMAI, mean (CI) Baseline: 2.85 (2.0-3.7) Postintervention: 1.35 (0.5-2.2) vs. 1.09 (0.3-1.9) vs. 1.14 (0.3-4.0) General Behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Kolanowski, 2011^81^ RCT United States Functional level vs. personality style of interest vs. both vs. interactive control n=128 Moderate risk of bias | Treatment 1: Functional group - activities tailored to skill level but opposite their personality style of interest; activities tailored to skill level and functionally challenging. Treatment 2: Personality group - activities tailored to be functionally challenging for them; activities tailored to skill level and functionally challenging. Comparison: Interactive control - activities that were functionally challenging and opposite their personality.; - up to 20 minutes twice per day (morning and afternoon) 5 days each week for 3 consecutive weeks; - nursing staff, research assistants | Agitation/Aggression CMAI, Least Square means (95% CI): Baseline: 1.62 (0.9-2.4) vs. 2.46 (1.7-3.2) vs. 1.86 (1.1-2.6) vs. 1.88 (1.1-2.6) Postintervention: 1.2 (0.3-2.0) vs.1.7 (0.9-2.5) vs.1.5 (0.6-2.3) vs.1.10 (0.3-1.9) General Behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Therapeutic Touch
Hawranik, 2008^74^ RCT Canada Therapeutic touch vs. simulated touch vs. usual care n = 51 Moderate risk of bias | Treatment: Therapeutic touch Comparison: Simulated therapeutic touch Comparison 2: No additional treatment; - 1 session of 30-40 minutes/day for 5 days; - therapeutic touch practitioners | Agitation/Aggression CMAI-Physical aggression (# behaviors), mean (SD) Baseline: 0.94 (0.83) vs. 0.75 (0.77) vs. 0.78 (0.81) Day 5: 0.18 (0.39) vs. 0.13 (0.34) vs. 0.11 (0.32) 2-week postintervention: 0.65 (0.70) vs. 0.38 (0.62) vs. 0.28 (0.57) Agitation – Physical nonaggression (# behaviors), mean (SD) Baseline: 1.4 (0.71) vs. 1.18 (0.83) vs. 1.39 (1.1) Day 5: 0.29 (0.69) vs. 0.25 (0.45) vs. 0.67 (0.91) 2-week postintervention: 1.24 (0.83) vs. 0.63 (0.81) vs. 0.83 (0.79) Agitation – Verbal agitation (# behaviors), mean (SD) Baseline: 1.88 (1.45) vs. 1.69 (1.25) vs. 2.33 (1.53) Day 5: 0.35 (0.70) vs. 0.38 (0.89) vs. 0.89 (0.96) 2-week postintervention: 0.88 (0.86) vs. 1.50 (1.59) vs. 01.33 (1.24) General Behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Woods, 2005^73^ RCT United States Therapeutic touch vs. placebo therapeutic touch vs. usual care n = 57 Moderate risk of bias | Treatment: Therapeutic touch Comparison: placebo therapeutic touch; - twice daily for 5-7 minutes each session for 3 days; - therapeutic touch practitioner | Agitation/Aggression: NR General Behavior Modified ABRS, mean (SD) Baseline: 1.55 (1.03) vs. 1.64 (1.87) vs. 1.53 (0.99) Postintervention: 1.03 (0.67) vs. 1.24 (1.26) vs. 1.48 (1.12) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Exercise
Telenius, 2015^83^ RCT Norway High-intensity exercise vs. attention control n=170 Moderate risk of bias | Treatment: intensive strength and balance exercises (warm-up, 2 lower body exercises, 2 balance exercises, 12-repetitions per exercise for strengthening exercises) performed in small groups of 3-6 participants Comparison: attention control - leisure activities (light physical activity, reading, games, listening to music, conversation); - twice weekly 50-60-minute sessions for 12 weeks; - physiotherapists, occupational therapists, nursing staff, volunteers, activity leaders | Agitation/Aggression: NR General behavior NPI-Q, Mean(SD) Total postintervention: 5.1 (6.0) vs. 5.4 (6.5); p=0.17 Agitation postintervention: 1.5 (2.2) vs. 1.7 (2.3); p=0.07 – change from baseline agitation significantly lower in intervention group Patient Distress, QoL QUALID, Mean(SD) Postintervention: 17.1 (7.0) vs. 17.4 (6.6); p=0.97 Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Rolland, 2007^84^ RCT France Exercise vs. Usual care n = 134 Moderate risk of bias | Treatment: The group exercise intervention consisted of aerobic, strength, flexibility, and balance training Comparison: Routine medical care; - twice weekly for 1 hour per session for 12 months (88 sessions total proposed to each subject); - research staff, occupational therapist | Agitation/Aggression: NR General Behavior NPI, mean (SD) Baseline: 10.7 (6.9) vs. 11.4 (7.7) 6 months: 8.2 (SD 8.0) vs. 9.2 (8.3) Postintervention: 8.3 (SD 8.9) vs. 8.9 (10.4) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: There were no significant group differences during the 12 months between the exercise program group and the routine medical care group in observed total number of falls (139 vs. 136), fractures (5 vs. 2), or deaths (7 vs. 8) Neuroleptic Use: NR
Unique Comparisons
Hutson, 2014^85^ RCT United Kingdom Sonas vs. treatment as usual n=39 Moderate risk of bias | Treatment: Sonas intervention to enhance communication through engagement in multisensory stimulation (listen to music, taste and smell food, looking at interesting items to reminisce, moving in stretches and light exercise, receive massages; singing and dancing invited) Comparison: engaged in usual activities (not further described); - 14 45-minute sessions over 7-8 weeks; - care home staff trained in Sonas delivery | Agitation/Aggression: NR General behavior NPI-Q, Mean(SD) Behavior - overall score, postintervention: 14.68 (16.38) vs. 9.31 (13.26) Behavior - severity, postintervention: 8.25 (6.09) vs.7.06 (4.91) Behavior - distress, postintervention: 7.72 (7.31) vs.4.38 (5.77) Patient Distress, QoL QoL-AD, Mean(SD) Postintervention: 32.26 (4.64) vs. 32.91 7.37) Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Maseda, 2014^86^ RCT Spain Multisensory stimulation room vs. individualized activities vs. control n=32 Moderate risk of bias | Treatment: Multisensory stimulation room of nondirective stimulation and one-on-one time with therapist; included fiber-optic cables, water columns, vibrating water bed, mirror, video, music, aroma therapy, etc. Comparison 1: Directive, one-to-one individualized activity sessions to stimulate intellectually and physically (cards, quizzes, photograph viewing, etc.) Comparison 2: Treatment as usual (cognitive stimulation group sessions, activities for daily living training); - 2 30-minute weekly sessions over 16 weeks; - psychologist, occupational therapist | Agitation/Aggression CMAI: Results reported graphically General behavior NPI-NH: Results reported graphically Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Low, 2013^87^ RCT Australia Humor therapy vs. usual care n=398 Moderate risk of bias | Treatment: SMILE intervention used LaughterBosses and ElderClowns to engage residents through laughter and enjoyment; tailored activities to personality, mood, and physical and cognitive abilities (ex. through serenading, jokes, pretend tennis activity, etc.) Comparison: no intervention; - 9-12 weekly sessions; - ElderClown (trained performer experienced in healthcare settings), LaughterBoss (nominated care home staff member who encouraged intervention between ElderClown visits) | Agitation/Aggression CMAI, Mean (variance method NR) Postintervention: 43.4 (19.1) vs. 37.9 (10.0) 6-month postintervention: 42.0 (18.3) vs. 39.0 (11.7) General behavior NPI-NH, Mean (variance method NR) Postintervention: 20.0 (20.3) vs. 19.3 (15.7) 6-month postintervention: 23.2 (22.0) vs. 18.1 (16.8) MOSES, Mean(variance method NR) Postintervention: 17.6 (6.4) vs. 18.2 (6.0) 6-month postintervention: 18.1 (6.1) vs. 18.7 (6.3) Patient Distress, QoL DEMQoL, Mean(variance method NR) Postintervention: 93.7 (13.1) vs. 92.9 (12.7) 6-month postintervention: 92.0 (14.0) vs. 92.5 (15.4) Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Rodriguez-Mansilla, 2013^75^ RCT Spain Massage therapy vs. ear acupuncture n = 75 Moderate risk of bias | Treatment 1: Massage therapy group received 20 minute back and lower limb massages Monday-Friday for 3 months Treatment 2: Ear acupuncture with adhesive herbal seeds, herbal seeds changed out every 15 days Comparison: no treatment; - 3 months; - physiotherapist, certified acupuncturist | Agitation/Aggression: NR General Behavior Behavior alterations 3 months: 34/36 vs. 3/405 months: 28/35 vs. 33/40 Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Lin, 2009^88^ RCT - Crossover Taiwan Acupressure vs. Montessori methods vs. presence n = 133 Moderate risk of bias | Three groups randomized to varying sequences of three conditions below: Treatment 1: Acupressure was applied to the hands in 15 minute sessions Treatment 2: Montessori methods included 45 minute sessions of sensory stimulation, demonstration, extension and conclusion for the following tasks: scooping, pouring, squeezing, fine motor skills, environmental care, and personal care Comparison: Presence consisted of companionship and conversation in 15 minute sessions; - each treatment was received once/day 6 days/week for 4 weeks, and between each intervention period, there was 1 week of posttesting, 2 weeks of washout, and 1 week of pretesting before the next intervention; - research team, Chinese medicine physician | Agitation/Aggression CMAI, beta(SE) -2.113 (0.609) vs. -2.318 (0.610) vs. NR General Behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Ito, 2007^89^ Japan RCT Group reminiscence (GR) vs. Social contact (SC) vs. comparison n=60 Moderate risk of bias | Treatment 1: Group reminiscence approach and reality orientation was given once a week for 3 months to the subjects in the GR arm. Treatment 2: In the SC arm, a 1-hour session of reality orientation and conversation between participants took place in the same manner. Comparison: Only supportive care; - 3 months; - care provider, psychologist, speech therapists, occupational therapists, medical social workers, nurse | Agitation/Aggression: NR General behavior MOSES, mean (SD) Baseline: 78.8 (20.8) vs. 76.6 (22.2) vs. 75.9 (17.1) Postintervention: 78.1 (26.0) vs. 75.1 (16.6) vs. 75.9 (19.0) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Lichtenberg, 2005^90^ RCT United States Pleasant events vs. usual care n = 20 Moderate risk of bias | Treatment: Pleasant events as instructed by The Pleasant Events Schedule for Alzheimer's disease; additional personalized activities for patients as suggested by nursing assistants Comparison: Usual care activity programming (not otherwise specified); - 3 times per week for 20 to 30 minutes over three months; - trained nursing assistant | Agitation/Aggression: NR General Behavior BEHAVE-AD, mean (SD) Baseline: 1.9 (0.69) vs. 1.4 (0.78) Postintervention: 1.3 (0.30) vs. 2.2 (0.32) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Baker, 2003^44^ RCT United Kingdom, Netherlands, and Sweden. Multisensory stimulation (MSS) vs. Comparison n=136 Moderate risk of bias NOTE: Because of low numbers in Sweden (only three participants in the MSS group), ANOVAs were carried out on UK and Netherlands data only. | Treatment: The key elements of MSS were to place emphasis on all the senses (except taste).; - Light and sound effects were used, as well as materials for touching and smelling.; - Light effects included bubble tubes, fiber-optic sprays, and moving shapes beamed across the walls.; - Sound effects included ‘new age’ or pseudo-classical music, which did not distract individuals from exploring other stimuli as familiar music would.; - Tactile stimulation used satin, cotton wool, shells, etc.; - Tactile boards made up, used different textures such as rough/smooth, warm/cold, and hard/soft.; - Sense of smell was stimulated using aromatherapy and lavender bags, etc.; Comparison: engaged in activities like playing card, games, looking at photographs, doing quizzes, etc.; - 8 30-minute sessions over 4 weeks.; - nursing staff, occupational therapists, psychology assistants | Agitation/Aggression: NR General behavior BRS, mean(SD) [underlined: UK:] (n=492) Baseline: 15.8 (4.6) vs. 16.8 (5.1) Postintervention: 16.8 (4.8) vs. 17.6 (5.6) [underlined: NETHERLANDS:] Baseline: 16 (5.5) vs. 19.6 (6.4) Postintervention: 17 (5.6) vs. 20.4 (3.7) REHAB, mean (SD) [underlined: UK] (n=87) Baseline: 50.1 (30.0) vs. 55.3 (25.9) Mid-trial:49.7 (29.5) vs. 55.4 (25.5) Postintervention: 49.9 (29.3) vs. 58.6 (27.0) Postintervention: 54.2 (30.0) vs. 61.3 (28.2) BMD (total score), mean (SD) [underlined: UK] (n=83) Baseline: 56.4 (13.4) vs. 55.9 (16.6) Mid-trial:52.6 (14.4) vs. 55.1 (19.4) Postintervention: 53.4 (13.9) vs. 55.2 (19.7) Postintervention: 55.3 (16.4) vs. 55.5 (18.2) GIP (total score), mean (SD) [underlined: NETHERLANDS ONLY] (n=26) Baseline: : 44.6 (10.1) vs. 53.6 (11.4) Postintervention: 46.2 (12.5) vs. 56.3 (12.6) Postintervention: 48.2 (13.6) vs. 59.6 (10.8) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Beck, 2002^91^ RCT United States Activities of daily living intervention (ADL) vs. psychosocial activity (PSA) intervention vs. ADL and PSA combined intervention vs. placebo vs. no intervention n = 127 Moderate risk of bias | Treatment 1: ADL intervention: 45-60 minutes per day, PNAs used this intervention during bathing, grooming, dressing, and the noon meal, using strategies to complete an ADL by addressing specific cognitive deficits, using standard strategies of behaviors and communications techniques, and problem-oriented strategies to address particular disabilities Treatment 2: PSA intervention: 25 standardized yet tailored modules containing 5 psychosocial content areas and five sensory modalities, 15-30+ minutes per day Treatment 3: Combined intervention: 90+ minutes per day consisting of both the ADL and the PSA interventions Comparison 1: Placebo control - one on one interaction with PNA doing activities that the participant chose, 30 minutes/day Comparison 2: Usual care with no scheduled contact; - 12 weeks of intervention (first 3 weeks considered baseline, 7 weeks of intervention, and 2 weeks of post-intervention); - professional nursing assistant | Agitation/Aggression DBS Physically Aggressive, mean (SD) Baseline: 20.67 (30.52) vs. 85.87 (199.01) vs. 68.84 (126.18) vs. 49.26 (90.24) vs. 114.66 (202.89) Postintervention: 15.02 (26.10) vs. 82.82 (166.93) vs. 61.04 (127.78) vs. 59.67 (106.37) vs. 77.98 (173.15) 1-month postintervention: 44.18 (100.62) vs. 113.49 (235.71) vs. 92.68 (205.52) vs. 76.79 (165.45) vs. 130.92 (257.12) 2-month postintervention: 21.45 (SD 36.47) vs. 81.30 (SD 151.85) vs. 60.40 (SD 131.54) vs. 48.25 (SD 101.34) vs. 128.20 (SD 195.67) DBS Vocally aggressive, mean (SD) Baseline: 22.85 (32.10) vs. 49.64 (93.15) vs. 34.49 (55.91) vs. 47.20 (79.70) vs. 55.16 (74.70) Postintervention: 21.15 (26.54) vs. 37.90 (53.43) vs. 31.18 (33.85) vs. 32.69 (55.77) vs. 33.26 (47.06) 1-month postintervention: 30.72 (48.95) vs. 54.47 (90.33) vs. 36.95 (42.70) vs. 29.30 (47.60) vs. 64.72 (77.89) 2-month postintervention: 18.28 (24.55) vs. 40.26 (45.26) vs. 32.82 (51.32) vs. 30.18 (52.85) vs. 28.09 (37.02) DBS Vocally agitated, mean (SD) Baseline: 33.49 (84.39) vs. 46.92 (98.70) vs. 62.49 (98.97) vs. 50.10 (92.05) vs. 47.65 (97.22) Postintervention: 43.17 (72.10) vs. 52.50 (90.78) vs. 69.08 (107.29) vs. 48.59 (72.20) vs. 68.01 (116.62) 1-month postintervention: 43.48 (64.39) vs. 68.22 (98.89) vs. 82.14 (118.97) vs. 63.74 (95.30) vs. 84.50 (112.48) 2-month postintervention: 50.53 (117.95) vs. 48.89 (92.33) vs. 75.80 (129.67) vs. 54.11 (80.61) vs. 73.07 (117.12) General Behavior DBS Total, mean (SD) Baseline: 172.51 (191.47) vs. 348.02 (467.50) vs. 287.66 (373.73) vs. 325.96 (337.14) vs. 408.71 (427.24) Postintervention: 164.56 (154.95) vs. 303.24 (367.54) vs. 286.21 (365.78) vs. 336.80 (366.55) vs. 281.97 (410.85) 1-month postintervention: 207.22 (205.58) vs. 373.17 (533.05) vs. 374.10 (510.10) vs. 389.92 (434.43) vs. 418.31 (630.58) 2-month postintervention: 190.70 (291.06) vs. 300.20 (366.42) vs. 312.83 (433.18) vs. 319.15 (384.59) vs. 292.85 (405.15) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Family Involvement in Care or Activity
Camberg, 1999^92^ RCT - Crossover United States Simpres vs. placebo vs. usual care n=54 Moderate risk of bias | Treatment: Simpres audio tape was designed as a personalized interactive tape made by a family member; best loved memories of the dementia residents identified through assessment process and introduced to patient in a telephone conversation format using a continuous play audio tape system. Comparison 1: The placebo audio tape was a recording of a person reading emotionally neutral newspaper. Comparison 2: Usual care included the routine interventions nursing home staff used for behavior management e.g., staff interactions, redirection, or physical restraints.; - 17 days of treatment and a 10-day washout period following each treatment.; - nursing home staff, family members | Agitation/Aggression SCMAI Total frequency of agitated behaviors under each treatment condition (variance NR): Simpres: 25.5 vs. 27.1 vs. 25.1 General Behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
McCallion, 1999^93^ RCT United States Family Involvement vs. usual care n=66 Moderate risk of bias | Treatment: FVEP (Family Visit Education Program) was aimed at improving the quality of interaction between family members and nursing home residents; trainer observed the family member and resident interacting for 20-30 minutes and then provided an additional 15 minutes of feedback about the observations in a family meeting room (after the family member had completed his/her visit). Comparison: Participants in the usual care condition continued to engage in the usual social and recreational programming offered by each nursing facility.; - delivered over 8 weeks and included 4 1.5-hour group sessions and 3 1-hour family conferences; - trainer | Agitation/Aggression CMAI- Physically aggressive, observant, mean (SD) Baseline: 0.0 (0.0) vs. 0.0 (0.0) 3-month: 0.3 (1.5) vs. 0.0 (0.0) 6-month: 0.0 (0.2) vs. 0.0 (0.0) CMAI- Physically nonaggressive, observant, mean (SD) Baseline: 0.5 (1.4) vs. 0.3 (1.2) 3-month: 1.4 (4.4) vs. 1.1 (6.0) 6-month: 0.2 (0.5) vs. 0.3 (1.9) CMAI- verbally agitated, observant, mean (SD) Baseline: 1.7 (3.2) vs. 0.5 (1.2) 3-month: 1.9 (3.8) vs. 0.9 (2.0) 6-month: 0.5 (1.2) vs. 0.8 (2.8) CMAI- Physically aggressive, nurse, mean (SD) Baseline: 12.5 (7.1) vs. 10.6 (4.6) 3-month: 11.7 (6.1) vs. 9.7 (3.2) 6-month: 12.1 (6.9) vs. 10.1 (3.6) CMAI- Physically nonaggressive, nurse, mean (SD) Baseline: 14.3 (7.6) vs. 10.6 (5.6) 3-month: 12.5 (7.2) vs. 10.6 (5.2) 6-month: 11.4 (7.4) vs. 12.9 (6.2) CMAI- verbally agitated, nurse, mean (SD) Baseline: 10.6 (9.6) vs. 11.6 (7.7) 3-month: 13.9 (8.6) vs. 10.6 (7.5) 6-month: 12.7 (7.1) vs. 10.7 (7.0) General Behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Hozumi, 1996^94^ Japan RCT Electro-stimulation vs. placebo n=27 Moderate risk of bias | Treatment: Electro stimulation group had electrodes attached to forehead; the device (HESS-100) delivered repetitive rectangular electric pulses of 6-8V at increasing frequencies from 6-80Hz, each pulse lasting 0.2ms Comparison: Placebo had same electrodes but they were disconnected to actual device; - 20 minutes each morning; - doctor, nurse | Agitation/Aggression Behavior Disorder - Unknown scale, mean (SD) Baseline: 1.20 (1.21) vs. 1.32 (1.23) 2-week postintervention: 0.95 (1.03) vs. 0.98 (1.13) General Behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR
Robichaud, 1994^95^ RCT Canada Sensory integration vs. usual care n = 40 Moderate risk of bias | Treatment: Sensory integration plus structured activities with various materials Comparison: Usual activities (not defined); - sensory integration 3 times/week over 10 weeks; structured activities session of 30-45 minutes; - study author | Agitation/Aggression: NR General Behavior RMBPC, Frequency, mean (SD) Baseline: 1.43 (0.64) vs. 1.11 (0.46) Postintervention: 1.16 (SD 0.43) vs. 1.04 (0.37) RMBPC – Disruptive Behavior, mean (SD) Baseline: 0.91 (0.65) vs. 0.61 (SD 0.38) Postintervention: 0.54 (0.44) vs. 0.49 (0.37) Caregiver Distress RMBPC – Reaction, mean (SD) Baseline: 1.97 (0.87) vs. 1.45 (0.79) Postintervention: 1.21 (0.58) vs. 1.10 (0.60) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Neuroleptic Use: NR

ABMI = Agitation Behavior Mapping Instrument; ABRS = Agitated Behavior Rating Scale; ANCOVA = analysis of covariance; ANOVA = analysis of variance; BACE = Balancing Arousal Controls Excesses; BEHAVE-AD = Behavioral Pathology in Alzheimer's disease; BMD = Behavior and Mood Disturbance; C-CMAI = Cohen-Mansfield Agitation Inventory-Community form; CI = confidence interval; CMAI = Cohen-Mansfield Agitation Inventory; CMAI-SF = Cohen-Mansfield Agitation Inventory-Short Form; CNPI = Checklist of Nonverbal Pain Indicators; DBS = Deep Brain Stimulation; DEMQoL = Dementia Quality of Life measure; FVEP = Family Visit Education Program; GIPB = Geriatric Indices of Positive Behavior; MANOVA = multivariate analysis of variance; MOUSEPAD = Manchester and Oxford Universities Scale for the Psychopathological Assessment of Dementia; MOSES = Multidimensional observation scale for elderly patients; NPI = Neuropsychiatric Inventory; NPI-NH = Neuropsychiatric Inventory-Nursing Home; NPI-Q = Neuropsychiatric Inventory Questionnaire; NR = not reported; NS = not significant; QoL = quality of life; PAS = Pittsburg Agitation Scale; QUALID = Quality of Life in Late-stage Dementia; RCT = randomized controlled trial; REHAB = Rehabilitation Evaluation Hall and Baker tool; RMBPC = Revised Memory and Behavior Problem Checklist; SCMAI = Cohen-Mansfield Agitation Inventory, short form; SD = standard deviation; SE = standard error

#### Music

##### Eligible Trials

We identified six trials with acceptable risk of bias that assessed the efficacy or comparative effectiveness of music interventions on agitation/aggression in nursing homes and/or assisted living facilities.58-63

Four of the trials compared music interventions with usual care, no treatment, and attention controls.58-61 One trial was conducted in Japan, one in Taiwan, one in the United States, and one in Italy. Inclusion criteria varied; most trials required participants to have behavioral symptoms as well as a diagnosis of dementia. Two trials studied music interventions delivered to groups of residents59,60 and two to individuals.58,61 Music intervention sessions varied in length (10 to 30 minutes), frequency (one time, weekly, three times per week) and duration (one time to 6 months). Type and number of staff involved in the intervention also varied.

Sakamoto et al. randomized 39 dementia residents to a music listening intervention (n = 13), an interactive music intervention (n = 13), or a no-music control (n = 13).58 Residents were recruited from four nursing homes in Kobe City, Japan. Inclusion criteria included a diagnosis of dementia according to DSM IV criteria and a severity in the Dementia Rating Scale of 3 or more. Those with hearing disorders, heart disease, hypertension, or diabetes were excluded because of the autonomic nervous system measures being used. Those with a history of playing a musical instrument were also excluded. The mean age of residents randomized to music listening was 79.7 years and most were female (76%). Similar characteristics were observed for the interactive music group (mean age 80.42 years and 85% female) and no-music control (mean age 81.5 years and 85% female). In the music listening intervention, participants listened to CDs; in the interactive music intervention, a music therapist led the group and encouraged them to clap, sing, and/or dance while listening. The comparison group had a staff member sit with the resident for the same amount of time in his or her room with no music. Interventions were delivered for 30 minutes once a week for 10 weeks. Patient agitation/aggression was measured using the Behavioral Pathology in Alzheimer's Disease (BEHAVE-AD) aggressiveness subscale after the tenth intervention and 3 weeks postintervention. Mean BEHAVE-AD scores were similar for the three groups after the tenth intervention and 3 weeks postintervention. General behavior was measured using the Behavioral and Social Symptoms of Dementia (BPSD) scale and the BEHAVE-AD scale; mean scores were similar for the three groups after the tenth intervention and 3 weeks postintervention. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

Lin et al. randomized 100 individuals with dementia in three Taiwan nursing homes to music therapy (n = 49) or a usual care control (n = 51).59 Residents needed to be diagnosed with dementia and to speak Mandarin or Taiwanese. The mean age of residents randomized to the intervention group was 81.46 years and 53 percent were female. Demographic characteristics of residents in the usual care group were similar (mean age 82.15 years and 53% were female). The intervention group received 30-minute sessions twice a week for a total of 12 sessions over 6 weeks. Sessions were led by the study investigators who received training in music therapy. Sessions focused on various musical activities. Examples of musical activities included rhythmical music and slow-tempo instrumental activities, therapeutic singing, and listening to specially selected music. Residents in usual care did not receive music therapy and they continued to engage in normal daily activities. Agitation/aggression was measured using the validated Chinese version of the Cohen-Mansfield Agitation Inventory administered after the sixth and twelfth sessions and at 1 month postintervention. Unadjusted overall mean scores were similar between intervention and control at each time point. The authors also separately analyzed the four behaviors making up the Cohen-Mansfield Agitation Inventory. Unadjusted means were similar between groups at each time point. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

Raglio et al. randomized 60 individuals with dementia residing in five nursing homes near Milan, Italy, to a group music intervention (n = 30) or usual care (n = 30).60 Usual care was not specifically described. Participation required a dementia diagnosis and moderate or high behavioral symptoms. The mean age of residents randomized to the experimental group was 85.4 years and 97 percent were female. The mean age of residents randomized to the control group was 84.6 years and 87 percent were female. The music intervention consisted of three 30-minute music therapy sessions per week for 1 month, alternating with a 1-month washout period for a total of 36 musical therapy sessions over 6 months. Three residents participated in a music session at a time. During music sessions, residents and a music therapist interact and express emotions and behaviors through musical instruments. All residents in the intervention and control group received standard care (e.g., educational and entertainment activities). Agitation/aggression was measured with the NPI agitation subscale at baseline, the end of the intervention, and 1 month after the last washout period. Group differences were not tested and standard deviations were not provided. Postintervention general behavior measured with the global NPI (reported graphically only) was lower in the intervention group (F_1,51_=4.84, p<0.05); statistical testing of postintervention scores was not provided. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

Remington et al. randomized 68 dementia nursing home residents to four arms: calming music (n = 17), hand massage (n = 17), calming music plus hand massage (n = 17), or no treatment (n = 17).61 Residents with dementia who were identified as having agitation/aggression were invited to participate in the study. Mean age of all study participants was 82.4 years and most were female (87%). The comparison of interest for assessing the efficacy of music interventions is that of the 34 residents randomized to music or no treatment. Residents were randomized to treatment immediately prior to receiving the intervention. If the resident did not show signs of agitation (CMAI score = 0) then assignment to treatment was delayed. The music intervention consisted of 10 minutes of calming music (a new age arrangement of Pachelbel's Canon in D) played on a CD player one time. The music was played in patient rooms or family lounge areas at a level slightly higher than background noise, but was low enough to allow for conversation. Agitation/aggression was measured using the CMAI immediately after and at 10, 20, and 60 minutes after the intervention; agitation/aggression decreased more with calming music than with no treatment. At postintervention (60 minutes) residents in the control group exhibited more agitation/aggression than residents in the treatment groups (p <0.05). No intermediate outcomes, secondary outcomes, or adverse effects were reported.

Vink et al. randomized 94 individuals with dementia and behavioral symptoms from six Dutch nursing homes to music (n = 47) or a recreational activity (n = 47).63 The mean age of residents randomized to music therapy was 82.42 years and 67 percent were female. In the recreational activity group, the mean age of residents was 81.76 years and 74 percent were female. The music intervention was delivered by trained music therapists to groups of five residents at a time. The semi-weekly 40-minute music therapies followed a structured protocol in which participation was encouraged. The comparison group received the same amount of group recreational activities facilitated by occupational therapists. Examples of recreational activities include handwork, playing shuffleboard, and playing puzzle games. Agitation/aggression was measured using the modified CMAI 1 hour before sessions, and 1, 2, and 4 hours after sessions. Agitation/aggression postintervention did not differ between residents in the music and recreational activity group. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

Cooke et al. conducted a crossover trial in 47 nursing home residents, comparing a live music intervention (n = 24) with an interactive reading intervention (n = 23).62 The study was conducted in two facilities in Australia. Residents with dementia were required to have a history of agitation/aggression in the past month. Overall mean age of study residents was not reported and most participants were female (70%). The music intervention was led by performing musicians and supplemented by a 10-minute rest period of supplemental recorded music. The musicians selected music based on participant preferences. Residents received 40-minute sessions three times a week for 8 weeks for a total of 24 sessions. Singing, clapping, dancing, or even playing an instrument was encouraged. The comparator was a reading group intervention that included jokes, puzzles, and quizzes. This group was also encouraged to interact with the activities. After the first cycle of interventions, participants crossed over to the other intervention. Agitation/aggression was measured with the Cohen-Mansfield Agitation Inventory short-form and the Rating Anxiety in Dementia scale and was reported at baseline, after the first intervention cycle, and at the end. Agitation/aggression was similar in music and reading groups after the first intervention cycle, before crossover. General behavior was also similar between groups. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

##### Evidence Synthesis and Strength of Evidence Assessment

One trial showed a benefit for agitation/aggression with music compared with no treatment; this trial examined a simple one-time 10-minute recorded calming music in the resident's room and found an improvement in agitation/aggression immediately after and for 10 and 20 minutes after the intervention.61 All other trials showed similar results to control groups. The trial with positive findings differed from the trials with null findings. The three trials with null findings approached music therapy as having a prolonged and sustained effect on agitation/aggression because they measured outcomes at a variety of time points throughout the long-term trial. We could pool results for only two of the three trials, showing no difference in agitation/aggression between intervention and control postintervention (standardized mean difference -0.18; 95% CI: -2.41 to 2.05) (Figure 3). Low strength evidence shows that music interventions are similar to control in decreasing agitation/aggression in dementia over a period of time.

Figure 3 Music therapy versus control (impact of treatment on agitation/aggression)

SMD=Standardized mean difference; CI=confidence interval.

Figure 3 is a forrest plot describing the random effects meta analysis of music therapy versus usual care. Neither trial showed an intervention effect and the pooled estimate showed no difference between treatments in managing agitation/aggression in dementia.

The trial showing a positive relationship between calming music and agitation/aggression treated the intervention as having an immediate effect by measuring the outcome just after the intervention and again within 30 minutes after the intervention.61 This evidence is insufficient to draw conclusions regarding the efficacy of music to immediately decrease agitation/aggression among individuals with dementia.

Neither of the trials that compared music interventions with other interventions showed differences between groups on agitation/aggression. Low strength evidence suggests that music interventions are not more or less effective at decreasing agitation/aggression in dementia compared with interactive comparison interventions. Two trials (n = 125) also reported a general behavior outcomes with conflicting results and evidence insufficient to draw conclusions.58,60

#### Aromatherapy

##### Eligible Trials

Aromatherapy interventions include inhalation or application of scented essential oils. Efficacy studies often used placebo aromas or sprays such as sunflower oil. We identified six trials with acceptable risk of bias that assessed the efficacy of aromatherapy in nursing home residents with agitation/aggression.35,64-68 Four trials studied lavender64-67 and two studied Melissa oil.35,68 Trials were conducted in nursing homes in Australia, Japan, Hong Kong, and the United Kingdom.

Yang et al. randomized 186 residents with severe agitation to aroma-acupressure (n=56), aromatherapy (n=73), or usual care (n=57).67 Mean age of residents was 84 years and 26 percent were female. Participants were diagnosed with Alzheimer's disease (91%), vascular dementia (6%), or other forms of dementia (2%). Participants in the aroma-acupressure group received 15 minutes of treatment at five acupressure points with lavender oil for 5 days a week over 1 month. Participants in the aromatherapy group received treatment with lavender oil for the same amount of time. Usual care was not defined. One primary outcome was assessed (agitation/aggression measured by CMAI) at baseline, postintervention, and 3-week postintervention. CMAI scores were similar at initial postintervention for all groups. At 3-week postintervention, CMAI scores were significantly lower. No secondary and intermediate outcomes were reported. No adverse events were reported.

Fu et al. randomized 67 nursing home residents with dementia and a history of agitation/aggression or aggression from three nursing home and assisted living facilities in Australia to lavender aromatherapy with massage (n = 22), lavender aromatherapy without massage (n = 23), or placebo aromatherapy (water sprays) (n = 22).64 Mean age of residents in the study was 84 years and more than half the participants were female (59%). Aromatherapy treatments were given twice a day, 7 days a week, for 6 weeks. Hand massage was done for 5 minutes (2.5 minutes per hand) twice a day for 10 days. Agitation/aggression measured with the Cohen-Mansfield Agitation Inventory-Short Form was similar across the three groups. Overall scores were not reported; item specific means were analyzed at several time points. Postintervention means were similar across the three groups at all time points. No intermediate or secondary outcomes were reported.

Burns et al. randomized 114 residents with probable or possible Alzheimer's disease to active aromatherapy (Melissa) with placebo psychotropic (n=38), placebo aromatherapy with donepezil (n=37), or both placebos (n=39).68 Participants' mean age was 85 and 60 percent were female. Active and placebo aromatherapy was administered twice daily for 1-2 minutes, and active and placebo psychotropic were administered daily for 3 months. Two scales assessed primary outcomes (agitation/anxiety measured by PAS, general behavior measured by NPI) at baseline and postintervention (3 months). Median change from baseline was similar for both outcomes postintervention. One scale assessed secondary outcomes (patient distress measured by Blau QoL) at baseline and postintervention. Aromatherapy resulted in higher postintervention mean QoL (quality of life) than donepezil. Intermediate outcomes were not reported. Adverse events were not reported.

Fujii et al. randomized 28 dementia residents with behavioral symptoms of one nursing home facility in Japan to lavender aromatherapy (n = 14) or no treatment (n = 14).65 The mean age of participants was 78 years and most were female (68%). Two drops of lavender oil were applied to residents' clothing three times a day approximately 1 hour after meals for 4 weeks. At the end of the intervention (4 weeks), general behavior measured with the NPI was similar with intervention and control. No intermediate or secondary outcomes were reported.

Lin et al. randomized 70 nursing home residents to lavender aromatherapy (n = 35) or sunflower inhalation (n = 35).66 Residents with dementia and significant agitation/aggression were invited to participate in the study. The mean age of all study participants was 78.29 years and 59 percent were female. Half of the study participants were first assigned to aromatherapy for 3 weeks and then switched to control group for another 3 weeks; the other half did the opposite, with a 2-week washout period between treatments. Results are only presented for the time period before the second intervention cycle. Aromatherapy was delivered by diffusing lavender oil for at least 1 hour near the patient's pillow each night. Postintervention agitation/aggression measured with the Chinese version of the Cohen-Mansfield Agitation Inventory and general behavior measured with the Chinese version of the Neuropsychiatric Inventory were similar with intervention and control at the end of the intervention. Psychotropic medication use postintervention did not change or differ between groups. No other intermediate or secondary outcomes were reported.

Ballard et al. randomized 72 nursing home residents in the United Kingdom to 4 weeks of aromatherapy with essential oils (Melissa) (n = 36) or placebo (sunflower oil) (n = 36).35 Residents with dementia and with clinically significant agitation/aggression were invited to participate in the study. The mean age of residents randomized to the intervention group was 77.2 years and 56 percent were female. The mean age of residents randomized to placebo was 79.6 years and 64 percent were female. Aromatherapy was delivered in a lotion applied by staff to patients' faces and arms twice a day. At 4 weeks from baseline residents in the Melissa oil group were significantly more likely than residents in the placebo group to experience a 30 percent reduction in CMAI scores (60% vs. 14%; χ^2^=16.3; p<.0001). The change in the proportion of patients prescribed additional psychotropic drugs was similar with intervention and control. No significant side effects were observed; one patient in the treatment group experienced 2 days of diarrhea.

##### Evidence Synthesis and Strength of Evidence

Only one of six trials showed that aromatherapy improved agitation/aggression compared with inactive controls.35 The trial that showed an aromatherapy effect used the Melissa scent applied to the patient in lotion form by a staff member. Delivery methods in the other trials did not appear to involve touch. However, the other trial using the Melissa scent did not show an effect on behavior. Methodological limitations of the eligible studies and imprecise estimates provide insufficient evidence for the effectiveness of aromatherapy for agitation/aggression in dementia. Low strength evidence suggests that aromatherapy with lavender is not effective in managing agitation/aggression in individuals with dementia. Evidence was insufficient to draw conclusions about the efficacy of Melissa in reducing agitation/aggression in dementia due to conflicting findings in two trials.

#### Bright Light

##### Eligible Trials

Light therapy interventions included some variant of bright light therapy (BLT). Patients were exposed to full spectrum versus active control light (red dim light) or standard light. BLT sessions were typically 1 to 2 hours per day at varying times of the day. We identified four trials that studied the efficacy of light therapy with acceptable risk of bias.69-72 Treatment lasted an average of 2 weeks.

Burns et al. randomized 48 residents in two nursing homes to bright light (n = 22) or standard light (n = 26).70 Both homes specialized in dementia and behavioral disturbances and all participants had dementia, sleep disorders, and a history of agitation/aggression. The mean age of residents randomized to bright light therapy was 84.5 years and 73 percent were female. Characteristics of residents in the standard light group were similar (mean age of 82.5 years and 62% were female). Residents were exposed to treatment during the second and third weeks. Residents in the BLT group were exposed to full spectrum BLT 10,000 lux. Residents in the standard light group were exposed to standard light at 100 lux. In both groups, exposure was for 2 hours daily between 10 a.m. and noon for 2 weeks. During each light therapy (bright light and standard light) a nurse was present and engaged residents in conversation. Agitation/aggression measured with the CMAI and general behavior measured with the Crichton Royal Behavior Rating Scale and MOUSEPAD were similar with BLT and standard light at 4 and 8 weeks. No intermediate or secondary outcomes were reported.

Dowling et al. randomized 70 residents with severe dementia, sleep disorders, and rest-activity disruptions (i.e., agitation/aggression) in two nursing homes in the United States to morning bright light (n = 29), afternoon bright light (n = 24), or usual indoor light (n = 17).71 The mean age of randomized participants was 84 years and 81 percent were female. In the morning bright light group, BLT was administered from 9:30 to 10:30 a.m., and in the afternoon bright light group BLT was administered from 3:30 to 4:30 p.m. In both bright light groups, BLT (>2,500 lux) was administered daily (Monday-Friday) for 10 weeks. Residents in the control group received usual indoor light (150 to 200 lux) and participated in regularly scheduled activities. Outcomes were measured at the end of the baseline week and after the last week of intervention. Agitation/aggression measured with the NPI-NH agitation subscale increased more with morning light group than standard light (t_1,55_ =-2.25, p=0.015) largely because scores in the standard light group decreased. General behavior measured with the NPI-NH overall scores was similar for intervention and control. The authors mention that this subscale change with bright light is likely not clinically meaningful despite its statistical significance. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

Ancoli-Israel et al. randomized 92 residents with dementia from five U.S. nursing homes to morning bright light (n = 30), morning dim red light (n = 31), or evening bright light (n = 31).69 The mean age of study participants was 82.3 years and 68 percent were female. For residents randomized to morning and evening bright light, an Apollo Bright-Light box was placed one meter from the patient for a resulting exposure of 2,500 lux. An eye-level photometer was used to ensure correct light exposure. The inactive control, dim red light, was administered with a red light box resulting in exposure equivalent to typical room light levels (<300 lux). In all groups, residents were exposed to light for 2 hours daily for 10 days. Morning bright light and morning dim red light were administered from 5:30 to 11:30 a.m. Evening bright light was administered from 9:30 to 11:30 p.m. During the administration of light therapy residents could engage in any activity as long as they remained facing the light. Outcomes were assessed and analyzed separately by morning and evening staff. Agitation/aggression measured with the CMAI was similar between the groups and for morning and evening staff assessments. Agitation/aggression was also assessed separately with the Physical and Verbal Agitation ratings from the Agitated Behavior Rating Scale (ABRS). Means were similar between groups. No group differences were reported for morning or evening assessments. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

Lyketsos et al. randomized 15 nursing home residents with dementia and agitation/aggression to bright light or dim light.72 Mean age of study participants was 80.8 years and 93 percent were female. Bright light (10,000 lux full spectrum lamp at 3 feet from patient) was administered daily for 1 hour for 4 weeks followed by 1 week of no treatment prior to being crossed over to the other intervention. During the administration of light therapy residents could engage in any activity as long as they faced the light. Residents in the control group were exposed to a dim, digital, low frequency light. Outcomes were assessed at 2 and 4 weeks after treatment assignment, combined and reported at the patient-intervention level after both groups received both interventions. Agitation/aggression measured with BEHAVE-AD aggression subscale and general behavior measured with BEHAVE-AD global rating was similar with bright light and dim light. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

##### Evidence Synthesis and Strength of Evidence

Four trials assessed the efficacy of BLT to manage agitation/aggression among dementia residents in nursing homes and assisted living facilities.69-72 The four trials measured agitation/aggression with different scales and time points. Of the eight postintervention outcomes reported, only one showed a statistically significant difference between groups. The authors admit that this small change in the instrument is likely not clinically meaningful. Only two trials provided sufficient data for pooling (Figure 4). Bright light therapy had an effect similar to standard light in improving agitation/aggression in individuals with dementia (standardized mean difference=0.09; 95% CI: -0.32 to 0.50). Low strength evidence suggests that bright light therapy is not effective in managing agitation/aggression among nursing home and assisted living facility residents with dementia.

Figure 4 Bright light versus standard light (impact of treatment on agitation/aggression)

SMD = Standardized mean difference; CI = confidence interval

Figure 4 is a forrest plot describing the random effects meta analysis of bright light therapy versus usual care. Neither trial showed an intervention effect and the pooled estimate showed no difference between treatments in managing agitation/aggression in dementia.

#### Therapeutic Touch

##### Eligible Trials

Therapeutic touch refers to transfers of energy without necessarily using actual physical touch. Typically, a practitioner sits next to the patient and places his or her hands on or near the patient to transfer energy. We identified two studies with acceptable risk of bias on therapeutic touch. These include Woods et al.73 and Hawranik et al.74

Hawranik randomized 51 residents with dementia and agitation/aggression from the personal care and special needs unit of a nursing home to therapeutic touch (n = 17), simulated therapeutic touch (n = 16), and usual care (n = 18).74 The mean age of all study participants was 82.8 years and 71 percent were female. Therapeutic touch is based on ancient healing practices and involves practitioners touching the patient or passing hands several inches from the patient. Therapeutic touch was conducted by trained practitioners. Volunteers were recruited to administer the simulated therapeutic touch (i.e., passing hands several inches from the patient). Therapeutic touch and simulated therapeutic touch were each given in 30 to 40 minute sessions once/day for 5 days. At baseline there were no differences in physically aggressive or verbally agitated behaviors between groups as measured by CMAI subscales. From baseline to the end of 5 days of intervention, there were significant differences between the three-treatment groups (therapeutic touch, simulated therapeutic touch, and usual care) (χ^2^ = 5.98, p<0.05). These differences are explained by an increased rate (2.3 times 95% CI 0.66 to 7.81) of physically nonaggressive behaviors (a subscale of the CMAI) in usual care compared with therapeutic touch. However, there were no differences between groups in the CMAI subscales of physically aggressive, physically nonaggressive, or verbally agitated behaviors at 24 hours after the final intervention, 1 week postintervention, or 2 weeks postintervention. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

Woods randomized 57 residents with dementia and behavioral symptoms in the special care units of three Canadian nursing homes to therapeutic touch (n = 19), placebo therapeutic touch (n = 19), or usual care (n = 19).73 The mean age of study participants was 81.04 years and 81 percent were female. Therapeutic touch consisted of a trained therapist providing contact on the neck and shoulders. Residents in the placebo therapeutic touch group received a simulated therapeutic touch (i.e., the treatment resembled therapeutic touch). Therapeutic touch and placebo therapeutic touch were given twice daily (between 10:00 and 11:30 a.m. and between 3:00 and 4:40 p.m.) for 5 to 7 minutes per session for 3 days. Behavioral observation was completed every 20 minutes from 8 a.m. to 6 p.m. for 3 days pre-intervention and for 3 days postintervention by trained observers blinded to group assignment. Mean behavioral symptoms of dementia appear similar across groups postintervention. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

##### Evidence Synthesis and Strength of Evidence

Two trials assessed the efficacy of therapeutic touch to manage agitation/aggression among dementia residents in nursing homes.73,74 The two studies measured agitation/aggression with different scales. One of the studies reported a statistically significant difference between groups.73 This difference was small and is unlikely to be clinically meaningful. Evidence was insufficient to draw conclusions regarding the effectiveness of therapeutic touch for agitation/aggression in dementia.

#### Massage

##### Eligible Trials

We identified three trials testing the efficacy of massage for agitation/aggression in dementia. In two of three trial arms, Remington et al. compared hand massage with no treatment.61 Rodriguez-Mansilla et al. compared back and lower limbs massage by physiotherapists for 20 minutes every day with no treatment in two of three arms.75 Moyle compared foot massage with attention control.76

Moyle et al. randomized 55 residents with moderate- to late-stage dementia to either a foot massage condition (n=26) or attention control (n=29).76 The mean age of participants was 86 years and 64 percent were female. Participants in the intervention received a 10-minute foot massage 5 days a week for 3 weeks; controls received quiet presence for the same amount of time as massage. One scale assessed primary outcomes (agitation/aggression measured by CMAI) at baseline, 3-week postintervention (after completion of first treatment), and 9-week postintervention (after completion of crossover treatment). Postintervention scores were similar between groups. Secondary and intermediate outcomes were not reported. Adverse effects were not reported.

Rodriguez-Mansilla et al. randomized 120 residents with dementia in three Spanish nursing homes to massage (n = 40), ear acupuncture (n = 40), or control (n = 40). The mean age of residents across all three groups was similar (massage = 85.8 years, ear acupuncture = 85.4 years, and control = 81.9 years), and most residents in the study were female (77%). The massage therapy arm is compared with the no treatment arm for efficacy of massage. The massage therapy group received a relaxing 20-minute massage of the back and lower limbs by a physiotherapist 5 days per week over 3 months. A qualified acupuncturist provided ear acupuncture. The acupuncturist applied Shenmen Muscle relaxant located in the peripheral inferior concha, close to the spleen and liver with adhesive herbal seeds of Wangbuliuxing (Semen Vaccariae Segetalis). The seeds were placed with adhesive tape and replaced with new seeds every 15 days for 3 months. The control group received no experimental therapy. General behavior was measured with an investigator-designed instrument asking staff about the number of behavioral alterations. General behavior improved more in the intervention versus control group postintervention and was maintained at 2-months postintervention. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

Remington et al. randomized 68 nursing home residents to four arms: calming music, hand massage, calming music plus hand massage, or no treatment.61 Details of this study are provided in the music intervention versus control section. The three interactive arms are relevant to the comparative effectiveness of massage interventions for agitation/aggression. The music intervention consisted of 10 minutes of calming music played on a CD player one time. The hand massage intervention consisted of 10 minutes of hand massage, 5 minutes per hand. The hand massage/calming music group received both interventions simultaneously. Agitation/aggression was measured with CMAI immediately and at 10 and 20 minutes after the intervention; agitation/aggression reduced similarly in each of the interactive arms. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

##### Evidence Synthesis and Strength of Evidence

Three trials assessed the efficacy of massage to reduce agitation/aggression in dementia in nursing home residents.61,75,76 Remington et al. reported an agitation/aggression outcome;61 Rodriguez-Mansilla et al. and Moyle et al. reported general behavior.75,76 Studies had methodological limitations, inconsistent findings, and estimates were imprecise. Therefore, evidence is insufficient to draw conclusions about the effect of massage on agitation/aggression or general behavior among nursing home residents with dementia.

#### Comparisons Between Tailored and Nontailored Interventions

##### Eligible Trials

We identified four trials with acceptable risk of bias that compared tailored interventions with nontailored interventions.77-80 The interventions varied on the resident characteristics used for tailoring. One tailored the intervention based on patient preferences and abilities,77 one on the Montessori model,78 another on the unmet needs,79 and the fourth on balancing arousal throughout the day according to the patients' response to different activities.80

Van Haitsma et al. randomized 180 dementia residents with moderate to severe dementia to a positive psychology intervention (n=44), attention control comparison (n=43), or usual care (n=93).77 The mean age of residents was 89 years and 82 percent were female. Residents in the intervention received a one-to-one activity that was tailored to their preferences and abilities, such as exercise, music, reminiscence, snacks, and so forth. Residents in the attention control received one-to-one time doing a standard activity, such as reading a magazine or conversing. Usual care was not defined. The intervention was performed by certified nursing assistants in 10-minute sessions, three times weekly over 3 weeks. One scale measured primary outcomes (agitation/aggression and general behavior measured with nonverbal behavior observations) at baseline and postintervention (3 weeks). At postintervention, aggression was significantly lower in usual care compared with intervention or attention control, but intervention and attention control were no different. Adverse effects were not reported.

Van der Ploeg et al. conducted a crossover trial in which 44 dementia residents with agitation/aggression in nine Australian nursing home and/or assisted living facilities were randomized to personalized one-on-one activities according to the Montessori model (n = 15) or nonpersonalized activity (n = 29).78 The mean age of study participants was 78.1 years and 68 percent were female. A single target behavior was selected for each resident based on nurse CMAI ratings of the residents' behavior. Residents randomized to Montessori participated in structured one-on-one activities. Up to 10 activities were selected by trained activity facilitators based on the residents' former interests and hobbies. Examples of activities include singing along to music and arranging flowers. The control condition received nonpersonalized activity. Both groups were exposed to the activity for 30 minutes twice weekly resulting in a total of four sessions over 2 weeks. After 2 weeks, study participants crossed over. Nursing homes committed not to modify psychoactive drugs during the 4-week study period. Agitation/aggression occurred at similar rates during and after the intervention in the intervention and control groups. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

Cohen-Mansfield et al. randomized 125 dementia residents with agitation/aggression in nine Maryland nursing homes to a tailored intervention (n = 89) or placebo control (n = 36). The mean age of study participants was 85.7 years and 74 percent were female. The intervention is referred to as the TREA (Treatment Route for Exploring Agitation) intervention.79 TREA includes making a baseline assessment from multiple sources, hypothesizing unmet needs, and developing an intervention designed to meet resident needs based on interests, preferences, and past identity. A trained research assistant conducted observations and recommended interventions to staff. The control group received general staff training on resident behavior. Agitation/aggression was measured with the Agitation Behavior Mapping Instrument and was analyzed using a two-way repeated-measures analysis of covariance. This showed that agitation/aggression decreased more with intervention [8.76 (5.61) to 2.08 (2.68)] than control [7.16 (7.61) to 7.92 (9.09)]. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

Kovach et al. randomized 78 dementia residents with agitation/aggression from 13 Midwest nursing homes to a tailored intervention (n = 36) or control (n = 42). The mean age of study participants was 87 years and 91 percent were female. The tailored intervention sought to decrease agitation/aggression by manipulating resident daily activities to achieve an optimum balance between states of high and low arousal.80 Research assistants designed the new activity plan during the first assessment and the second planning stage, and the plan was implemented by regular staff for 7 days. Agitation/aggression was measured using a visual analog scale rated from 0–100 by trained observers. Difference in change in scores was similar with intervention or control (Pretest to Posttest * group: F_1,69_=4.26; p=0.43). The difference in the change between groups was not tested. Mean scores postintervention were similar between intervention and usual care, but the intervention group had higher baseline scores. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

##### Evidence Synthesis and Strength of Evidence

Four trials studied tailored activities for agitation/aggression in dementia.77-80 Only one trial showed reduced agitation/aggression with tailored activities compared with nontailored activities79 and one showed higher aggression with intervention compared with usual care.77 These studies had methodologic limitations and imprecise estimates. In addition to the inconsistency, this rendered the evidence insufficient to draw conclusions regarding the effectiveness of tailored activities compared with nontailored activities.

#### Comparisons Between Different Tailored Activity Interventions

##### Eligible Trials

Two trials compared interventions tailored to different resident characteristics.81,82 Both of these trials were conducted by Kolanowski, et al. Studies tested the Needs-Driven, Dementia-Compromised Behavior model, which posits that activities for individuals with BPSD must fit the physical and cognitive functional abilities and personality of the resident.

Kolanowski, et al (2005) conducted a crossover RCT and randomized 33 dementia residents with agitation/aggression to activity based interventions based on skill level only, style of interest only, or skill level and style of interest. The mean age of study participants was 82.3 years and 77 percent were female. Residents randomized to skill level only received activities appropriate to their abilities but opposite to their personalities. Residents randomized to style of interest only received activities appropriate to their abilities but opposite to their personalities. Finally, residents randomized to skill level and style of interest received activities that were appropriate to both. Within each arm, activities were implemented for up to 20 minutes for 12 consecutive days. Agitation/aggression was measured with the CMAI. Postintervention outcomes were reported at the patient-intervention level. Postintervention CMAI was similar among all groups.82 No intermediate outcomes, secondary outcomes, or adverse effects were reported.

Kolanowski, et al (2011) evaluated the Needs-Driven, Dementia-Compromised Behavior model in 128 residents from nine community nursing homes.81 Participants were randomly assigned to activities tailored to functional level (n = 32), activities adjusted to personality style of interest (n = 33), to both (n = 31), or to interactive control (n = 32), who received activities opposite both their skill level and personality style. The mean age of study participants was 86 and 77 percent were female. The activities were provided twice daily for 3 weeks. Agitation/aggression measured with CMAI decreased in all four groups; mean changes and postintervention means were similar across groups. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

##### Evidence Synthesis and Strength of Evidence

Two studies assessed the effect of interventions tailored to different resident characteristics.81,82 Low strength evidence shows that interventions tailored to different patient characteristics have a similar effect on managing agitation/aggression in dementia.

#### Exercise

##### Eligible Trials

Two trials compared exercise.83,84 Telenius et al. randomized 170 residents with mild to moderate dementia to high-intensity exercise (n=87) or attention control (n=83).83 Participants' mean age was 87 and 74 percent were female. Participants in the intervention group performed intense lower body and balance exercises in small groups twice weekly for 3 months. Participants in the attention control performed leisure activities (reading, conversation, music listening) for an equivalent amount of time. One scale assessed primary outcomes (general behavior measured by NPI-Q) at baseline and postintervention (3 months). Change from baseline agitation was significantly lower in the exercise group at postintervention. One scale assessed secondary outcomes (patient distress, QoL measured by QUALID) at baseline and postintervention (3 months). Change from baseline QoL was not significantly different between groups. Intermediate outcomes and adverse effects were not reported.

Rolland et al. randomized 134 residents with mild to severe dementia to a group exercise program (n = 67) or usual care (n = 67).84 The mean age of residents in the group exercise program was 82.8 years and 72 percent were female. The mean age of residents in usual care was 83.1 years and 79 percent were female. Residents in group exercise were placed in groups of three to seven by functional abilities so that their exercises could be tailored to their ability (e.g., walking, strength, balance, and flexibility). Sessions were delivered by a physical therapist for 1 hour twice a week for 12 months. Residents in usual care received routine medical care. Agitation/aggression were assessed at 6 and 12 months using the NPI agitation subscale. At 6 and 12 months there was no difference in agitation/aggression between residents in the group exercise program and usual care. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

##### Evidence Synthesis and Strength of Evidence

Two trials with study limitations and imprecise estimates provided insufficient evidence regarding the effectiveness of this intervention.83,84

#### Multicomponent Intervention

##### Eligible Trial

Hutson et al. randomized 39 residents with a dementia diagnosis or moderate to severe cognitive impairment to a multicomponent intervention (n=21) or usual care (n=18).85 Participants' mean age was 87 and 74 percent were female. Participants in the intervention group received multisensory stimulation (music, food to smell and taste, looking at items to reminiscence, light exercise, massages) in 14 45-minute sessions over 7-8 weeks. Usual care was not defined. One scale measured primary outcomes (general behavior measured by NPI-Q) at baseline and postintervention. Differences between means at postintervention were not reported. One scale measured secondary outcomes (patient distress, QoL measured by QoL-AD) at baseline and postintervention. Differences between means at postintervention were not reported. Intermediate outcomes and adverse effects were not reported.

##### Evidence Synthesis and Strength of Evidence

One trial with study limitations and imprecise estimates provided insufficient evidence regarding the effectiveness of this intervention.

#### Multisensory Stimulation Room

##### Eligible Trial

Maseda et al. randomized 32 residents (diagnoses not reported) to a multisensory stimulation room (n=10), individualized activities (n=10), or usual care (n=10).86 Participants' mean age was 87 years and 90 percent were female. Participants in the intervention group were exposed to a multisensory room (vibrating water bed, mirror, music, aroma therapy, etc.) in twice-weekly 30-minute sessions for 4 months. Participants in the activities group attended individualized activities based on patient preference (cards, quizzes, photo-viewing) for an equivalent amount of time. Usual care was defined as cognitive stimulation and ADL training. Two scales assessed primary outcomes (agitation/aggression measured by CMAI, general behavior measured by NPI-NH) at baseline, postintervention (4 months), and 2-months postintervention. Results were reported graphically. Secondary and intermediate outcomes were not reported. Adverse effects were not reported.

##### Evidence Synthesis and Strength of Evidence

One small trial with study limitations and imprecise estimates provided insufficient evidence regarding the effectiveness of this intervention.

#### Humor Therapy

##### Eligible Trial

Low et al. randomized 398 residents (diagnoses not reported) to humor therapy (n=189) or usual care (n=209).87 Participants' mean age was 85 years and 77 percent were female. Participants in the intervention were provided personalized amusement from a special therapist and a home nurse (e.g., serenading, jokes, funny dress-up) in 9-12 weekly sessions. Usual care was not defined. Three scales assessed primary outcomes (agitation/aggression measured by CMAI, general behavior measured by NPI-NH, and MOSES) at baseline, postintervention (3 months), and 3-months postintervention. Differences between groups were not reported. One scale assessed secondary outcomes (patient distress, QoL measured by DEMQoL) at baseline, postintervention (3 months), and 3-months postintervention. Differences between groups were not reported. Intermediate outcomes and adverse effects were not reported.

##### Evidence Synthesis and Strength of Evidence

One trial with study limitations and imprecise estimates provided insufficient evidence regarding the effectiveness of this intervention.

#### Acupuncture

##### Eligible Trial

Rodriguez-Mansilla et al. randomized 120 nursing home residents from three nursing home and/or assisted living facilities in Spain to massage (n = 40), ear acupuncture (n = 40), or control (n = 40).75 Details of this study are provided in the massage section. We discuss the massage versus no-treatment arms with the other massage trial, and the acupuncture versus no treatment arms here. The ear acupuncture group received application of Shenmen Muscle relaxant located in the peripheral inferior concha, close to the spleen and liver with adhesive herbal seeds of Wangbuliuxing (Semen Vaccariae Segetalis). The techniques were performed by a qualified acupuncturist. The seeds were placed with adhesive tape, and were replaced with new seeds every 15 days. The intervention lasted for 12 weeks. General behavior was measured with an investigator-designed instrument asking staff about the number of behavior alterations (not defined). General behavior improved more in the intervention groups than the control group at postintervention (3 months) (p <0.001) and were maintained at 2 months after completing the treatment (5 months) (p <0.021). No intermediate outcomes, secondary outcomes, or adverse effects were reported.

##### Evidence Synthesis and Strength of Evidence

One trial with study limitations and imprecise estimates provided insufficient evidence for the effectiveness of this intervention.75

#### Massage Versus Ear Acupuncture

##### Eligible Trial

Two arms of one trial previously discussed are used to assess the comparative effectiveness of massage versus ear acupuncture on agitation/aggression. Rodriguez-Mansilla et al.'s trial was previously described.75 General behavior was measured with an investigator-designed instrument asking staff to report the number of behavior alterations (not defined). General behavior improved by a similar amount with either intervention. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

##### Evidence Synthesis and Strength of Evidence

One trial with study limitations and imprecise estimates provided insufficient evidence for the comparative effectiveness of these interventions.

#### Acupressure

##### Eligible Trial

Lin et al randomized 133 individuals with dementia residing in six Taiwanese nursing home special care units to acupressure (n = 42), structured Montessori-based activities (n = 39), or presence (attention control) (n = 52).88 The study used a double-blind crossover design. The mean age of study participants was 80.1 years and 26 percent were female. Acupressure was used to treat agitation/aggression using five acupoints (Fengchi, Baihui, Shenmen, Niguan, and Sanyinjiao). Acupuncture sessions were conducted for 15 minutes once a day, 6 days a week, for 4 weeks. Sessions consisted of warmup activities (5 minutes) and acupressure to each acupoint for 2 minutes. Montessori-based activities consisted of sensory stimulation (e.g., rhythmic music) and activities associated with daily living (e.g., scooping, pouring, and squeezing). This was done 6 days a week for 4 weeks. Attention control consisted of engaging subjects in conversation and attempting to maintain the subject's attention for 15 minutes. This was done 6 days a week for 4 weeks. Groups were defined by the sequence in which they received the intervention and analysis was at the patient-intervention level. Results were reported by group after all patients received all interventions. Agitation/aggression was measured with the CMAI. Mean differences before crossover were not reported for agitation/aggression or any intermediate or secondary outcomes, or adverse effects.

##### Evidence Synthesis and Strength of Evidence

One trial with study limitations and im precise estimates provides insufficient evidence for the effectiveness of this intervention.

#### Reminiscence

##### Eligible Trial

Ito et al. randomized 60 vascular dementia patients residing in three Japanese nursing home facilities to group reminiscence (n = 20), social contact (n = 20), and a control group (n = 20).89 The mean age of study participants was similar across all three arms (mean age in group reminiscence in 82.9 years, social contact 81.9 years, and control 82.1 years). In all three groups there were more woman than men. A team of 10 professionals from psychology, speech therapy, occupational therapy, social work, and nursing were trained to deliver group reminiscence therapy or social contact. Group reminiscence was delivered to four residents at a time and sessions were delivered 1 hour a week for 3 months. Residents in the social contact group (four residents per session) received a 1 hour session of reality orientation. The social contact group also participated in a protocol-based conversation. The control group received supportive care. General behavior, measured using MOSES Multi-dimensional Observation Scale for Elderly Patients, showed no difference between groups after the intervention. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

##### Evidence Synthesis and Strength of Evidence

One trial with study limitations and imprecise estimates provided insufficient evidence regarding the effectiveness of this intervention.

#### Pleasant Experiences

##### Eligible Trial

Lichtenberg et al. randomized 20 residents from two dementia special care units to individually designed pleasant event one-on-one activity (n = 9) or usual care (n = 11).90 The mean age of all residents was 85 years and 90 percent of participants were female. The behavioral treatment was an individually designed pleasant activity delivered by a trained nursing assistant three times a week for 20 to 30 minutes a session for 3 months. Pleasant activities were identified for the residents based on interviews with family caregivers. Repeated measures analysis of variance was used to evaluate treatment effects. No group differences were reported for general behavior as measured using the BEHAVE-AD instrument; both groups improved. A significant group time interaction occurred in favor of the intervention group (p <0.001). No intermediate outcomes, secondary outcomes, or adverse effects were reported.

##### Evidence Synthesis and Strength of Evidence

One trial with study limitations and imprecise estimates provides insufficient evidence regarding the effectiveness of this intervention.

#### Multisensory Intervention Versus Recreational Activities

##### Eligible Trial

Baker et al. randomized 136 residents or day program participants with dementia in facilities in the United Kingdom, the Netherlands, and Sweden to multisensory stimulation (n = 65) or a group activity (n = 71).44 The mean age of residents randomized to multisensory was 81 years, and the mean age of residents randomized to group activity was 83 years. The multisensory intervention involved one-to-one staff participant time in the sensory room where participants could experience touch, smell, sound, and sight. Group activities included activities such as playing card games or doing quizzes. Both multisensory and group activity sessions were conducted for 30 minutes twice a week for 4 weeks (a total of eight sessions). Pre-, mid- (after the fourth session), immediate post- (after the final session), and postintervention assessments (1 month after the final session) were taken. Changes in general behavior measured with several instruments (Behaviour Observation Scale for Intra-mural Psychogeriatrics; BRS; REHAB [general and deviant behavior]; and BMD [total, active/disturbed]) were similar with intervention and control. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

##### Evidence Synthesis and Strength of Evidence

One trial with study limitations and imprecise estimates provides insufficient evidence regarding the comparative effectiveness of these interventions.

#### Activities of Daily Living Intervention

##### Eligible Trial

Beck et al. randomized 127 nursing home residents with dementia and behavioral symptoms to five groups including an activities of daily living intervention (n = 28), a psychosocial activity intervention (n = 29), a combined activities of daily living/psychosocial activities group (n = 22), attention control (n = 29), or usual care (n = 19).91 Those with severe activity limitations or some psychiatric or medical diagnoses that would restrict participation were excluded. The mean age of all study participants was 82.5 years and 81 percent were female. The interventions were conducted over 2 weeks by project-hired nursing assistants under the supervision of the principal investigator. The goal of the activities of daily living intervention was to reduce agitation/aggression during bathing, grooming, dressing, and eating the noon meal. It was administered 45 to 60 minutes per day during these activities and entails breaking down the tasks, guiding the person initially, and applying individualized problem solving. The psychosocial activity interventions required caregivers to apply 25 standardized modules to help with communication, self-esteem, and personal identity. The modules lasted up to 30 minutes a day depending on resident tolerance. The combined group had both interventions. The attention control group received a 30-minute interaction with a caregiver each day. General behavior measured using the Disruptive Behavior Scale showed similar effects across groups. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

##### Evidence Synthesis and Strength of Evidence

One trial with study limitations and imprecise estimates provided insufficient evidence regarding the effectiveness or comparative effectiveness of these interventions.

#### Simulated Presence

##### Eligible Trial

Camberg et al. conducted a crossover RCT and randomized 54 nursing home residents with dementia and agitation/aggression to simulated family presence, attention control, or usual care.92 The mean age of study participants was 82.7 years and 77 percent were female. Simulated family presence consisted of an audiotape made by a family member and delivered with a telephone call. Because the residents in the study were impaired in recent memory, the recording was perceived as new each time it was heard. Audiotapes were used at least twice a day Monday–Friday for 17 days over 4 weeks. Attention control consisted of an audio tape recording with readings from the newspaper. Attention control was similar to simulated family presence, but recordings were not personalized. Usual care consisted of routine management of behavioral symptoms (e.g., staff interactions, redirection, or physical restraints). Direct observation showed no difference between groups, but staff observation logs showed a greater reduction in behavioral symptoms after simulated presence. Residents showed 67 percent reduction in agitation/aggression after simulated family presence compared with 46 percent reduction after attention control and 59 percent reduction after usual care. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

##### Evidence Synthesis and Strength of Evidence

One trial with study limitations and imprecise estimates provided insufficient evidence regarding the effectiveness of this intervention.

#### Enhancing Family Visits

##### Eligible Trial

McCallion et al. randomized 66 dementia residents of five nursing homes to a Family Visit Education Program (n = 32) or usual care (n = 34).93 The mean age of residents was 86 years. In both the intervention (94%) and usual care groups (65%) there were more females than males. The intervention was a structured 8-week training for family members to make more constructive use of their visits. It consisted of four group sessions with role-playing and teaching, followed by a session where the trainer observed the family member with the resident for 20-30 minutes and gave 15 minutes of individualized feedback. Groups varied from four to eight participants. Agitation/aggression was measured with two versions of the CMAI (CMAI-O based on observations and CMAI-N based on nurse report) and general behavior with MOSES at baseline and 3 and 6 months postintervention. Significant group and time interactions were observed on the physically nonaggressive behavior subscale of the CMAI-N from baseline to 6 months. During this time, physically nonaggressive behavior decreased more for residents in the intervention than for residents in usual care (p < 0.001). During this time period, verbal behavior increased more for residents in the intervention group than in usual care. Finally, from baseline to 3 months, restraints were used less on residents in the intervention group than those in usual care (p <0.024). However, during this same period of time fewer psychotropic drugs were used in residents in usual care than those in the intervention group (p<0.05). No other intermediate outcomes, secondary outcomes, or adverse effects were reported.

##### Evidence Synthesis and Strength of Evidence

One trial with study limitations and imprecise estimates provided insufficient evidence regarding the effectiveness of this intervention.

#### Electrostimulation

##### Eligible Trial

Hozumi et al. randomized 27 nursing home residents with dementia to electrostimulation (n = 14) or sham therapy (n = 13).94 The age of residents varied between 58 and 86 years and 56 percent were female. Electrodes were attached to the forehead using a defined amount of current. Placebo participants had the same electrodes but were not connected to a device. Intervention was performed daily for 2 weeks. Behavioral symptoms were evaluated on the last day of the intervention. Different domains of agitation/aggression were assessed with an unknown scale. Intervention and control did not differ for behavioral disorders. No intermediate outcomes, secondary outcomes, or adverse effects were reported.

##### Evidence Synthesis and Strength of Evidence

One trial with study limitations and imprecise estimates provides insufficient evidence regarding the effectiveness of this intervention.

#### Multisensory Group Intervention

##### Eligible Trial

Robichaud et al. randomized 40 residents with dementia who resided in three institutions in Quebec City, Quebec, Canada, to a sensory integration program (n = 22) or usual leisure activities (n = 18).95 Randomization was stratified according to dementia severity. The mean age of residents in the intervention group was 76.6 years and the mean age of residents in the control group was 80.1 years. Sensory integration incorporated reality orientation and movement approaches. Each session included five steps: (1) opening of the session, reality orientation; (2) activities emphasizing bodily responses: gross, proprioceptive, and vestibular movements; (3) sensory stimulations: taste, smell, touch, sight, hearing; (4) cognitive stimulations for organizing thought: memory, concentration, judgment; and (5) closing the session: socialization, pleasure, and relaxation. Subjects in the study group participated in three 45-minute group sessions per week for 10 weeks. Separate scores were obtained for two scales RMBPC (Revised Memory and Behavior Problem Checklist) (frequency, depression, memory, psychomotor slowness, disruptive behavior) and (reaction, depression, memory, psychomotor slowness, disruptive behavior). Each subject was evaluated at the beginning and end of the intervention program. General behavior measured with RMBPC was similar for intervention and control postintervention. No other intermediate outcomes, secondary outcomes, or adverse effects were reported.

##### Evidence Synthesis and Strength of Evidence

One trial with study limitations and imprecise estimates provides insufficient evidence regarding the effectiveness of this intervention.

## Care Delivery-Level Nonpharmacologic Interventions for Agitation/Aggression in Individuals With Dementia in Long-Term Care Settings

### Key Points

- Few trials studied comparisons and outcomes sufficiently similar to allow pooling data.
- Low strength evidence shows that dementia care mapping and person-centered care were similar to usual care in managing agitation/aggression in residents with dementia.

### Overview

We identified 27 eligible trials that assessed care delivery level nonpharmacologic interventions for agitation/aggression in residents of nursing homes and assisted living facilities. Of these, eight were assessed as having a high risk of bias. These studies are described in Appendix D. Our analysis of the remaining 19 trials is provided below by intervention type. Trials with acceptable risk of bias examined a wide variety of care delivery interventions including dementia care mapping, patient-centered care, emotion-oriented care, and a variety of staff trainings, and environmental changes to assist way-finding. We grouped studies by intervention type and comparison. All studies were trials but they differed in the unit of randomization (i.e., at nursing home level, staff, or residents). In many of the studies the intervention was compared with “usual care” but the nature of this care was poorly specified. In some instances the intervention was added to this usual care; in others it was offered as an alternative. It was frequently not even clear if psychoactive medications were being given concurrently. Table 7 provides a summary of the results by intervention type and comparison. Table 8 provides results for trials analyzed. Small changes, even though statistically significant, may not be clinically significant. There have been efforts to create validated measures of minimal important differences (MID) for some topics but we could find no such data for agitation or aggression. We, therefore, simply comment when we judge that the size of the effect is not likely to be clinically significant.

Table 7 Care delivery-level interventions for agitation/aggression in nursing home and assisted living facility residents with dementia

Intervention-Comparison | Total Number of Studies (Number of Participants) | Strength of Evidence - Summary of Results
Agitation/Aggression
Dementia care mapping | 3 (643) | Low – agitation/aggression not improved
Person-centered care | 3 (813) | Low – agitation/aggression not improved
Protocols to reduce antipsychotic use | 3 (1,263) | Insufficient – no conclusions drawn
Emotion-oriented care | 2 (297) | Insufficient – no conclusions drawn
General Behavior
Dementia care mapping | 3 (643) | Insufficient – no conclusions drawn
Person-centered care | 2 (467) | Insufficient – no conclusions drawn
Protocols to reduce antipsychotic use | 1 (659) | Insufficient – no conclusions drawn
Emotion-oriented care | No studies reported | Insufficient – no conclusions drawn
Intermediate Outcomes
Dementia care mapping | 1 (180) | Insufficient – no conclusions drawn (staff behavior)
Dementia care mapping | 2 (339) | Insufficient – no conclusions drawn (staff distress)
Dementia care mapping | 1 (158) | Insufficient – no conclusions drawn (antipsychotic & psychotropic drug use)
Person-centered care | 2 (505) | Insufficient – no conclusions drawn (antipsychotic & psychotropic drug use)
Person-centered care | 1 (159) | Insufficient – no conclusions drawn (staff distress)
Protocols to reduce antipsychotic use | 3 (1,263) | Insufficient – no conclusions drawn (antipsychotic & psychotropic drug use)
Protocols to reduce antipsychotic use | 1 (659) | Insufficient – no conclusions drawn (staff behavior)
Emotion-oriented care | 1 (151) | Insufficient – no conclusions drawn (antipsychotic & psychotropic drug use)
Secondary Outcomes
Dementia care mapping | 1 (159) | Insufficient – no conclusions drawn (injuries)
Dementia care mapping | 1 (180) | Insufficient – no conclusions drawn (staff distress/burden/quality of life)
Person-centered care | 1 (159) | Insufficient – no conclusions drawn (injuries)
Protocols to reduce antipsychotic use | No studies reported | Insufficient – no conclusions drawn
Emotion-oriented care | 1 (146) | Insufficient – no conclusions drawn (staff distress/burden/quality of life)

Table 8 Efficacy and comparative effectiveness of care delivery interventions for agitation/aggression in nursing home and assisted living facility residents with dementia

Study Design Country Comparison k= ; n= Study Risk of Bias | Intervention Description [Intensity, Duration, Qualifications Interventionist] | Primary Outcomes-Instrument Results | Intermediate/Secondary Outcomes-Instrument Results
Dementia Care Mapping
Chenoweth, 2009^96^ Jeon, 2012^96,99^ RCT Australia Dementia Care Mapping vs. Usual Care k=3; n=159 Low risk of bias | Treatment: Staff training and implementation of dementia-care mapping; sessions focused on observing positive and negative care delivery. Following observations feedback was provided to nurses and care plans were developed Comparison: Addressed custodial and physical task oriented practices (e.g., unwarranted use of physical restraints, tendency to ignore psychosocial needs, and limited options for resident choice); - 6 hours a day for 2 days; - Study investigators and two care staff from nursing home trained by Bradford-trained experts | Agitation/Aggression CMAI AMD (CI)=-10.9 (-21.1 to -0.7) General Behavior NPI, baseline Adjusted Mean (SE)=12.7 (5.1) vs. 16.9 (5.3) NPI, postintervention (4 months) Adjusted Mean (SE)=16.8 (5.1) vs. 20.2 (5.4) NPI, postintervention (8 months) Adjusted Mean (SE)=12.7 (5.1) vs. 16.9 (5.3) Hierarchical linear model: p-value for group: 0.68 Hierarchical linear model: p-value for group and group × time: 0.30 Patient Distress: NR Nursing Home Admission: NR Injuries: NR Incidents Falls, injuries, drug errors, behavioral events, baseline Adjusted Proportion=0.40% vs. 0.25% Falls, injuries, drug errors, behavioral events, postintervention (4 months) Adjusted Proportion=0.49% vs. 0.37% Falls, injuries, drug errors, behavioral events, postintervention (8 months) Adjusted Proportion=0.46% vs. 0.37% Hierarchical linear model: p-value for group and group: 0.15 Hierarchical linear model: p-value for group × time: 0.89 | Staff Behavior: NR Antipsychotic Use Baseline Adjusted Proportion=0.15% vs. 0.19% postintervention (4 months) Adjusted Proportion=0.19% vs. 0.14% postintervention (8 months) Adjusted Proportion=0.15% vs. 0.14% Hierarchical linear model: p-value for group: 0.01 Hierarchical linear model: p-value for group × time: 0.66 Staff Distress: MBI-Emotional Exhaustion Baseline Mean (SE) = 17.3 (1.7) vs. 12.4 (2.3) postintervention (4 months) Mean (SE) = 14.8 (1.8) vs. 14.5 (2.5) postintervention (8 months) Mean (SE) = 12.9 (1.8) vs. 16.6 (2.5) Repeated Measures ANCOVA: p-value for group × time: 0.028 (combined intervention groups vs. usual care) MBI-Depersonalization Baseline Mean (SE) = 3.5 (0.6) vs. 4.3 (0.8) postintervention (4 months) Mean (SE) = 3.6 (0.6) vs. 3.8 (0.9) postintervention (8 months) Mean (SE) = 3.0 (0.6) vs. 4.9 (0.8) Repeated Measures ANCOVA: p-value for group × time: 0.66 MBI-Personal Accomplishment Baseline Mean (SE) = 35.7 (1.4) vs. 31.2 (2.1) postintervention (4 months) Mean (SE) = 36.2 (1.3) vs. 33.8 (1.9) postintervention (8 months) Mean (SE) = 36.1 (1.3) vs. 36.9 (1.8) Repeated Measures ANCOVA: p-value for group × time: 0.17 GHQ-28 Baseline Mean (SE) = 0.9 (0.3) vs. 0.5 (0.4) postintervention (4 months) Mean (SE) = 1.5 (0.4) vs. 1.2 (0.5) postintervention (8 months) Mean (SE) = 0.7 (0.4) vs. 1.2 (0.5) Repeated Measures ANCOVA: p-value for group × time: 0.92 Staff Burden: NR Staff QoL: NR
Rokstad, 2013^97^ RCT Norway Dementia Care Mapping vs. Usual Care K=3; n=308 Moderate risk of bias | Treatment: Staff received 3-hour lecture on dementia-care mapping; used as a process tool to develop care staff skills in person centered care Comparison: All three treatment groups received five DVDs with lectures about dementia. No other information regarding the control group was provided.; - dementia-care mapping at beginning of study and 6-months; - two care staff members from nursing home were trained | Agitation/Aggression Brief Agitation Rating Scale MC (p-value between group)=-1.5 vs. 0.2 (0.06) Multivariate regression: Coefficient (CI) = -2.0 (-5.1 to 1.1) Agitation-NPI-Q Agitation MC (p-value between group)=-0.3 vs. 0.5 (<0.01) Multivariate regression: Coefficient (CI) = -0.9 (-1.7 to -0.04) General Behavior – NPI-Q MC (p-value between group) =-0.2 vs. 1.4 (<0.01) Multivariate regression: Coefficient (CI) = -2.7 (-4.6 to -0.7) Patient Distress: NR Nursing Home Admission: NR Injuries: NR | Staff Behavior: NR Antipsychotic Use: NR Staff Distress: NR Staff Burden: NR Staff QoL: NR
Van de Ven, 2013^98^ RCT Netherlands Dementia Care Mapping vs. Usual Care K=3; n=180 Moderate risk of bias | Treatment: Nursing homes given a briefing on dementia-care mapping (observation, feedback, action plan); two staff trained and certified Comparison: Continuation of daily care practices; practices could vary by facility. Additional details were not provided.; - 2 dementia-care mapping cycles; - two staff from each nursing home were trained | Agitation/Aggression CMAI MD (CI)= 2.4 (-2.7 to 7.6) General Behavior NPI-NH, baseline Mean (SE)=5.35 (0.94) vs. 6.28 (0.88) NPI-NH postintervention (4 months) Mean (SE)=7.19 (0.95) vs. 4.45 (0.88) NPI-NH postintervention (8 months) Mean (SE)=6.28 (0.92) vs. 4.13 (0.86) Linear mixed-effect model p-value for group: 0.23 Linear mixed-effect model p-value for group * time: 0.02 Patient Distress: NR Nursing Home Admission: NR Injuries: NR | Staff Behavior QEAW emotion reactions, baseline Mean (SE)=13.69 (1.51) vs. 9.48 (1.40) QEAW emotion reactions, postintervention (4 months) Mean (SE)=23.38 (1.67) vs. 25.97 (1.59) QEAW emotion reactions, postintervention (8 months) Mean (SE)=53.28 (1.20) vs. 53.09 (1.12) Linear mixed-effect model p-value for group: 0.719 Linear mixed-effect model p-value for group * time: 0.015 Antipsychotic Use: NR Staff Distress GHQ 12, baseline Mean (SE)=17.48 (0.33) vs. 16.67 (0.29) GHQ 12 postintervention (4 months) Mean (SE)=15.72 (0.38) vs. 14.89 (0.34) GHQ 12 postintervention (8 months) Mean (SE)=14.57 (0.37) vs. 14.42 (0.32) Linear mixed-effect model p-value for group: 0.122 Linear mixed-effect model p-value for group * time: 0.43 Staff Burden: NR Staff QoL MJSS-HC, baseline Mean (SE)=76.98 (1.36) vs. 77.29 (1.44) MJSS-HC, postintervention (4 months) Mean (SE) =76.40 (1.34) vs. 75.10 (1.43) MJSS-HC, postintervention (8 months) Mean (SE)=78.08 (1.40) vs. 75.58 (1.46) Linear mixed-effect model p-value for group: 0.56 Linear mixed-effect model p-value for group * time: 0.069
Person-Centered Care
Chenoweth, 2009^96^ Jeon, 2012^99^ RCT Australia Dementia Care Mapping vs. Usual Care k=3; n=141 Low risk of bias | Treatment: Training in person centered care using the Bradford University training manual; focused on teaching caregivers to interpret behavior as a form of communication Comparison: Addressed custodial and physical task oriented practices (e.g., unwarranted use of physical restraints, tendency to ignore psychosocial needs, and limited options for resident choice); - 2-day training session + 2 nursing home visits by study investigators to implement person-centered care + conference calls between investigators and staff; - study investigators | Agitation/Aggression CMAI AMD (CI) =-13.6 (-23.9 to -3.3) General Behavior NPI, baseline Adjusted Mean (SE)=21.3 (6.8) vs. 16.9 (5.3) NPI, postintervention (4 months) Adjusted Mean (SE)=16.8 (5.1) vs. 20.2 (5.4) General Behavior NPI, postintervention (8 months) Adjusted Mean (SE)=13.5 (5.1) vs. 15.3 (5.3) Hierarchical linear model: p-value for group: 0.68 Hierarchical linear model: p-value for group × time: p = 0.30 Patient Distress: NR Nursing Home Admission: NR Injuries: NR Incidents Falls, injuries, drug errors, behavioral events, baseline Adjusted Proportion=0.43% vs. 0.25% Falls, injuries, drug errors, behavioral events, postintervention (4 months) Adjusted Proportion=0.53% vs. 0.37% Falls, injuries, drug errors, behavioral events, postintervention (8 months) Adjusted Proportion=0.44% vs. 0.37% Hierarchical linear model: p-value for group and group: 0.15 Hierarchical linear model: p-value for group × time: 0.89 | Staff Behavior: NR Antipsychotic Use Baseline Adjusted Proportion=0.42% vs. 0.19% postintervention (4 months) Adjusted Proportion=0.30% vs. 0.14% postintervention (8 months) Adjusted Proportion=0.34% vs. 0.14% Hierarchical linear model: p-value for group: 0.01 Hierarchical linear model: p-value for group × time: 0.66 MBI-Emotional Exhaustion Baseline Mean (SE) = 14.3 (1.5) vs. 12.4 (2.3) postintervention (4 months) Mean (SE) = 16.0 (1.7) vs. 14.5 (2.5) postintervention (8 months) Mean (SE) = 15.1 (1.6) vs. 16.6 (2.5) Repeated Measures ANCOVA: p-value for group × time: 0.028 (group means either treatment group compared with usual care) MBI-Depersonalization Baseline Mean (SE) = 3.4 (0.6) vs. 4.3 (0.8) postintervention (4 months) Mean (SE) = 3.2 (0.6) vs. 3.8 (0.9) postintervention (8 months) Mean (SE) = 2.9 (0.6) vs. 4.9 (0.8) Repeated Measures ANCOVA: p-value for group × time: 0.66 MBI-Personal Accomplishment Baseline Mean (SE) = 34.1 (1.3) vs. 31.2 (2.1) postintervention (4 months) Mean (SE) = 35.5 (1.2) vs. 33.8 (1.9) postintervention (8 months) Mean (SE) = 35.2 (1.1) vs. 36.9 (1.8) Repeated Measures ANCOVA: p-value for group × time: 0.17 GHQ-28 Baseline Mean (SE) = 0.9 (0.2) vs. 0.5 (0.4) postintervention (4 months) Mean (SE) = 1.3 (0.3) vs. 1.2 (0.5) postintervention (8 months) Mean (SE) = 1.1 (0.3) vs. 1.2 (0.5) Repeated Measures ANCOVA: p-value for group × time: 0.92 Staff Burden: NR Staff QoL: NR
Rokstad, 2013^97^ RCT Norway Dementia Care Mapping vs. Usual Care k=3; n=288 Moderate risk of bias | Treatment: A 24-indicator framework to evaluate person-centered care; three nurses from each ward attended a 3-day training seminar on person-centered care, then led intervention Comparison: All three treatment groups received five DVDs with lectures about dementia. No other information regarding the control group was provided.; - 3-day training seminar; 3-hour class to all staff regarding the VPM methodology; 45-60 minutes weekly staff meetings to analyze patient-nurse interactions, meetings chaired by nurse trained in VPM method; - 3 nursing home staff | Agitation/Aggression Brief Agitation Rating Scale MC (p-value between group) = -1.2 vs. 0.2 (0.17) Multivariate regression: Coefficient (CI) = -1.1 (-3.8 to 1.6) NPI-Q Agitation MC (p-value between group) = -0.5 vs. 0.5 (<0.01) Multivariate regression: Coefficient (CI) = -0.9 (-1.6 to -0.01) General Behavior NPI-Q MC (p-value between group) = -0.7 vs. 1.4 (<0.01) Multivariate regression: Coefficient (CI) = -2.4 (-4.1 to -0.6) Patient Distress: NR Nursing Home Admission: NR Injuries: NR | Staff Behavior: NR Antipsychotic Use: NR Staff Distress: NR Staff Burden: NR Staff QoL: NR
Fossey, 2006*100 RCT England Clinical Protocol Combined with Person Centered Care vs. Usual Care k=3; n=346 Moderate risk of bias *This study fits in person-centered care and reducing antipsychotics | Treatment: Staff training in delivery of person centered care and understanding the role of the environment in the patient caregiver relationship; training in Cohen-Mansfield behavioral management technique Comparison:; - weekly supervision over 10 months; - psychologist, occupational therapist, or nurse to staff caregivers, study investigators provided weekly supervision; prescribers worked with study psychiatrists 2-days a week | Agitation/Aggression CMAI AMD (CI) = -0.3 (-8.3 to 8.9) Agitation-% of population with >1 episode of aggression MD (CI) = -1.6% (-12.7% to 15.8%) General Behavior: NR Patient Distress: NR Nursing Home Admission: NR Injuries: NR | Staff Behavior: NR Antipsychotic Use % taking antipsychotics MD (CI) = -19.5% (-47.1% to 3.0%) Dose of antipsychotics AMD (CI) = -4.0% (-29.9% to 22.0%) % taking other psychotropic MD (CI) = 5.9% (-27.2% to 15.5%) Staff Distress: NR Staff Burden: NR Staff QoL: NR
Reducing Antipsychotics
Fossey, 2006*100 RCT England Clinical Protocol Combined with Person Centered Care vs. Usual Care K=2; n=346 Moderate risk of bias *This study fits in person-centered care and reducing antipsychotics | Treatment: Staff training in delivery of person centered care and understanding the role of the environment in the patient caregiver relationship; training in Cohen-Mansfield behavioral management technique Comparison:; - weekly supervision over 10 months; - psychologist, occupational therapist, or nurse to staff caregivers, study investigators provided weekly supervision; prescribers worked with study psychiatrists 2-days a week | Agitation/Aggression CMAI AMD (CI) = -0.3 (-8.3 to 8.9) % of population with >1 episode of aggression MD (CI) = -1.6% (-12.7% to 15.8%) General Behavior: NR Patient Distress: NR Nursing Home Admission: NR | Staff Behavior: NR Antipsychotic Use -% taking antipsychotics MD (CI) = -19.5% (-3.0% to 41.7%) Antipsychotic Use -Dose of antipsychotics AMD (CI) = -4.0% (-29.9% to 22.0%) % taking other psychotropic MD (CI) = 5.9% (-27.2% to 15.5%) Staff Distress: NR Staff Burden: NR Staff QoL: NR
Rapp, 2013^101^ RCT Germany Clinical Protocol vs. Usual Care K=2; n=258 Low-Moderate risk of bias | Treatment: home staff received training on general information about dementia; use of activity-based interventions Comparison: 13 nursing homes provided group activity twice a week for 45 min; 5 nursing homes provided activity sessions once a week for 45 minutes. Not all residents in a usual care home participated in group activity (approximately 29.7% did at baseline). Activity therapy optional for residents in usual care.; - staff trained in two 4-hour sessions; activity interventions 1-2 days a week for 45 minutes; prescribers trained individually for 4 hours; - prescribers, nursing home staff | Agitation/Aggression CMAI AMD (CI) = -6.24 (-14.14 to -2.03) CMAI aggressive behavior subscale F-value (p-value) group × time: 6.442 (0.012) CMAI physically nonaggressive behavior F-value (p-value) group × time: 0.001 (0.977) CMAI verbally agitated behavior F-value (p-value) group × time: 0.853 (0.357) General Behavior: NR Patient Distress: NR Nursing Home Admission: NR Injuries: NR | Staff Behavior: NR Antipsychotic Use Dose of antipsychotic AMD (CI) = -0.03 (-0.05 to -0.03) Staff Distress: NR Staff Burden: NR Staff QoL: NR
Zwijsen, 2014^102^ RCT Netherlands Clinical Protocol vs. Usual Care n=659 Moderate risk of bias | Treatment: Training in using structured form to evaluate behaviors and develop individualized treatment goals Comparison: NR; - 1 day of training at study commencement, postintervention meeting 2 weeks later; study lasted 20 months; - Nursing staff, physicians, and psychologists | Agitation/Aggression CMAI Linear mixed effect model coefficient for difference in MC (CI): -2.5 (-4.3 - -0.6) in favor of intervention. NPI-Agitation Number of agitated behaviors OR (CI): 0.81 (0.50 – 1.32). General Behavior: Total number of NPI symptoms post intervention OR: estimated from figure 0.60 (NS). Patient Distress: NR Nursing Home Admission: NR Injuries: NR | Staff Behavior: Restraint use: NS - detailed data not provided Antipsychotic Use: Number of prescriptions post intervention OR (CI): 0.54 (0.37 – 0.80) in favor of treatment Staff Distress: NR Staff Burden: NR Staff QoL: NR
Emotion Oriented Care
Finnema, 2005^103^ RCT Netherlands Emotion oriented care vs. Control k=2; n=146 Low risk of bias | Treatment: Basic course for all nursing home care staff on emotion-oriented care (staff experience and understanding resident experiences); advanced course for select staff focused on making life histories and acknowledging patient experiences; advisor course for select staff focused on implementation on emotion oriented care (these staff also led emotion-oriented group sessions for residents). Comparison: working in accordance with the guidelines of the Model-Care plan of the Dutch Association of Nursing Home Care. No other details provided.; - basic course: 2 days; advanced course: 7 days over 8 months; advisor course: 10 days over 9 months; - nursing assistants | Agitation/Aggression CMAI Multivariate Analysis of Variance Adjusted Means (F-test, p-value): 3.34 vs. 3.63 (0.43, 0.51) General Behavior: NR Patient Distress: NR Nursing Home Admission: NR Injuries: NR | Staff Behavior: NR Antipsychotic Use: NR Staff Distress Stress reactions GHQ 12 Multivariate Analysis of Variance Adjusted Means improved and not improved (F-test, p-value): treatment 15.42 and 20.47 and control 19.14 and 14.19 (9.11, 0.003). Staff distress-Stress perception QOS Multivariate Analysis of Variance Adjusted Means improved and not improved (F-test, p-value): treatment 23.02 and 24.73 and control 22.59 and 23.70 (1.51, 0.54) Staff Burden: NR Staff QoL: NR
Schrijnemaekers, 2002^104^ RCT Netherlands Emotion Oriented Care vs. Usual Care n =151 Moderate risk of bias | Treatment: All nursing home staff received clinical lesson on goal of emotion-oriented care; eight staff caregivers received training in emotion-oriented care Comparison: nursing homes' procedures prior to entering the study; - lesson: 1 hour; three half-day supervision meetings; - professional training organization teacher | Agitation/Aggression CMAI-verbal aggression Day-care unit caregivers linear multilevel model adjusted MD per month (p-value): 0.04 (NS) 3-month day-care unit caregivers linear multilevel model adjusted MD per month (p-value): 1.54 (NS) 6-month day-care unit caregivers linear multilevel model adjusted MD per month (p-value): 0.78 (NS) 12-month day-care unit caregivers linear multilevel model adjusted MD per month (p-value): 0.41 (NS) Ward unit caregivers linear multilevel model adjusted MD per month (p-value): -0.14 (NS) 3-month ward unit caregivers linear multilevel model adjusted MD per month (p-value): -0.07 (NS) 6-month ward unit caregivers linear multilevel model adjusted MD per month (p-value): -1.10 (NS) 12-month ward unit caregivers linear multilevel model adjusted MD per month (p-value): -1.41 (NS) CMAI aggression Day-care unit caregivers linear multilevel model adjusted MD per month (p-value): 0.04 (NS) 3-month day-care unit caregivers linear multilevel model adjusted MD per month (p-value): 0.59 (NS) 6-month day-care unit caregivers linear multilevel model adjusted MD per month (p-value): 0.12 (NS) 12-month day-care unit caregivers linear multilevel model adjusted MD per month (p-value): 0.67 (NS) Ward unit caregivers linear multilevel model adjusted MD per month (p-value): -0.13 (NS) 3-month ward unit caregivers linear multilevel model adjusted MD per month (p-value): -0.87 (NS) 6-month ward unit caregivers linear multilevel model adjusted MD per month (p-value): -0.83 (NS) 12-month ward unit caregivers linear multilevel model adjusted MD per month (p-value): -1.18 (NS) CMAI physical nonaggression Day-care unit caregivers linear multilevel model adjusted MD per month (p-value): 0.03 (NS) 3-month day-care unit caregivers linear multilevel model adjusted MD per month (p-value): 0.70 (NS) 6-month day-care unit caregivers linear multilevel model adjusted MD per month (p-value): -0.85 (NS) 12-month day-care unit caregivers linear multilevel model adjusted MD per month (p-value): 0.97 (NS) Ward unit caregivers linear multilevel model adjusted MD per month (p-value): -0.14 (NS) 3-month ward unit caregivers linear multilevel model adjusted MD per month (p-value): -0.28 (NS) 6-month ward unit caregivers linear multilevel model adjusted MD per month (p-value): -2.26 (<0.01) in favor of control 12-month ward unit caregivers linear multilevel model adjusted MD per month (p-value): -1.27 (NS) GIP nonsocial Day-care unit caregivers linear multilevel model adjusted MD per month (p-value): 0.04 (NS) 3-month day-care unit caregivers linear multilevel model adjusted MD per month (p-value): 0.35 (NS) 6-month day-care unit caregivers linear multilevel model adjusted MD per month (p-value): 0.84 (NS) 12-month day-care unit caregivers linear multilevel model adjusted MD per month (p-value): 0.08 (NS) Ward unit caregivers linear multilevel model adjusted MD per month (p-value): 0.05 (NS) 3-month ward unit caregivers linear multilevel model adjusted MD per month (p-value): 1.96 (NS) 6-month ward unit caregivers linear multilevel model adjusted MD per month (p-value): 1.78 (NS) in favor of control 12-month ward unit caregivers linear multilevel model adjusted MD per month (p-value): 1.01 (NS) GIP loss of decorum Day-care unit caregivers linear multilevel model adjusted MD per month (p-value): 0.01 (NS) 3-month day-care unit caregivers linear multilevel model adjusted MD per month (p-value): 0.47 (NS) 6-month day-care unit caregivers linear multilevel model adjusted MD per month (p-value): 0.38 (NS) 12-month day-care unit caregivers linear multilevel model adjusted MD per month (p-value): 0.18 (NS) Ward unit caregivers linear multilevel model adjusted MD per month (p-value): 0.00 (NS) 3-month ward unit caregivers linear multilevel model adjusted MD per month (p-value): 0.05 (NS) 6-month ward unit caregivers linear multilevel model adjusted MD per month (p-value): 0.05 (NS) in favor of control 12-month ward unit caregivers linear multilevel model adjusted MD per month (p-value): -0.10 (NS) General Behavior: NR Patient Distress: NR Nursing Home Admission: NR Injuries: NR | Staff Behavior: NR Antipsychotic Use: NR Psychotropic Use Ward unit caregivers linear multilevel model adjusted MD per month (p-value): 0.00 (NS) 3-month ward unit caregivers linear multilevel model adjusted MD per month (p-value): 0.00 (NS) 6-month ward unit caregivers linear multilevel model adjusted MD per month (p-value): 0.07 (NS) 12-month ward unit caregivers linear multilevel model adjusted MD per month (p-value): 0.02 (NS) Staff Distress: NR Staff Burden: NR Staff QoL: NR
Unique Comparisons
Deudon, 2009^106^ RCT France Staff education vs. Control n=306 Low-Moderate risk of bias | Treatment: Teaching session on dementia to nursing home care staff; use of how-to instruction cards providing practical advice on how to deal with behaviors Comparison: Usual care defined as care according to own practices and procedures; - 90-minute session; trainings available 2-hours twice a week; - trainers | Agitation/Aggression CMAI Linear mixed effect model coefficient for MC (SD) [p-value for difference between intervention and control]: -0.26 (0.05) vs. 0.02 (0.06) [0.001] CMAI physically nonaggressive behavior Linear mixed effect model coefficient for MC (SD) [p-value for difference between intervention and control]: -0.02 (0.002) vs. -0.003(0.03) [<0.0001] CMAI verbally nonaggressive behavior Linear mixed effect model coefficient for MC (SD) [p-value for difference between intervention and control]: -0.02 (0.003) vs. 0.001 (0.004) [<0.001] CMAI physically aggressive behavior Linear mixed effect model coefficient for MC (SD) [p-value for difference between intervention and control]: -0.001 (0.002) vs. 0.004 (0.002) [0.142] CMAI verbally aggressive behavior Linear mixed effect model coefficient for MC (SD) [p-value for difference between intervention and control]: -0.01 (0.004) vs. -0.001 (0.004) [0.571] General Behavior NPI-Hyperactivity factor Linear mixed effect model coefficient for MC (SD) [p-value for difference between intervention and control]: -0.25 (0.2) vs. 0.35 (0.2) [0.032] Patient Distress: NR Nursing Home Admission: NR Injuries: NR | Staff Behavior: NR Antipsychotic Use: NR Baseline Mean (SD) =2.52 (1.3) vs. 2.68 (1.65) Postintervention (8 weeks) Mean (SD) =2.62 (1.3) vs. 2.76 (1.6) Postintervention (20 weeks) Mean (SD) =2.51 (1.3) vs. 2.81 (1.6) Staff Distress: NR Staff Burden: NR Staff QoL: NR
Proctor, 1999^110^ RCT England Staff Education and Care Planning vs. Usual Care n=120 Low-Moderate | Treatment: Nursing home staff received educational seminars on dementia; weekly psychiatric nurse visits to support developing care plans. Comparison: Usual care not defined; - seven 1-hour seminars; - psychiatric nurse | Agitation: NR General Behavior CRB AMD (CI) = -0.7 (-3.0 to 1.6) Patient Distress: NR Nursing Home Admission: NR Injuries: NR | Staff Behavior: NR Antipsychotic Use: NR Staff Distress: NR Staff Burden: NR Staff QoL: NR
Clare, 2013^112^ RCT England Staff Training in Aware Care vs. Usual Care k=1; n=65 Low risk of bias | Treatment: Nursing home staff received training on resident awareness and use of AwareCare measures; staff observation and weekly support Comparison: Homes in the control group received no input; - 8 week course (two 90-minute sessions + 6 weeks observation and weekly support); - accredited trainer | General Behavior PRS Analysis of Covariance Adjusted Means (SE): 37.39 (2.32) vs. 34.71 (2.17) Analysis of Covariance F-test (p-value) of group * time: 0.25 (0.62) Patient Distress: NR Nursing Home Admission: NR Injuries: NR | Staff Behavior MBI Depersonalization Analysis of Covariance Adjusted Means (SE): 1.32 (0.04) vs. 0.53 (0.07) Analysis of Covariance F-test (p-value) of group * time: 2.55 (0.12) Antipsychotic Use: NR Staff Distress GHQ Analysis of Covariance Adjusted Means (SE): 6.63 (0.82) vs. 7.12 (1.05) Analysis of Covariance F-test (p-value) of group * time: 0.22 (0.64) Staff Burden Emotional Exhaustion Analysis of Covariance Adjusted Means (SE):12.36 (0.07) vs. 12.38 (0.07) Analysis of Covariance F-test (p-value) of group * time: 0.00 (0.99) Staff QoL: NR
Wenborn, 2013^111^ RCT United Kingdom Activity Intervention vs. Usual Care n=159 Low-Moderate risk of bias | Treatment: Education sessions to nursing home staff to improve knowledge and skill; one-to-one coaching; occupational therapy assessment of physical environment Comparison: Usual care consisted of care consistent with procedures of the home. Homes were allowed to implement their own training or any new activity provision they sought fit.; - five 2-hour sessions over 16 weeks; - occupational therapists, study investigators | Agitation/Aggression CBS 4-week MD (CI) = 1.15 (-9.23 to 11.52) 12-week AMD (CI) = 4.13 (-21.10 to 29.36) General Behavior CAPE BRS 4-week MD (CI) = 1.08 (-0.18 to 2.34) 12-week AMD (CI) = 0.52 (-1.63 to 2.67) Patient Distress: NR Nursing Home Admission: NR Injuries: NR | Staff Behavior: NR Antipsychotic Use: NR Total Medications 4-week MD (CI) = 0.10 (-0.53 to 0.34, 0.66) 12-week AMD (CI) = -0.15 (-0.55 to 0.24) Staff Distress: NR Staff Burden: NR Staff QoL: NR
Chapman, 2007^114^ RCT United States Advanced illness care team vs. usual care n = 118 Moderate risk of bias | Treatment: Advanced illness care team (AICT) intervention addressed 4 domains of care (medical issues, meaningful activities, psychological problems, and behavioral concerns); care teams of staff working in each of the units at the nursing homes (medicine, nursing, social work, psychology, PT, OT, nutrition. Residents and families were invited to participate in a planning meeting of each AICT Comparison: Usual care (waitlist control) participants received typical services and received treatment after the 8 week usual care period; - care team met five times during the intervention period; planning meetings during weeks 3 and 8; - licensed clinical social workers (study authors) | Agitation/Aggression CMAI – Aggressive behavior, mean (SD) Baseline: 1.18 (0.47) vs. 1.23 (0.48) 8 weeks: 1.10 (0.25) vs. 1.16 (0.39) CMAI – Physically nonaggressive behavior, mean (SD) Baseline: 1.64 (1.10) vs. 1.36 (0.52) 8 weeks: 1.30 (0.60) vs. 1.29 (0.49) CMAI – Verbally agitated behavior, mean (SD) Baseline: 1.44 (0.48) vs. 1.44 (0.61) 8 weeks: 1.28 (0.42) vs. 1.36 (0.53) | Staff Behavior: NR Antipsychotic Use: NR Staff Distress: NR Staff Burden: NR Staff QoL: NR
Kovach, 2006^113^ RCT United States Training in Serial Trial Intervention vs. Usual Care n=114 Moderate risk of bias | Treatment: long-term care nurses led in an educational seminar on how to use STI method (a five step process used to identify needs and apply therapy to meet the need) Comparison: Nurses in the control group were taught common misconceptions about dementia, the physical effects of aging, causes of dementia, stages of Alzheimer's disease, and approaches to treating behaviors associated with dementia.; - 7-hour seminar; - 2 advanced practice nurses | General Behavior BEHAVE AD, baseline Mean (SD) =7.43 (6.75) vs. 6.80 (5.47) BEHAVE AD, Postintervention (2 weeks) Mean (SD) =5.56 (5.64) vs. 6.15 (5.55) BEHAVE AD, Postintervention (4 weeks) Mean (SD) =4.68 (4.06) vs. 4.96 (4.39) Repeated Measures Analysis of Variance F-test (p-value) group × time: 0.70 (0.5) Patient Distress: NR Nursing Home Admission: NR Injuries: NR | Staff Behavior: NR Antipsychotic Use: NR Staff Distress: NR Staff Burden: NR Staff QoL: NR
McGilton, 2003^115^ RCT Canada Way-finding vs control n = 32 Moderate risk of bias | Treatment: Way-finding intervention included backward chaining Comparison: NR; - 30 minutes 3x/week for 4 weeks; - research assistant | Agitation/Aggression Pittsburgh Agitation Scale, mean (SD) Baseline: 2.4 (1.6) vs. 1.8 (1.3) 1 week post-intervention: .87 (0.88) vs. 0.92 (1.0) 3 months post-intervention: 1.8 (1.1) vs. 0.92 (0.99) | Staff Behavior: NR Antipsychotic Use: NR Staff Distress: NR Staff Burden: NR Staff QoL: NR
Magai, 2002^108^ RCT United States Staff Training vs. Behavioral Placebo and Wait-list Control n=95 Moderate risk of bias | Treatment: Nursing home staff received training in nonverbal sensitivity Comparison: No information provided; placebo control group participated in training sessions but the sessions focused on cognitive and behavioral aspects of dementia and did not focus on patient affect; - ten 1-hour sessions over 2 weeks; - clinical psychologist | Agitation/Aggression Aggregate measure incorporating CDS, CMAI, and BEHAVE-AD Baseline Mean (SD) =83.7 (51.2) vs. 25.2 (5.2) vs. 40.6 (7.8) Postintervention (3 weeks) Mean (SD) =69.1 (36.1) vs. 49.6 (27.2) vs. 75.4 (41.4) Postintervention (6 weeks) Mean (SD) =69.1 (36.1) vs. 49.6 (27.2) vs. 75.4 (41.4) Postintervention (9 weeks) Mean (SD) =71.8 (37.6) vs. 44.6 (23.7) vs. 63.1 (42.0) Postintervention (12 weeks) Mean (SD) =65.5 (37.7) vs. 39.2 (15.2) vs. 61.6 (31.1) Repeated Measures Analysis of Variance F-test (p-value) for group: 2.28 (NS) Repeated Measures Analysis of Variance F-test (p-value) for group × interaction: 1.15 (NS) General Behavior: NR Patient Distress: NR Nursing Home Admission: NR Injuries: NR | Staff Behavior: NR Antipsychotic Use: NR Staff Distress: NR Staff Burden: NR Staff QoL: NR
McCallion, 1999^109^ RCT United States Staff Education vs. Usual Care n=105 Moderate risk of bias | Treatment: Nursing home staff received education in knowledge of dementia, verbal and nonverbal communication, memory aids, and problem behaviors Comparison: No intervention-related activity; - five 45-minute group sessions and four 30-minute individual conferences; - master's level social worker | Agitation/Aggression CSDD behavioral disturbance, baseline Mean (SD) =2.00 (1.58) vs. 1.13 (1.06) CSDD behavioral disturbance, Postintervention (3 months) Mean (SD)=1.32 (1.40) vs. 0.98 (1.13) CSDD behavioral disturbance, Postintervention (6 months) Mean (SD)=1.26 (1.17) vs. 1.29 (1.29) Random effects regression F-test (p-value) 3-month group: 49.20 (NS) Random effects regression F-test (p-value) 3-month group × interaction: 7.76 (<0.01) F-test (p-value) 6-month group: 23.46 (NS) F-test (p-value) 6-month group × interaction: 18.64 (<0.001) CMAI aggressive behavior, Baseline Mean (SD)=15.16 (9.81) vs. 13.25 (7.52) CMAI aggressive behavior, Postintervention (3 months) Mean (SD)=11.00 (5.35) vs. 12.46 (6.82) CMAI aggressive behavior, Postintervention (6 months) Mean (SD)=12.21 (8.31) vs. 12.02 (6.22) Random effects regression F-test (p-value) 3-month group: 0.23 (NS) Random effects regression F-test (p-value) 3-month group × interaction: 8.67 (NS) F-test (p-value) 6-month group: 6.02 (NS) F-test (p-value) 6-month group × interaction: 0.92 (NS) CMAI physically nonaggressive behavior, baseline Mean (SD)=12.49 (6.34) vs. 11.09 (5.47) CMAI physically nonaggressive behavior, Postintervention (3 months) Mean (SD)=10.36 (4.72) vs. 11.86 (6.54) CMAI physically nonaggressive behavior, Postintervention (6 months) Mean (SD)=11.38 (5.99) vs. 10.38 (6.32) Random effects regression F-test (p-value) 3-month group: 0.56 (NS) F-test (p-value) 3-month group × interaction: 17.59 (<0.001) F-test (p-value) 6-month group: 7.78 (NS) F-test (p-value) 6-month group × interaction: 0.26 (NS) CMAI verbally aggressive behavior, baseline Mean (SD)=16.22 (10.31) vs. 10.44 (6.21) CMAI verbally aggressive behavior, Postintervention (3 months) Mean (SD)=11.3 8 (7.13) vs. 11.52 (6.71) CMAI verbally aggressive behavior, Postintervention (6 months) Mean (SD)=12.88 (8.39) vs. 12.05 (6.86) Random effects regression F-test (p-value) 3-month group: 38.65 (NS) F-test (p-value) 3-month group × interaction: 32.97 (<0.001) F-test (p-value) 6-month group: 38.82 (NS) F-test (p-value) 6-month group × interaction: 14.23 (<0.001) General Behavior: NR Patient Distress: NR Nursing Home Admission: NR Injuries: NR | Staff Behavior Restraints Use, baseline Mean (SD) =1.20 (1.34) vs. 1.82 (1.62) Restraints Use, Postintervention (3 months) Mean (SD) = 1.53 (1.56) vs. 2.04 (1.78) Restraints Use, Postintervention (6 months) Mean (SD) = 1.88 (1.82) vs. 1.75 (1.42) Random effects regression F-test (p-value) 3-month group: 43.99 (NS) F-test (p-value) 3-month group × interaction: 0.00 (NS) F-test (p-value) 6-month group: 7.20 (NS) F-test (p-value) 6-month group × interaction: 9.54 (<0.01) Antipsychotic Use: NR Psychotropic Use, mean (SD) Baseline, 0.98 (1.41) vs. 1.62 (1.70) Postintervention (3 months) 0.93 (1.39) vs. 1.7 (1.82) Postintervention (6 months) 1.30 (2.15) vs. 1.57 (1.71) Random effects regression F-test (p-value) 3-month group: 37.48 (NS) F-test (p-value) 3-month group × interaction: 1.78 (NS) F-test (p-value) 6-month group: 4.99 (NS) F-test (p-value) 6-month group × interaction: 1.61 (NS) Staff Distress: NR Staff Burden: NR Staff QoL: NR
Teri, 2005^105^ RCT United States Staff Training vs. Usual Care n=31 Moderate risk of bias | Treatment: Assisted living staff received workshops focused on dignity and respect of patient and caregiver skill development + individualized sessions Comparison: Usual on-site training (general information on needs of older, memory-impaired adults); - 2-half day workshops; 4 individual sessions; - clinical psychologist (study author), graduate nursing student | Agitation/Aggression ABID AMC (SD)=-3.8 (4.0) vs. -0.5 (6.7) General Behavior NPI AMC (SD)= -3.5 (8.1) vs. 2.7 (10.0) RMBPC Total Score Frequency AMC (SD)= -1.1 (1.0) vs. 0.2 (0.8) RMBPC Disruption Frequency AMC (SD)= -0.2 (0.2) vs. 0.0 (0.3) General Behavior: NR Patient Distress: NR Nursing Home Admission: NR Injuries: NR | Staff Behavior: NR Antipsychotic Use: NR Staff Distress: NR Staff Burden NPI (staff impact) AMC (SD)= -1.2 (5.3) vs. 1.6 (4.2) RMBPC (reaction) AMC (SD)= -0.7 (1.0) vs. 0.2 (0.8) RMBPC-disruption (reaction) AMC (SD)= -0.1 (0.3) vs. 0.0 (0.0) Staff QoL-Job Satisfaction AMC (SD)= 0.2 (0.4) vs. 0.00 (0.05)
Galik, 2014^116^ RCT United States Function-focused Care vs. Attention Control n =103 Moderate risk of bias | Treatment: Nursing home staff were trained in engaging residents to optimize physical activities; key intervention components included nursing home environment assessment, staff education, development of function focused goals and physical activities Comparison: Attention control reduced educational seminars on function focused care.; - sites received intervention for 10 hours per week for 6 months total; - research nurse | Agitation CMAI baseline Control M (SE): 19.06 (1.05) Treatment M (SE): 16.57 (0.69) p-value difference between control and treatment: 0.08 CMAI 3-months Control M (SE): 18.95 (1.21) Treatment M (SE): 17.04 (0.69) p-value difference between control and treatment: 0.01 CMAI 6-months Control M (SE): 19.48 (1.46) Treatment M (SE): 17.83 (0.89) p-value difference between control and treatment: 0.36 General Behavior: NR Patient Distress: NR Nursing Home Admission: NR Injuries: NR Harms/Adverse Events Falls 6-months Control N (%): 25 (50) Treatment N (%): 15 (28) p-value difference between control and treatment: 0.02 Emergency room visits for falls 6-months: Control N (%): 5 (10) Treatment N (%): 1 (2) p-value difference between control and treatment: 0.08 Injuries post falls 6-months Control N (%): 5 (10) Treatment N (%): 5 (9) p-value difference between control and treatment: 0.92 Deaths 6-months Control N (%): 3 (6) Treatment N (%): 5 (9) p-value difference between control and treatment: 0.45 | Staff Behavior: Self-efficacy for Restorative Care Activities Function Focused Activities - The Restorative Care Behavior Checklist baseline Control M (SE): 0.55 (0.04) Treatment M (SE): 0.63 (0.04) p-value difference between control and treatment: 0.18 Function Focused Activities - The Restorative Care Behavior Checklist 3-months Control M (SE): 0.61 (0.04) Treatment M (SE): 0.71 (0.04) p-value difference between control and treatment: 0.12 Function Focused Activities - The Restorative Care Behavior Checklist 6-months Control M (SE): 0.40 (0.06) Treatment M (SE): 0.66 (0.05) p-value difference between control and treatment: 0.001 Antipsychotic Use: NR Staff Distress: NR Staff Burden: NR Staff QoL Job Satisfaction (Job Attitude Scale) baseline Control M (SE): 35.00 (1.02) Treatment M (SE): 39.37 (0.93) p-value difference between control and treatment: 0.002 Job Satisfaction (Job Attitude Scale) 3-months Control M (SE): 33.35 (1.19) Treatment M (SE): 37.85 (0.93) p-value difference between control and treatment: 0.003 Job Satisfaction (Job Attitude Scale) 6-months Control M (SE): 35.13 (1.24) Treatment M (SE): 36.89 (1.00) p-value difference between control and treatment: 0.280

ABID=Agitated Behavior in Dementia; BEHAVE-AD=Behavioral Pathology in Alzheimer's disease; BMD=Behavior and Mood Disturbance; = General Health Questionnaire; MBI = Maslach Burnout Inventory; MOSES=Multi-dimensional Observation Scale for Elderly Patients; NPI=Neuropsychiatric Inventory; REHAB=Rehabilitation Evaluation Hall and Baker; RMBPC=Revised Memory and Behavior Problem Checklist

#### Dementia Care Mapping

##### Eligible Trials

Three studies evaluated dementia care mapping (DCM) in nursing homes using cluster randomized designs.96-98 DCM is a systematic approach to identifying and strategically responding to presumed causes of agitation/aggression and distress. The DCM process consists of observing care, the environment, and factors associated with resident wellbeing as identified by behavioral indicators, and then identifying positive and negative aspects of care delivery. Feedback is given to nursing home staff and used to inform action plans. In some cases, the intervention was conducted by both the trained staff and outside experts. The three studies that evaluated DCM ranged in size from 180 to 308.^96-98^ Studies were similar in terms of resident characteristics with mean age of residents varying from 83 to 85 years and most were female. Two studies reported different characteristics of nursing facilities with the number of residents to staff ranging from 0.73 to 3.6.^96,97^ Only one study reported care staff characteristics.98

Chenoweth et al. compared DCM (n = 109) with person-centered care (PCC) (n = 98) and usual care (n = 82) over a 4-month period.96,99 Results for the PCC arm of the trial are presented in the PCC section. Nursing homes were randomized to treatment conditions, and dementia residents with need driven behavioral problems were invited by management and staff to participate in the study. Nursing homes in the DCM group had 52 beds, and 0.73 residents per staff member. Nursing homes randomized to usual care had 53 beds and 0.86 residents per staff member. The mean age of residents randomized to DCM was 83 years and most were female (83%). Mean age of patients in usual care was 85 years and 73 percent were female. In each intervention nursing home, two trained study investigators led DCM along with two care staff trained by a Bradford-trained expert in DCM. Study investigators and care staff conducted DCM for 6 hours over 2 days and then developed personalized care plans. Study investigators conferred with staff via regular teleconferences. Usual care consisted of normal practice of custodial and physical task oriented practices. Hierarchical linear models were estimated to test for treatment effects. With DCM, agitation/aggression declined compared with usual care as measured by the CMAI. At postintervention (4 months from end of intervention) CMAI score differed by 10.9 points (95% CI, 0.7 to 21.1) in favor of DCM compared with usual care. This represents a 5 percent improvement for patients in DCM relative to usual care and is unlikely to be clinically meaningful. There was no significant group or time by group interaction for general behavior as measured by the NPI, and DCM did not differ significantly from usual care for incidents (falls, injuries, drug errors, and behavioral events), and use of antipsychotic drugs.96 Staff outcomes (burnout and general health) were reported in a second publication.99 There was a significant reduction of burnout as measured by the Maslach Burnout Inventory emotional exhaustion subscale, but it is not clear if this is due to DCM or PCC. This study had a low risk of bias.

Rokstad et al. compared DCM (n = 158) and PCC (n = 138) with usual care (n = 150) over a 10-month period.97 Results for the PCC arm of the trial are presented in the PCC section. DCM was used as a process tool to help staff deliver PCC. Nursing homes were randomized to treatment conditions. All residents with dementia were invited to participate in the study. On average, nursing homes had 24.1 residents per ward and 3.6 patients per staff member. The mean age of all residents was 85.7 years and 71.8 percent were female. Two staff members from nursing homes randomized to DCM participated in a detailed training course. All other staff randomized to DCM participated in a 3-hour lecture on DCM principles. The two trained staff members and study investigators then carried out DCM. Each DCM session consisted of 4-6 hours of observation per person with dementia. Following observations of staff and patient interactions, staff participated in feedback sessions with the care mappers. Observation and feedback sessions were held during the beginning of the study and again at 6 months. Nursing home staff randomized to DCM, PCC, and the control group received five DVDs with lectures about dementia. Other than the educational DVDs the control group did not receive any additional training. Linear mixed-models were estimated to test for treatment effects. Compared with the control group, patients cared for by staff in the DCM (-2.0 95% CI, -5.1 to 1.1) showed less agitation/aggression at postintervention on the Brief Agitation Rating Scale, but this was not significant. However, again compared with the control group, patients cared for by staff assigned to DCM experienced significant reductions on the overall NPI-Q (DCM -2.7; 95% CI: -4.6 to -0.7) and the NPI-Q agitation subscale (DCM -0.9; 95% CI: -1.7 to -0.04).97 Although statistically significant, the difference may not be clinically meaningful.38 This study had a moderate risk of bias due to possible selection bias (unbalanced on key baseline covariates) and high attrition.

A study by van de Ven et al. attempted to replicate the DCM component of the study by Chenoweth et al.96,98 Nursing homes were randomized to DCM (resident n = 73) or usual care (resident n = 119). Managers in each home selected staff members to participate in the intervention. Residents were invited to participate in the study if they had dementia and at least one behavioral symptom. Residents lost to attrition were replaced. The mean age of residents in DCM (84.6 years) and usual care (83.5 years) was similar, and in both groups most residents were female. The mean age of care staff in DCM (43.6 years) and usual care (42.6 years) was similar, and in both homes 98 percent of care staff were female. Two staff members from each intervention nursing home participated in a basic and advanced DCM training program. All staff members in intervention nursing homes attended a seminar on the goals and methods of DCM. Staff trained in DCM conducted at least two cycles of mapping (observation, feedback, and action plans) over a 4-month period. Residents in usual care received the continuation of daily care practices. Linear-mixed effect models were used to evaluate treatment effects. DCM had no significant effect on patient agitation/aggression (CMAI mean difference in favor of usual care 2.4; 95% CI: -2.7 to 7.6). There was a significant interaction effect between group and time in favor of the control group on the NPI-NH scale (p = 0.022), but there was no difference in mean score at postintervention. In terms of staff outcomes, there was no significant group by time interaction in GHQ-12 scores (p = 0.432), or MJSS-HC (p = 0.069). This study had a moderate risk of bias due to possible selection bias (unclear methods of randomization) and high attrition.

##### Evidence Synthesis and Strength of Evidence Assessment

All eligible DCM studies assessed agitation/aggression. Chenoweth et al. was the only study to report an effect in favor of DCM on the primary measure of agitation/aggression. Rokstad et al. reported a significant improvement for DCM on a secondary outcome measure of agitation/aggression. However, both of these effects are small and unlikely to be clinically meaningful.96,97 Both Chenoweth et al. and van de Ven et al. used the CMAI to evaluate agitation/aggression. Rokstad et al. evaluated agitation/aggression using the Brief Agitation Rating Scale, an instrument derived from the CMAI. The secondary outcome measure used by Rokstad et al. was the NPI-Q agitation subscale. To pool results, we standardized the mean between treatment group differences in the primary measure of agitation/aggression from each study. Figure 5 shows the pooled results of the three DCM studies. Low strength evidence shows that the effect of DCM on agitation/aggression in dementia is similar to control (standardized mean difference -0.12; 95% CI: -0.66 to 0.42). The meta-analysis model had an I^2^ of 53 percent and Tau of 0.15. In a subsequent analysis we standardized the CMAI with the NPI-Q agitation subscale and again found similar effects with DCM and control.

Figure 5 Random effects meta-analysis for the effect of dementia care mapping on agitation/sggression

SMD = standardized mean difference; CI = confidence interval

Figure 5 is a forrest plot describing the random effects meta analysis of dementia care mapping versus usual care. Neither trial showed an intervention effect and the pooled estimate showed no difference between treatments in managing agitation/aggression in dementia.

Evidence for all other outcomes was insufficient. All three studies reported general behavior using a version of the NPI (e.g., NPI-Q and NPI-NH).96-98 Only Rokstad et al. reported significant improvements in general behavior for the intervention group. Chenoweth reported no effect and van de Ven et al. reported a significant effect favoring the control. Studies varied on reporting of other outcomes of intermediate and secondary outcomes. Chenoweth et al. reported a null effect for DCM on neuroleptic use and injuries. This was the only study to report on neuroleptic use or injuries. None of the studies reported adverse events. Finally, van de Ven reported null effects of DCM on staff behavior and general health. This was the only study to evaluate staff outcomes.

#### Person-Centered Care

##### Eligible Trials

Three studies evaluated PCC interventions using cluster randomized designs.96,97,100 PCC aims to foster personhood (e.g., positive relationships with others) as dementia progresses. It involves observations and feedback but involves less effort to identify underlying causes of behaviors than DCM. Three studies ranged in size from 141 to 346.^96,97,100^ Studies were similar in terms of resident characteristics with the mean age of residents varying from 82 to 85 years. Two studies reported different characteristics of nursing facilities with the number of residents to staff ranging from 0.73 to 3.6.^96,97^

Chenoweth et al. compared PCC with usual care over a 4-month period. The study design is described in the DCM section above. The mean age of residents in PCC was 84 years and 74 percent were female. The number of beds in nursing homes randomized to PCC was 47 and there were 0.92 residents per staff member. Staff members in nursing homes randomized to PCC participated in a 2-day training session focused on interpreting behaviors as a form of communication. Sessions also highlighted techniques to develop care plans for residents. During the intervention period, staff discussed care plans with trainers. Hierarchical linear models were estimated to test for treatment effects. Compared with patients cared for by staff randomized to usual care, patients cared for by staff randomized to PCC had significantly less agitation/aggression at 4 months after the intervention (mean difference in CMAI score 13.6 points; 95% CI: 3.30 to 23.9). This represents a 7 percent improvement for patients in PCC relative to usual care and is unlikely to be clinically meaningful. The NPI also showed a significant time trend favoring PCC (p = 0.04). However, the group and group by time interaction were not significant. There was no significant difference between PCC and usual care on incidents (falls, injuries, drug errors, and behavioral events) and antipsychotic drugs. Staff outcomes (burnout and general health) were evaluated in a separate study.99 There was a significant treatment effect on the measure of burnout as measured by the Maslach Burnout Inventory emotional exhaustion subscale, but it is not clear if this is due to DCM or PCC. This study had a low risk of bias.

Rokstad et al. compared PCC with usual care over a 10-month period. The study design is described in the DCM section above. PCC was based on the VIPS framework (described as [V]aluing people with dementia, [I]ndividualized care, understanding the world from the [P]atient's perspective, and providing a social environment that supports the needs of patient[S]). The VIPS framework consists of 24 indicators used to ensure person-centered care. A staff nurse that participated in a 3-day training in the VIPS method led weekly 60-minute meetings during which the VIPS framework was used to evaluate a challenging patient-staff interaction. PCC and the control group received five DVDs with lectures about dementia. Other than the DVDs the control group consists of usual practice. Linear mixed-models were estimated to test for treatment effects. Compared with the control group, patients in the PCC group (-1.1; 95% CI: -3.8 to 1.6) showed a nonsignificant reduction in agitation/aggression measured using the Brief Agitation Rating Scale. However, patients in PCC had statistically significant reductions on the NPI-Q (mean difference -2.4; 95% CI: -4.1 to -0.6) and the NPI-Q agitation sub scale (mean difference -0.9; 95% CI: -1.6 to -0.1). However, these reductions may not be clinically meaningful. This study had a moderate risk of bias due to possible selection bias (unbalanced on key baseline covariates) and high attrition.

Fossey et al. compared a staff training and support program designed to reduce drug use for the management of agitation/aggression (n = 181) with usual care (n = 168) over a 12-month period. Nursing homes were randomized to treatment and usual care. Residents with dementia were invited to participate in the study. The median age of residents in the treatment group was 82 years and 35 percent were female. The median age of residents in usual care was 82 years and 39 percent were female. Care staff characteristics were not provided. Staff members in the intervention group were trained in person-centered care methods and the use of nonpharmacologic behavioral management techniques. In addition, nursing homes randomized to the intervention agreed to work with a geriatric psychiatrist to review and adjust medications as needed. Treatment effects were evaluated using weighted t test and weighted linear regression. The authors adjusted for baseline neuroleptic use and region and found a nonsignificant decrease in the proportion of residents taking any neuroleptics in the intervention group compared with usual care at 12-month postintervention (-19.1; 95% CI: -41.7 to 3.0). Null effects were also observed for dose of neuroleptics and proportion of residents taking other psychotropics. Intervention and usual care did not differ significantly on agitation/aggression at 12 months (CMAI mean difference in favor of the intervention 0.3; 95% CI: -8.3 to 8.9) or on the number of aggression episodes (mean difference in favor of intervention group of percent of residents with >1 episode of aggression (-1.6; 95% CI: -12.7 to 15.8). This study had a moderate risk of bias due to detection bias (not adjusting for multiple comparisons) and high attrition.

##### Evidence Synthesis and Strength of Evidence Assessment

All eligible person-centered care studies assessed agitation/aggression. Chenoweth et al. was the only study to report a statistically significant effect of PCC on agitation/aggression. However, because the effect size was unlikely to be clinically meaningful, these results should not be interpreted as evidence of effectiveness due only to the statistical difference. Rokstad et al. reported a statistically significant reduction in agitation/aggression for PCC as assessed with one instrument, but not another. To pool results, we standardized the mean between treatment group differences at the final period of postintervention on the primary measure of agitation/aggression from each study. Figure 6 shows the pooled analysis describing the effect of PCC on agitation/aggression in dementia. Low strength evidence shows that PCC and usual care have a similar effect on agitation/aggression in dementia (standardized mean difference -0.15; 95% CI: -0.67 to 0.38). The meta-analysis model had an I^2^ of 56 percent and a Tau of 0.14.

Figure 6 Random effects meta-analysis for the effect of person-centered care on agitation/aggression

SMD=Standardized mean difference; CI=confidence interval;

Figure 6 is a forrest plot describing the random effects meta analysis of person-centered care versus usual care. Neither trial showed an intervention effect and the pooled estimate showed no difference between treatments in managing agitation/aggression in dementia.

Evidence for general behavior and intermediate outcomes was insufficient. Two of the three studies reported general patient behavioral outcomes; of these, Rokstad et al. reported a difference in general patient behavior in favor of PCC, and Chenoweth et al. reported a null effect. PCC had no effect on neuroleptic use or injuries. None of the studies reported staff outcomes.

#### Protocols To Reduce Use of Antipsychotics

##### Eligible Studies

Three studies used staff training and clinical protocols to reduce the use of antipsychotics. These studies have been grouped together.100-102 The studies ranged in size from 258 to 659.^100-102^ Resident characteristics were similar across studies, but neither study reported nursing facility or care provider characteristics.

Fossey et al. evaluated a clinical protocol to reduce antipsychotic use combined with person-centered care versus usual care. Results from this study were analyzed in both the person-centered care and in the reducing antipsychotics group. The authors adjusted for baseline antipsychotic use and region and found no difference in the proportion of residents taking any antipsychotics at 12-month postintervention between intervention and control (mean difference favoring the intervention group -19.1; 95% CI: -41.7 to 3.0). Null effects were also observed at 12-month postintervention for dose of antipsychotics (mean difference in dose of antipsychotics favoring the intervention group -4.9; 95% CI: -20.0 to 29.9) and proportion of the population taking other psychotropics. Daily dose was translated into chlorpromazine daily equivalents using the British National Formulary. Additional details of this study are reported in the PCC section.

Rapp et al. evaluated a staff-training and behavior-based intervention also designed to reduce the use of antipsychotics. The intervention (n = 163) was compared with usual care (n = 141) at 10 months. Nursing homes were randomized to treatment conditions, and residents with dementia were invited to participate in the study. The mean age of study residents was 81.56 years and 73 percent were female. The intervention consisted of two 4-hour staff training sessions on the symptomatology and causes of behavioral symptoms of dementia. Staff members were also trained on the use of physical- and activity-based nonpharmacologic therapies for the management of behavioral symptoms. Finally, prescribers within nursing homes attended individual training sessions on the causes of behavioral symptoms and the use of a guideline-based prescribing for pharmacotherapy. The control group received treatment as usual. Repeated measures multivariate analysis of variance was used to evaluate treatment effects. At 10 months CMAI was significantly lower for residents in the treatment group than for residents in the control group (mean difference 6.24; 95% CI: 2.03 to 14.44). This represents a 3 percent improvement for residents in the treatment group compared with usual care, which may not be clinically meaningful. In addition, CMAI-aggression subscale scores significantly decreased in the intervention group (baseline mean sub score 14.03 SD = 5.82 and 10 month postintervention mean sub score 11.75 SD = 4.32) while increasing in the control group (baseline mean sub score 14.53 SD = 6.94 and 10 month postintervention mean sub score 17.12 SD = 11.07). The difference in mean change between intervention and control was significant (p = 0.012). No differences were observed between the intervention and control on the physically nonaggressive (p= 0.977) and verbally agitated (p = 0.357) subscales of the CMAI. At 10 months residents in the intervention group were prescribed fewer antipsychotics (mean difference of defined daily dosage 0.03; 95% CI: 0.01 to 0.05). The defined daily dosage was determined based on medication usage 2 weeks prior to assessment and was calculated using the German algorithm of the anatomic therapeutic chemicals. This study had a low-moderate risk of bias due to performance bias (unclear application of the intervention) and detection bias (not blinding assessors).

Zwijsen et al. compared a structured patient analysis form with a control group using a stepped-wedge randomized trial.102 Nursing homes with dementia special care units were recruited to participate in the study. In total, 659 residents with dementia participated in the study. The mean age of residents was 84 years and 69 percent were female. Nursing staff characteristics were not provided. Staff randomized to the intervention (nursing assistants, physicians, and psychologist) participated in a 1-day seminar to learn about the analysis form. A postintervention seminar was conducted 2 weeks after the initial training. As part of the training, prescribers were provided information about the negative consequences associated with antipsychotics and the benefits of psychosocial interventions. The structured patient analysis form consisted of observing patient behavior to develop treatment goals and plans. Patients were evaluated after the implementation of the treatment plan. No information was provided regarding the control condition. Mixed effects models were used to evaluate treatment effects at 20 months. Compared with the control group residents in the intervention experienced a significant but modest reduction in agitation/aggression as measured by the CMAI (-2.4; 95% CI: -4.30 - -0.60). This small reduction may not be clinically significant. There was no significant difference between groups in terms of general behavior as measured by the NPI-NH. Residents in the intervention group were prescribed fewer antipsychotics (OR: 0.54; 95% CI: 0.37 – 0.80). Finally, there was no difference in the use of restraints.

##### Evidence Synthesis and Strength of Evidence Assessment

Evidence was insufficient to draw conclusions regarding efficacy of interventions on reducing antipsychotic use, agitation/aggression, or any of the secondary outcomes. Rapp et al. reported a small but significant reduction in mean defined daily dose of antipsychotics in the intervention group. Zwijsen et al. also found a small reduction in the number of antipsychotics prescribed. In contrast, Fossey et al. reported no difference between intervention and control in terms of total antipsychotic use or dosing. To pool results, we standardized the mean between treatment group differences of antipsychotic dose. Results from Zwijsen et al. could not be pooled due to insufficient data regarding sample sizes in each treatment group. Figure 7 shows the forest plot of the effect of the interventions on antipsychotic dose. The pooled results indicated that the interventions had no effect on antipsychotic dose (standardized mean difference -0.28; 95% CI: -3.50 to 2.94). The meta-analysis model had an I^2^ of 89 percent and a Tau of 0.34.

Figure 7 Random effects meta-analysis for the effect of clinical protocols on dose of antipsychotics

SMD=Standardized mean difference; CI=confidence interval

Figure 7 is a forrest plot describing the random effects meta analysis of clinical protocols versus usual care. Neither trial showed an intervention effect and the pooled estimate showed no difference between treatments in managing antipsychotic use.

For agitation/aggression, Fossey et al. reported a null effect for the intervention. In contrast, Rapp et al. and Zwijsen et al. found significant reductions in agitation/aggression for the intervention group. To pool results, we evaluated the mean between treatment group differences at final period of postintervention on CMAI. Figure 8 shows the forest plot of the effect of interventions on agitation/aggression as measured by the CMAI. Again, results from Zwijsen et al. could not be pooled due to insufficient data. In pooled results, these studies had no effect on agitation/aggression (mean difference -4.5; 95% CI: -38.84 to 29.93). The meta-analysis model had an I^2^ of 32 percent and a Tau of 2.39.

Figure 8 Random effects meta-analysis for the effect of clinical protocols on agitation/aggression

SMD = Standardized mean difference; CI = confidence interval

Figure 8 is a forrest plot describing the random effects meta analysis of clinical protocols versus usual care. Neither trial showed an intervention effect and the pooled estimate showed no difference between treatments in managing agitation/aggression in dementia.

#### Emotion-Oriented Care

##### Eligible Studies

Two studies evaluated emotion-oriented care using cluster randomized designs.103,104 Emotion-oriented care consists of understanding the resident's perception of the environment and the role of verbal and nonverbal communication in the caregiver-patient relationship. The two studies that evaluated emotion-oriented care ranged in size from 146 to 151. Resident characteristics were similar across both studies. However, only one study provided data on the characteristics of care staff.103

Finnema et al. compared emotion-oriented care combined with the guideline based Model-Care plan of the Dutch Association of Nursing Home Care (n = 46) versus the guideline based Model-Care plan alone (n = 53) (i.e., usual care) over 9 months. Nursing homes were randomized to treatment conditions, and residents with dementia were invited to participate in the study. The mean age of residents in the treatment group was 83.8 years and 81 percent were female. Similarly, the mean age of residents in usual care was 83.6 years and 81 percent were female. The mean age of care staff in both treatment groups was 30 years and 87 percent were female. The emotion-oriented care component of the intervention consisted of a 2-day basic course for all staff in emotion-oriented care (e.g., staff members' experiences and application of nonverbal empathic skills). Five staff members from each intervention nursing home then participated in an advanced emotion-oriented care class. The 7-day advanced course (spread over 8 months) trained staff members on how to take life histories, acknowledge residents' experiences, and be alert to how past residents' experiences affect the present. Finally, one staff member per intervention nursing home was invited to participate in an adviser emotion-oriented training course. During this 10-day course (delivered over 9 months) the staff member was trained to organize and lead emotion-oriented care sessions for residents. These staff members were also responsible for the implementation of emotion-oriented care in their home institution. Two half-day training courses on the Model-Care plan were conducted in all intervention and usual care nursing homes. In both intervention and usual care homes, the staff training provided a methodological framework for developing individualized care plans. Multivariate analysis of variance was used to evaluate treatment effects. Residents cared for by staff randomized to the intervention group did not significantly improve agitation/aggression measures (CMAI, CMAI-PA, CMAI-VNA, BIP10-restless behavior). Compared with the usual care, staff that improved in the application of emotion-oriented care scored lower on stress reactions on the GHQ-28 (p = 0.003), but did not differ in stress perception scores as measured by the QOS (p = 0.54). This study had a low risk of bias.

Schrijnemaekers et al. compared an emotion-oriented intervention (n = 77) with usual care (n = 74). Homes for the elderly were randomized to treatment conditions and dementia residents with behavioral problems were invited to participate in the study. Homes for the elderly are similar to nursing homes, but all homes offered a structured day-care unit for residents during the day. At night, residents return to their room within the elderly home. The mean age of residents in the intervention group was 84.3 years and 90 percent were female. The mean age of residents in usual care was 85.9 years and 89 percent were female. All staff in the intervention nursing homes were trained on the goals and objectives of emotion-oriented care. In addition, eight staff caregivers in each intervention home participated in a 6-day training on emotion-oriented care. Hierarchical linear models were estimated to evaluate treatment effects. Overall there was no statistical difference between intervention and control on measures of agitation/aggression and psychotropic use. At the 6-month postintervention residents cared for by staff assigned to the control group had 2.3 fewer physically nonaggressive behaviors than in the treatment group (CMAI-PNA, p <0.001). This represents a 1 percent improvement for usual care residents compared with residents in the intervention group, which may not be clinically meaningful. During the same time period, there were no statistical difference on the CMAI-aggression subscale, CMAI-verbal aggression subscale, or the GIP and GIP-subscales (nonsocial behavior, loss of decorum, rebellious behavior, and restless behavior). This study had a moderate risk of bias due to high detection bias (not blinding assessors).

##### Evidence Synthesis and Strength of Evidence Assessment

Evidence was insufficient to draw conclusions regarding efficacy of interventions on reducing antipsychotic use, agitation/aggression, or any of the secondary outcomes.

Both studies reported no effect for emotion-oriented care on the primary measure of agitation/aggression.103,104 Schrijnemaekers et al. reported a significant reduction in the physically nonaggressive behavior subscale of the CMAI at 6 months for the control group, but staff who made the assessments were aware of treatment assignments. Moreover, this effect was not sustained at 12 months. It was not possible to pool results because one study did not provide standard deviations for point estimates.104 Finnema et al. reported significant improvement on staff stress reactions. Schrijnemaekers reported no significant differences on staff distress, burden, or quality of life. Neither study reported staff behavior outcomes, antipsychotic use, general behavioral outcomes, injuries, or adverse events.

#### Unique Comparisons

##### Eligible Studies

Twelve trials evaluated unique care-delivery level comparisons and could not be conceptually grouped. One study was conducted in an assisted living facility.105 All other studies were conducted in nursing homes.106-116 Studies varied in size from 31 to 306. Studies also varied in terms of unit of randomization and in reporting demographic characteristics of residents and care staff.

Deudon et al. compared an 8-week staff education and training program (n = 174) with a control group (i.e., usual care) (n = 132). Nursing homes were randomized. Staff members in each nursing home invited select dementia residents with behavioral symptoms to participate in the study. The mean age of residents in the treatment group was 86.5 years and 77 percent were female. In usual care, the mean age of residents was 86 years and 79 percent were female. Facility and care staff characteristics were not provided. A 90-minute training session was conducted in intervention nursing homes. The training session provided general information on dementia, behavioral symptoms, and the use of “how-to instruction cards.” The instruction cards were for use in clinical practice and provided practical advice to care staff on how to deal with behavioral symptoms (e.g., recommendations on nonpharmacologic interventions). Trainers also visited intervention nursing homes to observe care staff. Following observations, the trainers provided feedback to staff and personalized training. Treatment effects were evaluated using Wilcoxon nonparametric test and linear mixed-effect models. At 8 and 20 weeks there was no difference between residents randomized to intervention versus control nursing homes on the CMAI and CMAI subscales.

Results from the linear mixed effects model indicated that the decline in agitation/aggression in the intervention group (CMAI coefficient -0.26 p <0.001) was significantly different (p = 0.001) than the mean change observed in the control group (coefficient 0.02 p =0.797). Similar results were observed on the physically nonaggressive and verbally nonaggressive subscales of the CMAI (difference in change between intervention and control p <0.001). While these significant improvements for the intervention group, they represent small improvements and are unlikely to be clinically meaningful. Mean change did not differ significantly between residents in the intervention group and residents in the control group on the physically aggressive and verbally aggressive behavior subscales of the CMAI. Finally, no significant changes were observed on the NPI hyperactivity subscale or psychotropic use for the intervention and control groups. This study had a low-moderate risk of bias due to possible selection bias (unclear description of randomization), and possible attrition bias (unclear description of attrition).

Proctor et al. compared a staff-training program combined with psychosocial management of behavioral symptoms (n = 60) with a control group (i.e., usual care) (n = 60). Residential homes and nursing homes were randomized. In each home, staff members selected 10 residents with behavioral problems to participate in the study. Not all residents had dementia. The mean age of residents who completed assessments at baseline and 6 month postintervention was 83.1 years and 83 percent were female. Facility and care staff characteristics were not provided. Staff training consisted of seven 1-hour seminars over 6 months on staff-identified topics (e.g., management of dementia and aggression). An experienced psychiatric nurse conducted the psychosocial management portion of the intervention. The psychiatric nurse visited intervention nursing homes and advised and supported staff in developing care plans for residents. The control group received treatment as usual. Generalized estimating equations were estimated to evaluate treatment effects. After adjusting for baseline differences, there was no statistical difference in behavioral symptoms for residents in the intervention group compared with residents in the control group at 6 month postintervention (difference on the Crichton scale -0.7; 95% CI: -3.0 to 1.6). This study had a low-moderate risk of bias due to potential selection bias (unbalanced on key baseline variables), potential performance bias (unclear description of the intervention), and potential detection bias (unclear if assessors were blinded).

Clare et al. compared a staff-training program using the AwareCare measure (n = 32) with a control group (i.e., usual care) (n = 33). Care homes were randomized, and care home managers identified and invited residents with severe dementia. Care home managers also identified select care staff to participate in the study. The mean age of residents in the intervention group was 82.3 years and 32 percent were female. The characteristics of residents in usual care were similar. The mean age of care staff in the intervention and control group was 38 years and most were female. The intervention was conducted over 8 weeks and consisted of training staff members to consider residents' awareness and use the AwareCare observational method. In addition, study investigators provided feedback to staff on communication with residents. Analysis of covariance was used to evaluate treatment effects. At 8 weeks from baseline, residents in the intervention group did not improve significantly compared with residents in the control group on behavioral (Positive Response Scale p = 0.62) or key staff outcomes (staff burnout and general health). This study had a low risk of bias.

Wenborn et al. compared an occupational therapy intervention that aimed to increase resident social activity (n = 104) with a control group (i.e., usual care) (n = 106). Care homes and nursing homes were randomized. Residents were invited to participate in the study if they had dementia. The mean age of residents in the intervention group was 84.2 years and 66 percent were female. In the usual care group the mean age of residents was also 84.2 years and 75 percent were female. The intervention consisted of an assessment of the care home's physical environment, a staff education program, and one-to-one staff coaching sessions. Five 2-hour sessions focused on teaching staff to how to identify resident interests and to engage residents in meaningful activities. A trained interventionist worked directly with staff and residents on providing meaningful activities. Usual care consisted of normal practice. Analysis of covariance and multilevel modeling was used to evaluate treatment effects. Resident behavior did not significantly differ between the intervention and control groups as measured by the CBS and CAPE-BRS at 4 or 12 months. The 12-month adjusted results were similar to unadjusted results. Finally, the groups did not differ significantly in use of total medications. This study had a low-moderate risk of bias due to potential performance bias (treatment fidelity is not clear) and potential attrition bias.

Kovach et al. compared a clinical protocol designed to enhance comfort in dementia patients and manage behavioral symptoms (n = 57) with an educational control (n = 57). Long-term care facilities were randomized. Residents with dementia were identified and invited to participate in the study. The mean age of residents in the treatment group was 87 years and 74 percent were female. In the control group, the mean age of residents was 87 years and 77 percent were female. Staff members in the intervention group participated in a 7-hour training focused on the use of a protocol consisting of a physical and affective assessment followed by targeted therapy. Examples of targeted therapy include nonpharmacologic interventions, analgesics, or consultations with other practitioners. Staff members in the control group were given information on misconceptions about aging, dementia, and approaches to treating behaviors associated with dementia. Repeated measures analysis of variance was used to test for treatment effects. Staff nurses in both groups recorded patient behavior. Behavior was measured using BEHAVE-AD. At 2 weeks and 4 weeks post treatment there was no significant time by group interaction for the measure of behavior, and both intervention and control reported reductions in behavior (BEHAVE-AD). Following treatment, more subjects in the intervention returned to baseline behaviors than in the control group (p = 0.002). This study had a moderate risk of bias due to potential selection bias (method of randomization not clear) and detection bias (assessors not blinded).

Magai et al. compared a staff-training program in nonverbal sensitivity (n = 41) with a behavioral placebo group (n = 23) and a wait-list control group (n = 27). Three nursing homes were randomly assigned to treatment conditions. Within each nursing home dementia residents and care staff were invited to participate in the study. The mean age of residents across all groups was 85.9 years and 93 percent were female. The mean age of care staff in all groups was 41.6 years and all were female. Nonverbal sensitivity training consisted of 10 hour lectures over 2 weeks on issues of nonverbal communication and emotional expression. The lectures also covered cultural aspects related to patient affect, including basic emotions, personal emotional triggers, and body language. The behavioral placebo group also participated in 10 hour-long lectures over 2 weeks. Lectures focused on behavioral symptoms of dementia and not on patient affect. The wait-list control received usual care until after the study period, at which point they received training in nonverbal sensitivity. Repeated measures analysis of variance was used to evaluate treatment effects. There were no statistically significant time, treatment, or time by treatment interaction effects for patient symptomology (an aggregate measure incorporating CDS, CMAI, and BEHAVE-AD). This study had a moderate risk of bias due to potential selection bias (method of randomization not clearly explained and unbalanced on several baseline measures), and potential detection bias (potentially underpowered given no power calculation and small sample size [N = 91]).

McCallion et al. compared a nursing assistant communication skills program (n = 49) with a waitlist control group (n = 56). Two nursing homes participated in the study. Within each nursing home, one unit was randomized to the treatment group and the other to the control group. Data were also collected from dementia residents in the units that participated in the study. The mean age of residents in the treatment group was 84.5 years and 86 percent were female. In the control group, the mean age of residents was 83.3 years and 89 percent were female. The mean age of care staff in the treatment group was 40.9 years and 95 percent were female. Care staff in the control group had similar characteristics. For staff assigned to the intervention group, a master's level social worker led five 45-minute group sessions on knowledge of dementia, verbal and nonverbal communication, memory aids, and problem behaviors. Social workers also led four 30-minute individual sessions to help care providers identify barriers to communication, recognize verbal and nonverbal messages conveyed by residents, and provide feedback on the use of memory charts (e.g., the use of signs and labeling property to help residents). All social workers had experience with dementia patients and all participated in four half-day training sessions. Random effect regression models were estimated to evaluate treatment effects. Significant time by group interactions were observed over 3 months (F = 7.76; p <0.01) and 6 months (F= 18.64, p<0.001) for the treatment group compared with the control group on the behavioral disturbance subscale of the CSDD. Over 3 months, there was also a significant time by group interaction (F = 17.59; p <0.001) on the physically nonaggressive behavior subscale of the CMAI in favor of the treatment group. Significant time by group interactions was also observed on the verbally aggressive behavior subscales of the CMAI at 3 (F = 32.97; p <0.001) and 6 months (F = 14.23; p <0.001) in favor of the treatment group. However, at 6 months, staff in the intervention group increased significantly in the use of restraints (F = 9.54; p <0.01). There was no difference in use of psychotropics. This study had a moderate risk of bias due to potential selection bias (unclear method of randomization and some baseline variables not balanced), potential detection bias (potentially underpowered given no power calculation and small sample size [N = 105]), and potential selection bias (staff attrition greater than 20 percent and information on resident attrition not provided).

Teri et al. evaluated an intervention aimed at improving interactions between care staff, the environment, and residents compared with usual care. Only an overall sample size was provided (n = 31). The two-phase study consisted of first a feasibility study and then a randomized trial conducted in the same site to evaluate the effect of the intervention compared with usual care. A sample of assisted living facilities that previously participated in a feasibility study was randomly assigned to treatment conditions. Dementia residents with behavioral problems were invited to participate in the study. The mean age of residents across both treatment conditions was 85.8 years and 87 percent were female. The mean age of staff across both groups was 37.4 years and 96 percent were female. Assisted living staff participated in two half-day workshops and four individualized sessions delivered over 2 months. Each training session was modular and focused on basic information on dementia, verbal and nonverbal skills for communicating with residents, maintaining pleasant events for residents, improving communication between staff and families, and using a framework of activators, behaviors, and consequences for identifying and decreasing resident distress. Staff in usual care received general information on needs of older adults and techniques for caring for residents with dementia. General linear models were estimated to evaluate treatment effects. Compared with usual care, residents in the intervention group had statistically significant improvements on behavioral outcomes. NPI scores declined 3.5 (SD 8.1) points in the intervention group and increased 2.7 (SD 10) points in the control group. The difference in change over time between intervention and control was significant (p = 0.031). This reflects an improvement in behavior for residents in the intervention. Total RMBP scores significantly declined (indicating improvement) in the intervention group (mean change from baseline -1.1 SD 1) and increased in the control group (mean change from baseline 0.2; SD 0.8). The difference in change was significant (p < 0.001) and favored residents in the treatment group. In addition, the difference in change on the ABID between the intervention and control was significant in favor of the intervention (mean change in intervention -3.8 SD 4.0, mean change in control -0.5 SD 6.7, significance of difference in change p <0.001). Staff also benefited from the intervention compared with the control, and significant differences were observed on NPI staff impact (mean change in intervention -1.2 SD 5.3, mean change in control 1.6 SD 4.2, significance of difference in change p = 0.022) and total RMBPC-reaction measures (mean change in intervention -0.7 SD 1.0, mean change in control 0.2 SD 0.8, significance of difference in change p <0.001). Although significant improvements in favor of intervention were observed, these improvements were small and may not be clinically meaningful. No significant difference was observed for staff job satisfaction. This study had a moderate risk of bias due to potential selection bias (information on randomization not provided), using the same site for feasibility testing and implementation, potential detection bias (no power calculation and small sample size [residents N = 31, staff N = 25]), and potential attrition bias (information on attrition not provided).

Chapman, et al. compared the effectiveness of Advance Illness Care Teams (AICT) (n = 57) with usual care (n = 61). Participants were recruited from two large northeastern United States nursing homes. To be invited to participate in the study, residents had to have dementia, needed assistance with four or more ADLs, scored 23 or less on the MMSE, and scored 4 or more on the GDS. The mean age of residents in AICT was 85 years and 95 percent were female. The mean age of residents in usual care was 88 years and 98 percent were female. AICT consisted of staff teams applying a holistic approach (medical issues, meaningful activities, psychological problems, and behavioral concerns) to the care of dementia residents. Staff teams were multidisciplinary (medicine, nursing, social work, OT/PT, psychology, and nutrition). AICT teams met eight times (once a week) to develop and apply interventions across the holistic domains of the intervention.114 Families were invited to the team meeting at week 3 and week 8. Residents randomized to usual care received normal care (e.g., medication management, nursing care, and social-recreational activities). Random effects regression models were used to evaluate treatment effects. Agitation/aggression was measured using the CMAI at baseline and 8 weeks. Physically nonaggressive behavior significantly declined in the treatment group compared with usual care (p <0.05). No other significant group and time interactions were observed.

McGilton et al. compared a wayfinding intervention (n = 17) with a control group (n = 15).115 Residents with dementia in the cognitive support units of a nursing home section of a large, university-affiliated geriatric center were invited to participate in the study. Residents were being relocated to a new facility, which meant that all residents needed to learn their new environments, enabling the investigators to look at the effects of the wayfinding. The study started 6 weeks post-relocation to a new building. The mean age of residents in the treatment group was 86.2 years and 94 percent were female. The mean age of residents in the control group was 89.2 years and 67 percent were female. Wayfinding includes backwards chaining intervention, which focuses on residents' ability to find their way to a specific location. Intervention lasted for 30 minutes, three times a week, for 4 weeks. Outcomes included the Pittsburgh Agitation Scale. Repeated measures analysis of variance was used to evaluate treatment effects. At 3 months after the intervention there was no significant group and time interaction on the measures of agitation/aggression.

Galik et al. compared function-focused care (n = 53) with an attention control group (n = 50).116 Residents with dementia from four nursing homes were invited to participate in the study. The mean age of residents was 83.7 years and 67 percent were white. Nursing assistants were predominantly female (96 percent), nonwhite (96 percent), and had worked within their respective facility for an average of 5.8 years. Function-focused care consisted of four components: (1) an environmental and policy assessment; (2) 30 minute in-service educational seminar for nursing staff on function-focused care (e.g., having residents walk to the dining room) and 15 minute seminar on engaging residents to participate in functional activity; (3) individualized goals were developed; and (4) ongoing education and support was provided to staff implementing function-focused care. To implement the intervention, a research nurse provided up to 10 hours of support for 6 weeks to nursing homes in the intervention group. In addition, within each intervention, nursing home staff champions were identified. Staff in nursing homes randomized to the attention control group received a 30-minute in-service educational seminar on function-focused care. This was the same seminar provided to staff in the intervention group (i.e., step two of the intervention). Generalized estimating equations were used to evaluate treatment effects. Agitation and aggression were measured using the CMAI. At 6-months there was no statistical difference in CMAI score between intervention and attention control. Residents in the intervention group had significantly fewer falls (28% vs. 50%). There were no other differences between groups in terms of adverse events as measured by emergency room visits for falls, inquires post fall, and death. At baseline and 3-months staff in the intervention group reported higher job satisfaction as measured by the Job Attitude Scale, but by 6-months there was no statistically significant difference between staff. Finally, at 6-months staff in the intervention group engaged in functional focused care more often than staff in the control group as measured by the Restorative Care Behavior Checklist.

##### Evidence Synthesis and Strength of Evidence Assessment

Twelve trials studied interventions that could not be conceptually grouped with other studies.105-116 These trials typically had small sample sizes and methodological problems, so evidence was insufficient for all comparisons and outcomes. To evaluate any trends across the studies, we plotted standardized effects of each intervention on agitation/aggression in a forest plot (Figure 9). All of the interventions reported null effects on agitation/aggression, and the forest plots provide evidence of consistency across studies. Studies have wide confidence intervals indicating an overall lack of precision.

Figure 9 Unique comparisons and effect on agitation/aggression

SMD = standardized mean difference; CI = confidence interval

Figure 9 is a forrest plot describing results of a variety of interventions versus usual care. Neither trial showed an intervention effect in managing agitation/aggression in dementia.

Reports of other outcomes of interests in these studies was sparse. Five studies reported general behavioral outcomes. Four of these studies reported a null effect,106,111-113 and one study reported an effect in favor of treatment.105 Two studies reported no effect on antipsychotic use.106,109 None of the other studies reported medication use. Two studies reported multiple outcomes related to staff behavior and distress.105,112 Results were mixed, with both no effect and effects in favor and against the intervention. No other outcomes were reported.

## Patient-Level Interventions for Community-Dwelling Individuals With Dementia

### Key Points

- We identified few trials studying patient-level interventions in community-dwelling dementia patients.

### Overview

We identified five trials that examined patient-focused interventions for managing agitation/aggression in community-dwelling individuals with dementia.36,117-120 Three of these were assessed as having high risk of bias and were not included in the analysis117,118,120 (Appendix D). Table 9 summarizes the results of these trials and Table 10 lists results for relevant outcomes.

Table 9 Patient-level interventions for agitation/aggression in community-dwelling individuals with dementia

Intervention-Comparison | Total Number of Studies (Number of Participants) | Strength of Evidence - Summary of Results
Primary Outcomes
Agitation/Aggression
Multisensory vs. activity | 1 (50) | Insufficient – no conclusions drawn
General Behavior
Multisensory vs. activity | 1 (50) | Insufficient – no conclusions drawn
Art therapy vs. activity | 1 (43) | Insufficient – no conclusions drawn
Intermediate Outcomes
Caregiver Burden | 1 (43) | Insufficient – no conclusions drawn

Table 10 Efficacy and comparative effectiveness of interventions delivered directly to caregivers of community-dwelling individuals with dementia

Study Design Country Comparison n Study Risk of Bias | Intervention Description [Intensity, Duration, Qualifications Interventionist] | Primary Outcomes-Instrument Results | Intermediate/Secondary Outcomes-Instrument Results
Hattori, 2011^119^ RCT Japan Art therapy vs. math exercise n=43 Moderate risk of bias | Treatment: coloring abstract patterns Comparison: addition and multiplication problems; - 45 minute weekly sessions in hospital for 12 weeks, plus 15 minute daily session at-home; - industrial designer/artist, speech therapists | Agitation/Aggression: NR General Behavior Dementia Behavior Disturbance Scale, Mean (SD) Postintervention: 16.8 (12.9) vs. 14.5 (12.7) Patient Distress, QoL SF-8 (physical and mental subscales), Mean (SD) Postintervention physical: 50.5 (4.0) vs. 47.3 (6.7) Postintervention mental: 53.4 (3.3) vs. 52.9 (6.7) Nursing Home Admission: NR Adverse effects: NR | Caregiver Behavior: NR Antipsychotic Use: NR Caregiver Burden: ZBI, Mea (SD) Postintervention: 16.9 (9.1) vs. 16.5 (10.5) Caregiver Distress: NR Caregiver QoL: NR
Baker, 2001^36^ RCT United Kingdom Multicomponent sensory stimulation vs. specialized activity n=50 Moderate risk of bias | Treatment: Nondirective stimulation of all nontaste senses (music, aromas, tactile objects, special lighting) Comparison: interactive control received standardized sessions for the same amount of time geared towards their interests; - 8 30-minute sessions (twice weekly) for 1 month; - nurse, occupational therapist, psychologist | Agitation/Aggression REHAB deviant behavior, AMD (CI) Postintervention: -.32 (-.55 to -.09) BRSD social disturbance, AMD (CI) Postintervention: -.32 (-.55 to -.09) General Behavior REHAB general behavior, MD (CI) Postintervention: ND BMD, MD Postintervention: ND Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR | Caregiver Behavior: NR Antipsychotic Use: NR Caregiver Burden: NR Caregiver Distress: NR Caregiver QoL: NR

AMD=adjusted mean difference; BMD=Behavior and Mood Disturbance; BRSD=Behavior Rating Scale for Dementia; CI=confidence interval; MD=mean difference; ND=no difference; NR=not reported; QoL=quality of life; RCT=randomized controlled trial; REHAB=Rehabilitation Evaluation Hall and Baker; SD=standard deviation; SF-8=short form 8; ZBI=Zarit Burden Index

#### Multisensory Stimulation

##### Eligible Trial

Baker et al., randomized 50 community-dwelling individuals with dementia to a multisensory stimulation intervention (n = 25) or an interactive control group (n = 25).36 The mean age of patients was 78 years and 50 percent were female. Participants had moderate to severe cognitive impairment with a majority diagnosed with Alzheimer's disease (66%) followed by vascular dementia (14%) or a mixed diagnosis (20%). The intervention group received eight standardized 30-minute multisensory stimulation sessions twice weekly for 4 weeks. The multisensory stimulation sessions included unpatterned stimuli, efforts to stimulate all nontaste senses, nondirective enabling approaches by staff, and no intellectual demand of the patient. The interactive control received eight standardized 30-minute sessions composed of activities typically used with individuals with dementia and geared to the individual's interests twice weekly for 4 weeks. Five different scales assessed primary outcomes (patient agitation/aggression measured with the REHAB deviant behavior subscale and the BRS Social Disturbance subscale, general behavior measured using the REHAB general behavior subscale, the Behavior and Mood Disturbance Scale, and the Behavioral Rating Scale) at baseline, 2 weeks, 4 weeks, and 1 month after sessions were completed. Change from baseline was similar with multisensory stimulation or activities in agitation/aggression and general behavior outcomes once differences in baseline characteristics were taken into consideration. No intermediate or secondary outcomes were reported.

##### Evidence Synthesis and Strength of Evidence

One small study provides insufficient evidence on the effectiveness of patient-level multisensory stimulation intervention for treatment of agitation/aggression in community-dwelling individuals with moderate to severe dementia for all outcomes.

#### Art Therapy

##### Eligible Trial

Hattori et al. randomized 43 community-dwelling individuals with dementia to an art therapy intervention (n=22) or interactive control group (n=21).119 The mean age of participants was 74 years and 54 percent were female. Participants had mild cognitive impairment and met Alzheimer's disease diagnostic criteria, although actual diagnosis was not reported. The intervention group received 12 weekly 45-minute coloring sessions in hospital, in addition to daily 15-minute sessions at home over 12 weeks. Participants were given abstract patterns which revealed birds and animals to color at their own pace. The interactive control received arithmetic exercises of simple addition and multiplaction to do at their own pace in daily 15-minute sessions. Two scales assessed primary outcomes (general behavior measured with Dementia Behavior Disturbance Scale, patient distress - QoL measured with SF-8) at baseline and post-treatment. Percent of responders showing a 10 percent or greater improvement for the mental subscale of the SF-8 was significantly higher in the intervention group compared with control post-intervention. No other between-group results were significant. One scale assessed secondary outcomes (caregiver burden measured with Zarit Burden Index [ZBI]) at baseline and post-treatment. ZBI results were not significant. No intermediate outcomes were reported.

##### Evidence Synthesis and Strength of Evidence

One small study provides insufficient evidence on the effectiveness of patient-level art therapy intervention for treatment of agitation/aggression in community-dwelling individuals with moderate to severe dementia for all outcomes.

## Caregiver-Level Interventions for Community-Dwelling Individuals With Dementia

### Key Points

- Evidence for most comparisons was insufficient to conclude whether caregiver-level interventions were effective in managing agitation/aggression in community-dwelling individuals with dementia. This was largely due to heterogeneous comparisons and small sample sizes. Trials often showed no difference between intervention and comparison, but differences were typically too imprecise to conclude a lack of efficacy.
- Evidence was sufficient to draw conclusions for only five comparison-outcome pairs:
  ○ Low strength evidence shows that interventions targeting caregiver skills and knowledge were similar to no treatment in managing care recipient general behavior.
  ○ Low strength evidence shows that interventions targeting caregiver skills and behavior were similar to no treatment in managing caregiver burden.
  ○ Low strength evidence shows that interventions targeting caregiver skills and behavior were similar to attention control in managing care recipient agitation/aggression.
  ○ Moderate strength evidence shows that interventions targeting caregiver skills and behavior are better than attention control in managing caregiver distress.
  ○ Moderate strength evidence shows that interventions targeting caregiver skills and behavior are better than attention control in improving caregiver confidence in caregiving.

### Overview

Twenty-eight references reporting on 27 unique RCTs studied caregiver interventions for managing agitation/aggression in community-dwelling individuals with dementia.121-148 Eight records reported comparisons and outcomes that were assessed as having a high risk of bias (Appendix E).123,124,133,137,142,148-150 These studies were not used in our qualitative analysis; they are described in Appendix E. This results in 20 references of 20 unique trials with an acceptable risk of bias to use in analysis. We grouped trials using previously proposed taxonomy.151 We first identified the primary functional domain addressed by the intervention (i.e., either knowledge or skills for eligible interventions). We then assessed a secondary functional domain addressed by the intervention (i.e., knowledge, skills, behavior, or affect). We discuss the interventions by the primary and secondary functional domains addressed and conducted a qualitative analysis because interventions and outcomes were heterogeneous and pooling was not appropriate. Table 11 summarizes the results of these interventions and Table 12 lists results for relevant outcomes.

Table 11 Caregiver-level interventions: evidence summary

Comparison | Outcome K=total trials; n= total dyads | Evidence Summary
Knowledge-skills vs. no treatment/waitlist/information control Guerra, 2012^136^ Ostwald 1999^144^ | Care recipient agitation/aggression | Insufficient – no data
Knowledge-skills vs. no treatment/waitlist/information control Guerra, 2012^136^ Ostwald 1999^144^ | Care recipient general behavior K=2; n=140 | Insufficient – no conclusions drawn (moderate risk of bias, imprecise)
Knowledge-skills vs. no treatment/waitlist/information control Guerra, 2012^136^ Ostwald 1999^144^ | Care recipient distress/QoL k=1; n=56 | Insufficient– no conclusions drawn (moderate risk of bias, indirect, imprecise, unknown consistency)
Knowledge-skills vs. no treatment/waitlist/information control Guerra, 2012^136^ Ostwald 1999^144^ | Care recipient psychoactive medication | Insufficient – no data
Knowledge-skills vs. no treatment/waitlist/information control Guerra, 2012^136^ Ostwald 1999^144^ | Care recipient nursing home admission | Insufficient – no data
Knowledge-skills vs. no treatment/waitlist/information control Guerra, 2012^136^ Ostwald 1999^144^ | Caregiver burden K=2; n=140 | Insufficient– no conclusions drawn (moderate risk of bias, indirect, imprecise)
Knowledge-skills vs. no treatment/waitlist/information control Guerra, 2012^136^ Ostwald 1999^144^ | Caregiver distress/QoL k=1; n=56 | Insufficient– no conclusions drawn (moderate risk of bias, indirect, imprecise, unknown consistency)
Knowledge-skills vs. no treatment/waitlist/information control Guerra, 2012^136^ Ostwald 1999^144^ | Caregiver behavior k=1; n=84 | Insufficient– no conclusions drawn (moderate risk of bias, imprecise, unknown consistency)
Knowledge-affect vs. attention control Chien, 2008^125^ | Care recipient agitation/aggression | Insufficient – no data
Knowledge-affect vs. attention control Chien, 2008^125^ | Care recipient general behavior K=1; n=88 | Insufficient– no conclusions drawn (moderate risk of bias, imprecise, unknown consistency)
Knowledge-affect vs. attention control Chien, 2008^125^ | Care recipient distress/QoL | Insufficient – no data
Knowledge-affect vs. attention control Chien, 2008^125^ | Care recipient psychoactive medication | Insufficient – no data
Knowledge-affect vs. attention control Chien, 2008^125^ | Care recipient nursing home admission | Insufficient – no data
Knowledge-affect vs. attention control Chien, 2008^125^ | Caregiver burden K=1; n=88 | Insufficient– no conclusions drawn (moderate risk of bias, indirect, imprecise, unknown consistency)
Knowledge-affect vs. attention control Chien, 2008^125^ | Caregiver distress/QoL k=1; n=88 | Insufficient– no conclusions drawn (moderate risk of bias, indirect, imprecise, unknown consistency)
Knowledge-affect vs. attention control Chien, 2008^125^ | Caregiver behavior | Insufficient – no data
Skills-knowledge vs. waitlist, usual care, or info control De Rotrou, 2011^126^ Klondnica, 2011^139^ Gallagher-Thompson, 2010^127^ Ulstein, 2007^152^ Gitlin, 2003^130^ | Care recipient agitation/aggression | Insufficient – no data
Skills-knowledge vs. waitlist, usual care, or info control De Rotrou, 2011^126^ Klondnica, 2011^139^ Gallagher-Thompson, 2010^127^ Ulstein, 2007^152^ Gitlin, 2003^130^ | Care recipient general behavior K=5; n=657 | Skills-knowledge interventions similar to no treatment on care recipient general behavior (Low strength evidence – moderate risk of bias, imprecise)
Skills-knowledge vs. waitlist, usual care, or info control De Rotrou, 2011^126^ Klondnica, 2011^139^ Gallagher-Thompson, 2010^127^ Ulstein, 2007^152^ Gitlin, 2003^130^ | Care recipient distress/QoL | Insufficient – no data
Skills-knowledge vs. waitlist, usual care, or info control De Rotrou, 2011^126^ Klondnica, 2011^139^ Gallagher-Thompson, 2010^127^ Ulstein, 2007^152^ Gitlin, 2003^130^ | Care recipient psychoactive drug use | Insufficient – no data
Skills-knowledge vs. waitlist, usual care, or info control De Rotrou, 2011^126^ Klondnica, 2011^139^ Gallagher-Thompson, 2010^127^ Ulstein, 2007^152^ Gitlin, 2003^130^ | Care recipient nursing home admission | Insufficient – no data
Skills-knowledge vs. waitlist, usual care, or info control De Rotrou, 2011^126^ Klondnica, 2011^139^ Gallagher-Thompson, 2010^127^ Ulstein, 2007^152^ Gitlin, 2003^130^ | Caregiver burden K=2; n=337 | Insufficient– no conclusions drawn (moderate risk of bias, indirect, imprecise)
Skills-knowledge vs. waitlist, usual care, or info control De Rotrou, 2011^126^ Klondnica, 2011^139^ Gallagher-Thompson, 2010^127^ Ulstein, 2007^152^ Gitlin, 2003^130^ | Caregiver distress/QoL | Insufficient – no data
Skills-knowledge vs. waitlist, usual care, or info control De Rotrou, 2011^126^ Klondnica, 2011^139^ Gallagher-Thompson, 2010^127^ Ulstein, 2007^152^ Gitlin, 2003^130^ | Caregiver behavior k=1; n=190 | Insufficient– no conclusions drawn (moderate risk of bias, imprecise, unknown consistency)
Skills-knowledge vs. haloperidol Teri, 2000^154^ | Patient agitation/aggression K=1; n=75 | Insufficient– no conclusions drawn (moderate risk of bias, imprecise, unknown consistency)
Skills-knowledge vs. haloperidol Teri, 2000^154^ | Patient general behavior K=1; n=75 | Insufficient– no conclusions drawn (moderate risk of bias, imprecise, unknown consistency)
Skills-knowledge vs. haloperidol Teri, 2000^154^ | Care recipient distress/QoL | Insufficient – no data
Skills-knowledge vs. haloperidol Teri, 2000^154^ | Care recipient psychoactive drug use | Insufficient – no data
Skills-knowledge vs. haloperidol Teri, 2000^154^ | Care recipient nursing home admission | Insufficient – no data
Skills-knowledge vs. haloperidol Teri, 2000^154^ | Caregiver burden K=1; n=75 | Insufficient– no conclusions drawn (moderate risk of bias, indirect, imprecise)
Skills-knowledge vs. haloperidol Teri, 2000^154^ | Caregiver distress/QoL K=1; n=75 | Insufficient– no conclusions drawn (moderate risk of bias, indirect, imprecise)
Skills-knowledge vs. haloperidol Teri, 2000^154^ | Caregiver behavior | Insufficient – no data
Skills-knowledge vs. placebo Teri, 2000^154^ | Patient agitation/aggression K=1; n=75 | Insufficient– no conclusions drawn (moderate risk of bias, imprecise)
Skills-knowledge vs. placebo Teri, 2000^154^ | Patient general behavior K=1; n=75 | Insufficient– no conclusions drawn (moderate risk of bias, imprecise)
Skills-knowledge vs. placebo Teri, 2000^154^ | Care recipient distress/QoL | Insufficient – no data
Skills-knowledge vs. placebo Teri, 2000^154^ | Care recipient psychoactive drug use | Insufficient – no data
Skills-knowledge vs. placebo Teri, 2000^154^ | Care recipient nursing home admission | Insufficient – no data
Skills-knowledge vs. placebo Teri, 2000^154^ | Caregiver burden K=1; n=75 | Insufficient– no conclusions drawn (moderate risk of bias, indirect, imprecise)
Skills-knowledge vs. placebo Teri, 2000^154^ | Caregiver distress/QoL K=1; n=75 | Insufficient– no conclusions drawn (moderate risk of bias, indirect, imprecise)
Skills-knowledge vs. placebo Teri, 2000^154^ | Caregiver behavior | Insufficient – no data
Skills-behavior vs. waitlist/information control 3 Gitlin, 2008^129^ Gonzalez, 2014^134^ Marriot, 2000^140^ | Patient agitation/aggression K=1; n=56 | Insufficient– no conclusions drawn (moderate risk of bias, imprecise)
Skills-behavior vs. waitlist/information control 3 Gitlin, 2008^129^ Gonzalez, 2014^134^ Marriot, 2000^140^ | Patient general behavior K=2; n=144 | Insufficient– no conclusions drawn (moderate risk of bias, imprecise, inconsistent)
Skills-behavior vs. waitlist/information control 3 Gitlin, 2008^129^ Gonzalez, 2014^134^ Marriot, 2000^140^ | Care recipient distress/QoL | Insufficient – no data
Skills-behavior vs. waitlist/information control 3 Gitlin, 2008^129^ Gonzalez, 2014^134^ Marriot, 2000^140^ | Care recipient psychoactive drug use | Insufficient – no data
Skills-behavior vs. waitlist/information control 3 Gitlin, 2008^129^ Gonzalez, 2014^134^ Marriot, 2000^140^ | Care recipient nursing home admission | Insufficient – no data
Skills-behavior vs. waitlist/information control 3 Gitlin, 2008^129^ Gonzalez, 2014^134^ Marriot, 2000^140^ | Caregiver burden K=2; n=158 | Skills-behavior interventions similar to no treatment on caregiver burden (Low strength evidence – moderate risk of bias, indirect)
Skills-behavior vs. waitlist/information control 3 Gitlin, 2008^129^ Gonzalez, 2014^134^ Marriot, 2000^140^ | Caregiver distress/QoL K=1; n=56 | Insufficient– no conclusions drawn (moderate risk of bias, unknown consistency)
Skills-behavior vs. waitlist/information control 3 Gitlin, 2008^129^ Gonzalez, 2014^134^ Marriot, 2000^140^ | Caregiver behavior k=1; n=56 | Insufficient– no conclusions drawn (moderate risk of bias, unknown consistency)
Skills-behavior vs. attention control 5 Gitlin, 2010a131 Huang, 2013^138^ Gitlin, 2010b132 Gerdner, 2002^128^ Marriot, 2000^140^ | Patient agitation/aggression K=3; n=575 | Skills-behavior interventions similar to attention control on care recipient agitation/aggression (Low strength evidence – moderate risk of bias, imprecise)
Skills-behavior vs. attention control 5 Gitlin, 2010a131 Huang, 2013^138^ Gitlin, 2010b132 Gerdner, 2002^128^ Marriot, 2000^140^ | Patient general behavior K=1; n=102 | Insufficient– no conclusions drawn (moderate risk of bias, imprecise, inconsistent)
Skills-behavior vs. attention control 5 Gitlin, 2010a131 Huang, 2013^138^ Gitlin, 2010b132 Gerdner, 2002^128^ Marriot, 2000^140^ | Care recipient distress/QoL K=1; n=209 | Insufficient– no conclusions drawn (moderate risk of bias, indirect, imprecise, unknown consistency)
Skills-behavior vs. attention control 5 Gitlin, 2010a131 Huang, 2013^138^ Gitlin, 2010b132 Gerdner, 2002^128^ Marriot, 2000^140^ | Care recipient psychoactive medication | Insufficient – no data
Skills-behavior vs. attention control 5 Gitlin, 2010a131 Huang, 2013^138^ Gitlin, 2010b132 Gerdner, 2002^128^ Marriot, 2000^140^ | Care recipient nursing home admission | Insufficient – no data
Skills-behavior vs. attention control 5 Gitlin, 2010a131 Huang, 2013^138^ Gitlin, 2010b132 Gerdner, 2002^128^ Marriot, 2000^140^ | Caregiver burden K=2; n=448 | Insufficient– no conclusions drawn (moderate risk of bias, indirect, imprecise, unknown consistency)
Skills-behavior vs. attention control 5 Gitlin, 2010a131 Huang, 2013^138^ Gitlin, 2010b132 Gerdner, 2002^128^ Marriot, 2000^140^ | Caregiver distress K=3; n=685 | Skills-behavior interventions improve caregiver distress more than attention control (Moderate strength evidence – moderate risk of bias)
Skills-behavior vs. attention control 5 Gitlin, 2010a131 Huang, 2013^138^ Gitlin, 2010b132 Gerdner, 2002^128^ Marriot, 2000^140^ | Caregiver behavior K=1; n=239 | Skills-behavior interventions improve caregiver confidence more than attention control (Moderate strength evidence – moderate risk of bias)
Skills-behavior vs. sham treatment 2 Gormley, 2001^135^ Bourgeois, 2002^122^ | Patient agitation/aggression K=2; n=125 | Insufficient– no conclusions drawn (moderate risk of bias, imprecise)
Skills-behavior vs. sham treatment 2 Gormley, 2001^135^ Bourgeois, 2002^122^ | Patient general behavior K=2; n=125 | Insufficient– no conclusions drawn (moderate risk of bias, imprecise)
Skills-behavior vs. sham treatment 2 Gormley, 2001^135^ Bourgeois, 2002^122^ | Care recipient distress/QoL | Insufficient – no data
Skills-behavior vs. sham treatment 2 Gormley, 2001^135^ Bourgeois, 2002^122^ | Care recipient taking psychotropic medication K=1; n=62 | Insufficient– no conclusions drawn (moderate risk of bias, indirect, imprecise, unknown consistency)
Skills-behavior vs. sham treatment 2 Gormley, 2001^135^ Bourgeois, 2002^122^ | Care recipient nursing home admission | Insufficient – no data
Skills-behavior vs. sham treatment 2 Gormley, 2001^135^ Bourgeois, 2002^122^ | Caregiver burden K=1; n=62 | Insufficient– no conclusions drawn (moderate risk of bias, indirect, imprecise, unknown consistency)
Skills-behavior vs. sham treatment 2 Gormley, 2001^135^ Bourgeois, 2002^122^ | Caregiver distress/QoL | Insufficient – no data
Skills-behavior vs. sham treatment 2 Gormley, 2001^135^ Bourgeois, 2002^122^ | Caregiver behavior | Insufficient – no data
Skills-affect Belle, 2006^121^ Mittelman, 2004^141^ | Care recipient agitation/aggression | Insufficient – no data
Skills-affect Belle, 2006^121^ Mittelman, 2004^141^ | Patient general behavior K=2; n=924 | Insufficient– no conclusions drawn (moderate risk of bias, imprecise, inconsistent)
Skills-affect Belle, 2006^121^ Mittelman, 2004^141^ | Care recipient distress/QoL | Insufficient – no data
Skills-affect Belle, 2006^121^ Mittelman, 2004^141^ | Care recipient psychoactive drug use | Insufficient – no data
Skills-affect Belle, 2006^121^ Mittelman, 2004^141^ | Care recipient nursing home admission K=1; n=518 | Insufficient– no conclusions drawn (moderate risk of bias, imprecise, inconsistent)
Skills-affect Belle, 2006^121^ Mittelman, 2004^141^ | Caregiver burden K=1; n=518 | Insufficient– no conclusions drawn (moderate risk of bias, imprecise, inconsistent)
Skills-affect Belle, 2006^121^ Mittelman, 2004^141^ | Caregiver distress/QoL K=1; n=406 | Insufficient– no conclusions drawn (moderate risk of bias, imprecise, unknown consistency)
Skills-affect Belle, 2006^121^ Mittelman, 2004^141^ | Caregiver behavior | Insufficient – no data

QoL=Quality of Life

Table 12 Efficacy and comparative effectiveness of caregiver-level interventions for community-dwelling individuals with dementia

Study Design Country Comparison n Study Risk of Bias | Intervention Description [Intensity, Duration, Qualifications Interventionist] | Primary Outcomes-Instrument Results | Intermediate/Secondary Outcomes-Instrument Results
Interventions addressing knowledge-skills (k=2)
Guerra, 2011^136^ RCT United States Caregiver intervention vs. waitlist n=56 Low risk of bias | Treatment: Basic education about dementia; training regarding specific problem behaviors; - five weekly 30-minute sessions; - junior psychologists and social workers; Comparison: Waitlist | Agitation/Aggression: NR General Behavior NPI-Q severity score ASMD (CI): -0.10 (-0.66 to 0.48) Patient Distress, QoL DEMQOL ASMD (CI): 0.32 (-0.84 to 1.48) Nursing Home Admission: NR Adverse effects: NR | Caregiver Behavior: NR Antipsychotic Use: NR Caregiver Burden ZBS ASMD (CI): -1.02 (-0.53 to 0.51) Caregiver Distress NPI-Q carer distress score ASMD (CI): -0.09 (-0.64 to 0.48) Caregiver QoL WHO-QoL-Brief, Psych ASMD (CI): 0.10 (-0.47 to 0.68)
Ostwald, 1999^144^ RCT United States General stress mediation model Psychoeducational intervention vs. waitlist n=84 Low to moderate risk of bias | Treatment: Education about dementia and how it affects patient, caregivers, family system; develop and strengthen caregivers' practical skills for dealing with caregiving tasks on a day-to-day basis; strengthen caregivers' feelings of confidence and belief that they are able (competent) to deal with issues, day in and day out; facilitating the family's ability to work collaboratively to find solutions to current management problems; - 7 weekly 120-minute sessions; - study investigators, interdisciplinary faculty (nurses, occupational therapists, family therapists, educators); Comparison: Waitlist | General Behavior RMBPC, disruptive behavior subscale Baseline, mean (SD): 6.75 (5.55) vs. 5.32 (4.10) 3-months, mean (SD): 6.16 (5.26) vs. 4.87 (3.54) 5-months, mean (SD): 6.35 (5.20) vs. 6.68 (4.50) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR | Caregiver Behavior: NR Antipsychotic Use: NR Caregiver Burden ZBS Baseline, mean (SD): 56.18 (13.29) vs. 56.54 (15.97) 3-months, mean (SD): 56.82 (11.83) vs. 55.43 (15.91) 5-months, mean (SD): 54.13 (11.29) vs. 59.81 (15.23) Caregiver distress RMBPC, caregiver response to disruptive behavior subscale Baseline, mean (SD): 6.76 (6.27) vs. 5.20 (5.10) 3-months, mean (SD): 5.00 (5.38) vs. 4.42 (4.23) 5-months, mean (SD): 4.08 (4.44) vs. 5.73 (4.42) Caregiver QoL: NR
Interventions addressing knowledge-affect (k=1)
Chien, 2008^125^ Hong Kong Dementia care management vs. standard care n=88 Moderate risk of bias | Treatment: Personalized care management program including education on dementia care, family role and strength rebuilding, and community support resources; training to target problem areas identified by case manager; - 12 2-hour sessions every other week over 6 months; - trained case manager; Comparison: Monthly education sessions, pharmacotherapy, social and recreational activities for patients, and educational materials for caregivers | Agitation/Aggression: NR General behavior NPI, mean (SD) Postintervention: 68.1 (10.2) vs. 84.5 (9.8) 6 month postintervention: 64.2 (11.8) vs. 85.1 (12.1); significant lower symptom severity in treatment group (p<0.01) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR | Caregiver Behavior: NR Antipsychotic Use: NR Caregiver Distress: NR Caregiver Burden Family Caregiver Burden Inventory, mean (SD) Postintervention: 56.7 (15.7) vs. 63.0 (15.1) 6 month postintervention: 48.3 (13.9) vs. 65.9 (16.3); significantly lower burden in treatment group (p<0.001) Caregiver QoL WHO-QoL, mean (SD) Postintervention: 75.1 (16.8) vs. 69.8 (16.7) 6 month postintervention: 81.4 (16.0) vs. 65.2 (17.5); higher QoL in treatment group (p<0.001)
Interventions addressing skills-knowledge (k=6)
de Rotrou, 2011^126^ France Psychoeducational program vs. usual care n=167 dyads Low risk of bias | Treatment: Group sessions of 6-10 caregivers to deliver education on dementia, problem-solving techniques, emotion-centered coping, behavior management, communication skills, crisis management, and resources; debriefing and ecological stimulation used; - weekly 2-hour sessions over 12 weeks; - psychologists and experienced geriatric health professionals; Comparison: Waitlist | Agitation/Aggression: NR General behavior: NPI – Mean(SD) at 6 mo: 15.8(16.0) vs. 14.2(13.0); p=0.57 Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR | Caregiver Behavior: NR Antipsychotic Use: NR Caregiver Distress: NR Caregiver Burden: ZBI – Mean (SD) at 6 mo: 23.0 (14.6) vs. 26.5 (17.0); p=0.25 Caregiver QoL: NR
Klodnicka, 2011^139^ Canada Psychoeducational communication intervention vs. information pamphlet n=50 Low risk of bias | Treatment: Education on communication difficulties relating to cognitive limitations (concentration, attention, memory, orientation, reasoning, etc.); skill modelling and performance used; - weekly 90-120 minute sessions over 5 weeks; - nurse practitioner; Comparison: Information pamphlet on memory and communication | Agitation/Aggression: NR General behavior RMBPC (communication difficulties) – Adjusted mean (SD) at 6 weeks: 1.74 (0.55) vs. 1.70 (0.59); F=69.1 (p<0.001) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR | Caregiver Behavior: NR Antipsychotic Use: NR Caregiver Distress: NR Caregiver Burden: NR Caregiver QoL: NR
Gallagher-Thompson, 2010^127^ United States Psychoeducational skill training DVD vs. information control n=70 Low risk of bias | Treatment: DVD of role-playing with narrations, accompanying workbook, and home practice exercises on dementia, management of difficult behaviors, and stressful family situations (recognizing and changing stressful care recipient behaviors, effective communication with family and healthcare providers, accessing community resources, legal issues, and preparing for end-of-life care); - 2.5 hours of DVD footage used over 4 months; - delivered via DVD; Comparison: Two DVDs of information on dementia | Agitation/Aggression: NR General behavior RMBPC – Mean (SD) 4 months: 11.6 (5.2) vs. 11.0 (4.2); NS (p-value NR) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR | Caregiver Behavior: NR Antipsychotic Use: NR Caregiver Distress: NR Caregiver Burden: NR Caregiver QoL: NR
Gitlin, 2003^130^ RCT United States Environmental skill-building vs. usual care n=190 Competence-environmental press framework Moderate risk of bias | Treatment: Education about dementia and impact of home environment; instruction in problem solving and developing effective approaches to manage caregiving concerns that involve manipulating physical/social environment including cognitive reframing/validation; implementation of environmental strategies tailored to caregivers context; generalization of strategies;; - five 90-minute home visits and one 30-minute phone session; - occupational therapist; Comparison: Resource information at each outcome assessment point | General Behavior RMPBC no. of disruption-related behaviors AMD (CI): -.07 (-46 to .33) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR | Caregiver Behavior Perceived change in ability to manage caregiving AMD (CI): .12 (-.05 to .30) Mastery AMD (CI): .11 (-.05 to .27) Antipsychotic Use: NR Caregiver Burden: NR Caregiver distress Upset with disruptive behaviors (RMPBC subscale) AMD (CI): -.05 (-19 to .09) Caregiver QoL: NR
Teri, 2000^154^ RCT United States Behavioral Management Training vs. Haloperidol vs. placebo n=75 Moderate risk of bias (4 months) | Treatment: AD information; strategies for decreasing agitation/aggression, and structured in-/out-of-session assignments;; - 8 weekly & 3 biweekly sessions; - master's level therapists; Comparison 1: Haloperidol treatment began with 0.5 mg per day and was increased at the next visit by 0.5 mg per day unless the subject had at least moderately improved behavior, significant adverse events were noted, or the maximum dose was reached (3 mg/day) Comparison 2: Placebo | Agitation/Aggression Improved score on ADCS-CGIC RR (CI)=1.0 [0.7 to 1.4] Agitation CMAI MC (SD): -3.37 (11.45) vs. -7.26 (22.51) Agitation-ABID Frequency MC (SD): -3.61 (9.88) vs. -6.74 (16.22) General Behavior BRSD MC (SD): -3.56 (12.85) vs. -5.35 (22.41) RMBPC Total Frequency -0.08 (0.54) vs. -0.17 (0.65) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR | Caregiver Behavior: NR Antipsychotic Use: NR Caregiver Distress ABID Reaction MC (SD): -2.41 (6.71) vs. -3.27 (9.10) Caregiver Burden-SCB Subjective MC (SD): -2.95 (7.29) vs. -1.88 (8.89) Caregiver Burden-SCB Objective MC (SD): -1.23 (3.32) vs. -0.44 (3.22) Caregiver QoL: NR
Ulstein, 2007^152^ RCT United States Caregiver education vs. usual care n=180 Moderate risk of bias | Treatment: Education on symptoms and normal course of dementia, how to handle neuropsychiatric symptoms, available resources, and fostering care recipients' acceptance of help; pharmacological and nonpharmacological treatment; training on communication techniques and structured problem-solving; cognitive reframing; - one 3-hour educational program; six 120-minute group meetings over 4.5 months; - physicians (geriatricians and psychiatrists); Comparison: “Treatment as usual” at memory clinic not defined | General Behavior NPI-S, 4.5 month: MD in MC (SD)=0.8 (-3.61 to 5.28) NPI-S, 12 month MD in MC (SD)=-2.2 (-2.65 to 7.06) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR | Caregiver Behavior: NR Antipsychotic Use: NR Caregiver Burden RSS, 4.5 month: MD in MC (SD)=-0.1 (-2.50 to 2.32) RSS, 12 month MD in MC (SD)=-1.2 (-4.23 to 1.79) Caregiver Distress: NR Caregiver QoL: NR
Interventions addressing skills-behavior (k=9)
Gonzalez, 2014^134^ United States Resourcefulness training sessions vs. no treatment/information n=102 Moderate risk of bias | Treatment: Group sessions of 5-7 caregivers to identify problem behaviors and management strategies (cognitive behavioral skills: problem identification, coping, problem solving, priority setting, decisionmaking); - weekly 2-hour sessions over 6 weeks; - registered nurse; Comparison: binder of information on Alzheimer's disease, community resources, and new research | Agitation/Aggression: NR General behavior RMBPC – Adjusted mean (SD) at 12 weeks: 1.3 (0.6) vs. 1.6 (0.6); p=0.11 Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR | Caregiver Behavior: NR Antipsychotic Use: NR Caregiver Distress: NR Caregiver Burden Caregiver Role Strain (global strain subscale) – Mean (SD) at 12 weeks: 1.90 (0.88) vs. 1.85 (0.88); p=0.78 Caregiver QoL: NR
Huang, 2013^138^ Taiwan Behavior management program + telephone support vs. attention control n=129 dyads Moderate risk of bias | Treatment: In-home training to enhance behavior management, self-efficacy, and preparedness; education to identify timing/frequency and causative stressors of behavior problems, and modify environment to decrease stress; - visits 1 week, 2 weeks, 3 months, and 6 months after treatment initiation, and monthly phone calls over 6 months; - study nurse; Comparison: In-home, general information on dementia with written informational materials provided (written instruction + telephone support) | Agitation/Aggression CMAI – n (%) at 6 mo: 9 (16.4) vs. 14 (26.4); p=0.20 General behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR | Caregiver Behavior: NR Antipsychotic Use: NR Caregiver Distress: NR Caregiver Burden: NR Caregiver QoL: NR
Gitlin, 2010a131 RCT United States Care of Persons with Dementia in their Environments (COPE) vs. Attention Control n=209 Moderate risk of bias (4 months) | Treatment: Education on patient capabilities, potential effects of medications, pain, constipation, and dehydration; training to address caregiver-identified concerns and reduce stress (problem-solving, communication, engaging patients in activities, and simplifying tasks); - up to 10 sessions over 4 months with therapist, 1 face-to-face session and 1 telephone session with nurse; - occupational therapists, advance practice nurse; Comparison: Three 20-minute phone calls; education materials | Agitation/Aggression ABID AMD (CI)^a^: -.65 (-3.05 to 1.74) Patient QoL-AD AMD (CI)^a^: 0.10 (0.00 to 0.20) General Behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR | Caregiver Behavior Confidence using activities AMD (CI)^a^: 0.81 (0.30 to 1.32) Antipsychotic Use: NR Caregiver Burden Perceived change in wellbeing AMD (CI)^a^: 0.22 (0.08 to 0.36)
Gitlin, 2010b132 RCT In-home caregiver training vs. attention control n=239 at 16 weeks; n=220 at 24 weeks Low to moderate risk of bias | Treatment: Advancing Caregiving Training in strategies to modify triggers and reduce care recipient upset; - 9 home sessions with OT, 1 home, and 1 phone nursing sessions over 16 weeks; 3 maintenance phone calls between 16 and 24 weeks; - health professional; Comparison: No contact | General Behavior Improvement in occurrence of targeted behavior, 16 weeks 67.5% vs. 45.8%; p=.002 Target symptoms worsened/stayed the same, 16 weeks 18.4%/14% vs. 31.7%%/22.5%; p>.05 Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR | Caregiver Behavior Confidence managing behavior 16 weeks AMD (CI)^b^: 0.33 (0.08 to 0.58) 24 weeks: 71.9% vs 29.1%; χ^2^=41.1; p=.001 Antipsychotic Use: NR Caregiver Burden ZBS, 16 weeks AMD (CI) b: -1.37 (-2.75 to 0.01) ZBS, 24 weeks AMD (CI) b: -1.61 (-3.13 to -0.09) Behavior upset overall, 16 weeks AMD (CI) b: -1.07 (-1.57 to -0.56) Behavior upset overall, 24 weeks AMD (CI) b: -0.82 (-1.34 to -0.29) Caregiver Wellbeing Perceived Change Index, 16 weeks AMD (CI) b: 0.45 (0.29 to 0.62) Perceived Change Index, 24 weeks AMD (CI) b: 0.29 (0.14 to 0.44)
Gitlin, 2008^129^ RCT United States Tailored Activity Program vs. waitlist/information control n=56 Low risk of bias | Treatment: One activity prescription based upon assessment with information, role-playing, direct demonstration with patient; stress management techniques; - 8 sessions [6 90-minute home visits and 2 15-minute phone sessions] over 4 months; - occupational therapists; Comparison: Resource information at each assessment | Agitation/Aggression Specific Behaviors-agitated AMD (CI)^c^: .06 (.01 to .56) Behavioral Occurrences AMD (CI)^c^: -.32 (-.55 to -.09) Number of Behaviors^d^ AMD (CI)^c^: -.98 (-2.67 to .71) General Behavior: NR Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR | Caregiver Behavior Mastery AMD (CI)^c^: .34 (.08 to .60) Confidence using activities AMD (CI)^c^: 1.67 (.41 to 2.94) Strategy use AMD (CI)^c^: 0.25; (0.04 to 0.46) Antipsychotic Use: NR Caregiver Burden ZBS Subjective - Behavior Upset AMD (CI) c: -.01 (-1.21 to 1.18) ZBS Subjective - Burden AMD (CI) c: .75 (-3.36 to 4.85) Caregiver Distress: NR Caregiver QoL: NR
Bourgeois, 2002^122^ RCT United States Patient-focused skills training vs. caregiver-focused skills training vs. attention control n=63 Moderate risk of bias | Treatment 1: Patient-focused behavior change – in-home training to identify most frequent problem behaviors and corresponding antecedents/consequences, and formulate behavior management plans; used cues, diversion, and prompting depending on behavior type. Group session focused on antecedent-behavior-consequence relationship of dementia symptoms. Treatment 2: Caregiver coping skills– in-home training to increase pleasant events, improve problem solving skills, and learn relaxation techniques. Group session focused on self-change strategies. Comparison: In-home sessions with general information with handouts, and general suggestions for problem behaviors. Group session focused on stages of family adjustment to Alzheimer's disease.; - 12 1-hour weekly in-home training sessions, one 3-hour group workshop; - project staff, trained research assistants | Agitation/Aggression: BEHAVE-AD aggressivility/activity disturbance subscale – adjusted mean (SD) at 6 months: 5.6 (3.8) vs. 5.2 (3.6) vs. 8.4 (2.4); treatment 1 significantly lower than control (p<0.05); treatment 2 significantly lower than control (p<0.01) General behavior: BEHAVE-AD total score – Adjusted mean (SD) at 6 months: 17.5 (10.4) vs. 14.8 (10.5) vs. 23.1 (11.4); treatment 2 score significantly lower than control (p<0.01) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR | Caregiver Behavior: NR Antipsychotic Use: NR Caregiver Distress: NR Caregiver Burden: NR Caregiver QoL: NR
Gerdner, 2002^128^ PLST training program vs. attention control n=237 Moderate risk of bias | Treatment: Individualized care plan (structured routine with environmental modifications, engaging activities, reduced screen time); review, education, written summary of care plan; - 2 sessions; 4 hours total; - research associate; Comparison: Two one-hour visits of information on ADRD (Alzheimer's Disease and Related Disorders), referral to community services, local support groups, and case management; caregiver book; related information pamphlets; notebooks (content differed according to treatment - not further explained) | General Behavior MBPC frequency (hierarchical linear model): Coefficient (SE) Nonspouse experimental: REF Nonspouse comparison: 0.77 (0.36); p<.001 Spouse experimental: 0.18 (0.26) Spouse comparison: 0.18 (0.26) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR | Caregiver Behavior: NR Antipsychotic Use: NR Caregiver Burden: NR Caregiver distress MBPC reaction hierarchical linear model estimate -0.39; SE 0.18; p<.01 Caregiver QoL: NR
Gormley, 2001^135^ RCT United States Behavior management of aggression in dementia vs. sham treatment n=62 Moderate risk of bias | Treatment: Training to identify precipitating and maintaining factors; behavioral interventions suggested by behavioral analysis; - 4 sessions over 8 weeks; - study author; Comparison: Equivalent number of group sessions; discussions of care-related issues with advice regarding local services (no behavior change) | Agitation/Aggression RAGE, baseline Mean (SD)=9.2 (3.8) vs. 8.8 (2.9) RAGE, postintervention Mean (SD)=6.9 (3.6) vs. 8.6 (4.5) General Behavior BEHAVE-AD, baseline Mean (SD)=8.0 (3.7) vs. 8.0 (4.0) BEHAVE-AD, postintervention Mean (SD)=6.5 (2.8) vs. 7.8 (3.4) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR | Caregiver Behavior: NR Antipsychotic Use Taking psychotropic drugs Baseline, n/N (%) 20 (58.8) vs. 16 (57.1) Postintervention, n/N (%) 18 (52.9) vs. 17 (60.7) RR: 0.87 (0.56 to 1.35) Caregiver Burden ZBS, baseline: Mean (SD)=38.6 (13.9) vs. 39.5 (13.0) ZBS, postintervention Mean (SD)=36 (12.3) vs. 41.2 (12.0)
Marriott, 2000^140^ RCT United States Family intervention vs. attention control vs. no treatment n=42 Moderate risk of bias | Treatment: Education based on assessment using knowledge about dementia interview; provided general AD information and practical advice on management; stress management; coping skills training; - 14 biweekly sessions; - clinical psychologist; Comparison 1: Audiotaped semi-structured interview to assess caregiving situation and unmet needs, but no intervention Comparison 2: No interview or intervention | General Behavior MOUSE-PAD-Behavioral disturbance Baseline, mean (SD): 5.1 (2.1) vs. 5.4 (2.5) vs. 5.1 (2.2) Post-treatment, mean (SD): 4.9 (0.2) vs. 5.0 (0.2) vs. 5.6 (0.2) Postintervention, mean (SD): 5.3 (2.0) vs. 5.5 (2.4) vs. 5.2 (2.0) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR | Caregiver Behavior: NR Antipsychotic Use: NR Caregiver Burden: NR Caregiver Distress: NR Caregiver QoL: NR
Interventions addressing skills-affect (k=2)
Belle, 2006^121^ RCT United States Results reported by race REACH II vs. waitlist/attention control Hispanic or Latino n=168 REACH II vs. attention control White n=182 REACH II vs. attention control Black n=168 Moderate risk of bias | Treatment: Range of strategies tailored to needs (could include information, didactic instruction, role playing, problem solving, skills training, stress management, telephone support groups); - 12 sessions [nine 1.5 hour in-home sessions, three 30-minute telephone sessions, and five telephone support sessions]; - certified college graduate interventionist; Comparison: Two brief check-in phone calls; educational materials | Hispanic or Latino: General Behavior Problem behavior: Change (%) in net improvement (CI): 36.3 (13.2 to 56.7) Long term care admission RR (95% CI): 0.17 (0.02 to 1.36) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR White: General Behavior Problem behavior: Change (%) in net improvement (CI): 13.6 (-6.3 to 35.3) Long term care admission RR (95% CI): 0.51 (0.21 to 1.22) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR Black: General Behavior Problem behavior: Change (%) in net improvement (CI): -3.6 (-25.2 to 16.7) Long term care admission RR (95% CI): 1.54 (0.45 to 5.31) Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR | Hispanic or Latino: Caregiver Behavior: NR Antipsychotic Use: NR Caregiver Burden Change (%) in net improvement (CI): -4.2 (-16.9 to 25.7) Caregiver distress: NR Caregiver QoL: NR White: Caregiver Behavior: NR Antipsychotic Use: NR Caregiver Burden Change (%) in net improvement (CI): -4.6 (-23.7 to 15.4) Caregiver distress: NR Caregiver QoL: NR Black: Caregiver Behavior: NR Antipsychotic Use: NR Caregiver Burden Change (%) in net improvement (CI): 23.1 (0.6 to 45.7) Caregiver distress: NR Caregiver QoL: NR
Mittelman, 2004^141^ RCT United States Caregiver intervention vs. usual care/attention control n=406 Moderate risk of bias | Treatment: Individual and family counseling sessions tailored to needs assessment; weekly support groups [beginning in month 5; indefinitely]; ad hoc counseling via phone as needed; - 2 individual, 4 family sessions over 4 months; - counselors; Comparison: Informational resources, advice when requested by caregivers, support available elsewhere; requests for in-person information and counseling not refused | General Behavior MBPC-frequency log growth model: Estimate for group (SE): 0.24 (1.23); p=.84 Estimate for group × time (SE): -0.03 (0.86); p=.96 Patient Distress, QoL: NR Nursing Home Admission: NR Adverse effects: NR | Caregiver Behavior: NR Antipsychotic Use: NR Caregiver Burden: NR Caregiver distress MBPC-reaction: Estimate for group (SE): -2.90 (1.27) p=.02 Estimate for group × time (SE): -1.86; (0.89) p=.04 Caregiver QoL: NR

ABID = Agitated Behavior in Dementia Scale; ADCS-CGIC = Alzheimer's Disease Cooperative Study-Clinical Global Impression of Change; AMD = adjusted mean change; ASMD = adjusted standardized mean difference; BEHAVE-AD = Behavioral Pathology in Alzheimer's disease; BRSD = CERAD Behavior Rating Scale for Dementia; CI = confidence interval; CMAI = Cohen-Mansfield Agitation Inventory; DEMQoL = Dementia Quality of Life measure; MBPC = Memory and Behavior Problem Checklist; MC = mean change NPI-Q = Neuropsychiatric Inventory Questionnaire; NPI-S = Neuropsychiatric Inventory Questionnaire Score; NR = not reported; NS = not significant; QoL = quality of life; QoL-AD = Quality of Life in Alzheimer's Disease; RAGE = Rating Scale for Aggressive Behavior in the Elderly; RCT = randomized controlled trial; RMBPC = Revised Memory and Behavior Problem Checklist; RR = risk ratio; SCB = Screen for Caregiver Burden; SD = standard deviation; SE = standard error; WHO-QoL= World Health Organization Quality of Life; WHO-QoL-Brief, Psych = World Health Organization Quality of Life, short form – psychological questions; ZBS = Zarit Burden Scale

a adjusted for living arrangement (alone vs. with caregiver) and baseline value of dependent variable

b adjusted for baseline value, caregiver gender and relationship to patient

c analysis adjusted for baseline value, care recipient cognitive status (MMSE) and number of ADL dependencies, caregiver age, gender, education, relationship to the care recipient

d Behavioral outcomes included occurrence of each of 24 behaviors (16 from ABDS and 2 from RMBPC and 2 others identified by families). For each behavior, families indicated yes if behavior occurred and how many times. Behaviors reported as constantly occurred were scored 300.

#### Interventions Addressing Caregiver Knowledge and Skills

We identified two eligible trials that primarily addressed knowledge and secondarily addressed skills.136 Guerra et al. randomized 58 caregiver-care recipient dyads to intervention (n = 29) or waitlist (n = 29).136 The mean age of caregivers was 51 years and 85 percent were female. The mean age of care recipients was 82 years and 74 percent were female. The intervention used the Helping Carers to Care model, designed for use in diverse low- and middle-income countries. The intervention was delivered by ‘junior’ psychologists and social workers. It is unclear what ‘junior’ means in this perspective. Three modules were delivered through five 30-minute weekly sessions that included assessment, basic education about dementia, and tailored training for identified problem behaviors. The waitlist group received the intervention after 6 months. Postintervention assessments occurred after 6 months. Patient agitation/aggression was not specifically measured; general behavior measured with the NPI-Q severity scores. General behavior was similar between groups at 6-month postintervention. Care recipient quality of life measured with the DEMQOL. Adjusted standardized mean changes was similar between intervention and comparison groups at 6-month postintervention. Intervention and comparison groups also showed similar postintervention changes in secondary outcomes of caregiver burden, distress, and quality of life as measured by the ZBI, the NPI-Q caregiver distress score, and the WHOQOL-BREF, respectively.

In their Minnesota Family Workshop trial, Ostwald et al. randomized 117 caregiver-care recipient dyads to an intervention group (n = 72) or waitlist (n = 45).144 A high percentage of the caregivers were female (65%) while a little more than half of the care recipients were male (51%). The mean age of caregivers was 66 years and the mean age of care recipients was 77 years. The intervention group received seven weekly 2-hour training sessions in a classroom format, including homework and readings. The first four sessions included general education and videos about dementia and its impacts on others. The fifth session included videos of the participants being assessed with the Cognitive Performance Test, the results of which were given to participants. The final two sessions included skill development and mastery. Care recipients were invited to a daycare-like setting with activities tailored to their functional level. The waitlist group received the intervention after 5-6 months. Postintervention assessments occurred at 3 months and 5 months after baseline. Patient general behavior was measured using RMBPC, disruptive behaviors subscale.144 Mean scores were similar with intervention and comparison at both postintervention time points. No intermediate outcomes were measured. Two secondary outcomes were reported. Caregiver burden as measured by the ZBI was similar with intervention and comparison, but there was a significant intervention by time interaction (F [2, 156] = 5.53, p=0.005). Caregiver distress measured by the RMBPC response to disruptive behaviors was similar in both groups at both time points with a significant intervention by time interaction (F [2, 164] = 4.60, p=0.01).

##### Evidence Synthesis and Strength of Evidence

These small trials provided insufficient evidence to draw conclusions about the effectiveness of caregiver interventions addressing knowledge and skills managing agitation/aggression in community-dwelling individuals with dementia.

#### Interventions Addressing Caregiver Knowledge and Affect

One trial studied an intervention with objectives of improving caregiver knowledge primarily and affect secondarily. Chien et al. randomized 88 caregiver-care recipient dyads to personalized dementia care management (n=44) or standard care (n=44).125 The mean age of caregivers was 44 years and 64 percent were female The mean age of care recipients was 68 years and 43 percent were female. Caregivers attended 12 2-hour sessions every other week over 6 months. A trained case manager identified problem areas and designed a personalized program to educate the caregiver about dementia care, family role and strength rebuilding, and community support resources. Caregivers in the comparison group attended monthly education sessions, received educational materials, and care recipients received “usual” pharmacotherapy (not specified) and social and recreational activities. General behavior was measured with the NPI at baseline, 6 months (immediate postintervention), and 6-month postintervention. Mean neuropsychiatric symptoms at immediate postintervention were significantly lower in the intervention group compared with the comparison group. It was unclear if this significance was sustained at 6-month postintervention. Two scales assessed secondary outcomes (caregiver burden measured by Family Caregiver Burden Inventory, caregiver QoL measured by WHO-QoL) at baseline, posttreatment, and 6-month postintervention. Mean burden was significantly lower and mean QoL was significantly higher in the intervention group at immediate postintervention compared with comparison. It was unclear if this significance was sustained at 6-month postintervention. No intermediate outcomes were reported.

##### Evidence Synthesis and Strength of Evidence

These trials provided insufficient evidence to draw conclusions for any outcome.

#### Interventions Addressing Caregiver Skills and Knowledge

We identified six trials studying interventions addressing caregiver skills and knowledge. Five of these trials compared interventions targeting skills and knowledge with no treatment. One compared the intervention with an antipsychotic medication.

De Routrou et al. randomized 167 caregiver-patient dyads to a psychoeducational program (n=79) or usual care (n=78).126 The mean age of caregivers was 65 years and 68 percent were female. The mean age of patients was 79 years and 60 percent were female. Patients had been diagnosed with Alzheimer's disease. Caregivers attended weekly 2-hour sessions over 12 weeks. Small groups of 6-10 caregivers were led by psychologists and experienced geriatric health professionals to deliver education on dementia, problem-solving techniques, emotion-centered coping, behavior management, communication skills, and available resources. Caregivers in the comparison group were on a waitlist; usual care was not defined. General behavior was measured with NPI at baseline, postintervention (3-month intervention) and 3-month postintervention. Mean neuropsychiatric symptoms at postintervention and 3-month postintervention were not significantly different between groups. Caregiver burden was measured with the ZBI at baseline, postintervention (3-month intervention), and 3-month postintervention. Mean caregiver burden at postintervention and 3-month postintervention was not significantly different between groups. No intermediate outcomes were reported.

Klodnicka et al. randomized 50 caregivers to a psychoeducational communication intervention (n=25) or usual care (n=25).139 The mean age of caregivers was 62 years and 82 percent were female. Patients had been diagnosed with cognitive problems likely associated with early stages of Alzheimer's disease. Caregivers attended weekly 90- to 120-minute sessions over 5 weeks. Sessions provided education on communication difficulties relating to cognitive limitations and incorporated skill modelling and performance. Caregivers in the comparison group received an information pamphlet on memory and communication. General behavior was measured with the RMBPC at baseline, 1 week postintervention, and 6-weeks postintervention. Adjusted mean problem behaviors at postintervention and 6-weeks postintervention were lower in the intervention group compared with usual care. No secondary or intermediate outcomes were reported.

Gallagher-Thompson et al. randomized 70 caregivers to receive a psychoeducation skill training DVD (n=36) or educational DVD (n=34).127 The mean age of caregivers was 59 years and 87 percent were female. The mean age of care recipients was 83 years and gender was not reported. Care recipients had significant memory loss or deteriorating cognition for at least 6 months. Caregivers in the intervention group watched 2.5 hours of footage over 4 months of role-played situations with narrations, accompanying workbook, and exercises to practice at home. Psychoeducation focused on dementia, managing difficult behaviors (recognizing and changing stressful behaviors), managing stressful family situations (communication with family and healthcare providers), and accessing other resources (legal issues, community resources, preparing for end-of-life). Caregivers in the comparison group received two DVDs of information on dementia. General behavior was measured with the RMBPC at baseline and postintervention (4 month intervention). Mean problem behaviors at postintervention were no different between groups. No secondary or intermediate outcomes were reported.

Ulstein et al. randomized 180 caregiver and care recipient dyads to a tailored education and training program with caregiver psychosocial components (n = 90) or usual care (n = 90).152 The mean age of caregivers was 65 years and 64 percent were female. The mean age of care recipients was 76 years and 56 percent were female. The intervention took place over 4.5 months and included a 3-hour physician-led education session that included information about the course of dementia and different treatment options. The intervention also included six 2-hour group meetings focused on communication techniques, problem-solving, and cognitive techniques. Usual care was not defined. Outcomes were assessed postintervention and at postintervention (12 months). General behavior measured with the NPI-S was similar with intervention and comparison postintervention and at postintervention. No intermediate outcomes were reported. Caregiver burden measured with the Relatives' Stress Scale (RSS) was similar with intervention and comparison postintervention and at postintervention.

Gitlin et al. in their REACH trial, randomized 255 caregiver-care recipient dyads to an Environmental Skill-Building Program (ESP) or usual care.153 The mean age of caregivers was 61 years, 76 percent were female, 45 percent were white, and 53 percent were African American. The mean age of care recipients was 81 years and 68 percent were female. The ESP intervention included five 90-minute home visits and one 30-minute telephone contact over 6 months with an occupational therapist, developing a tailored plan after a needs assessment at the first home visit with the caregiver. The tailored plans could address or recommend environmental factors, education, and community resources. Caregivers were given a form outlining the tailored strategies. In future visits, the dementia education was reinforced, caregivers were observed using previously discussed strategies, strategies were further refined, and new recommendations were given regarding cognitive restructuring and validation. The 6-month analysis included 190 caregivers (89 in ESP group and 101 in usual care). General behavior measured with the RMBPC frequency scale was similar with intervention and comparison. Intermediate outcomes of mastery managing behaviors measured with the Caregiving Mastery Index and ability to manage caregiving measured by the Perceived Change Index were similar between groups. Caregiver distress measured with the RMBPC reaction to disruptive behaviors scale was also similar with intervention and comparison.

One trial evaluated interventions primarily aimed at educating caregivers about dementia and how to address common situations.154 For caregivers, mean age was 65.5 years and 68.2 percent were female. For care recipients, mean age was 75 years, 55 percent were female, and 86 percent were white. Teri et al. randomized 148 caregiver and care recipient dyads to a behavior management group (n = 41), an antipsychotic treatment group with haloperidol (n = 34), trazodone (n = 37), and placebo (n = 36).154 The only treatment arms relevant to our KQ were behavior management and haloperidol. The behavior management intervention consisted of 11 therapist-led sessions (eight weekly and three biweekly) over 4 months. The sessions provided information about Alzheimer's disease, strategies for decreasing agitation/aggression, structured assignments, and videotape training. Treatment began with 0.5 mg per day and was increased at the next visit by 0.5 mg per day unless the subject had at least moderately improved behavior, significant adverse events were noted, or the maximum dose was reached (3 mg/day). Assessments occurred at baseline, 9 weeks (midpoint of intervention period), 4 months (conclusion of intervention), and 3 months, 6 months, and 12 months postintervention. Agitation/aggression was measured with three different instruments: a dichotomous variable measuring improvement based on change in Alzheimer's Disease Cooperative Study-Clinical Global Impression of Change (ADCS-CGIC); continuous variables based upon scores on the ABID frequency scale, and the CMAI. General behavior was measured with the BRSD. Changes from baseline were similar between the behavior management and haloperidol treatment groups for each of these instruments. No intermediate outcomes were reported. Changes in caregiver burden, measured with the Screen for Caregiver Burden (SCB), and changes in caregiver distress, as measured with the ABID reaction scale, also were similar in these two treatment groups.145,154 Harms comparison was important for this study because one arm was an antipsychotic. Behavior management had statistically significantly fewer symptoms of parkinsonian gait and bradykinesia (0% and 0%, respectively) compared with haloperidol (22% and 33%, respectively). There were no differences between groups for the following adverse effects: drooling, dry mouth, dizziness, akathisia, rigidity, dyskinesia, drowsiness, tremor, and fatigue.

##### Evidence Synthesis and Strength of Evidence

Low strength evidence shows that interventions targeting caregiver skills and knowledge were similar to no treatment in managing patient general behavior. Evidence was insufficient to draw conclusions for any other outcome. Few trials measured similar outcomes, and when they did, methodological limitations and imprecision were apparent. Often trials did not show statistical differences in outcomes, but precision was not sufficient to conclude a lack of effectiveness.

#### Interventions Addressing Caregiver Skills and Behavior

We identified nine trials that primarily addressed caregiver skills and secondarily behavior. Gonzalez et al. randomized 102 caregivers to group resourcefulness training (n=50) or no treatment (n=52).134,155 The mean age of caregivers was 60 years and 97 percent were female. The mean age of patients was 80 years and 58 percent were female. Patients had been diagnosed with Alzheimer's disease. Caregivers attended weekly 2-hour sessions over 6 weeks. Groups of five to seven caregivers were led by a registered nurse to identify problem behaviors and management strategies, such as coping skills, problem solving, priority setting, and decisionmaking. Participants in the comparison group received a binder of information on Alzheimer's disease, availability of community resources, and information on recent research. One scale assessed primary outcomes (general behavior measured with RMBPC) at baseline, postintervention (6-week intervention), and 3-month postintervention. Adjusted mean problem behavior frequency at postintervention and 3-month postintervention was not significantly different between groups. One scale assessed secondary outcomes (caregiver burden measured with Caregiver Role Strain—global strain subscale) at baseline, postintervention (6-week intervention), and 3-month postintervention. Adjusted mean caregiver burden at postintervention and 3-month postintervention was not significantly different between groups. No intermediate outcomes were reported.

Huang et al. randomized 129 caregiver-care recipient dyads to a behavior management program with telephone support (n=63) or written instructions with social telephone postintervention (n=66).138 The mean age of caregivers was 55 years and 75 percent were female. The mean age of patients was 80 years and 54 percent were female. Patients had been diagnosed with dementia. Caregivers received in-home visits from a study nurse 1 week, 2 weeks, 3 months, and 6 months after study initiation, as well as monthly phone calls during the 6 months. Training focused on enhancing behavior management, self-efficacy, and preparedness to identify stressors and problem behaviors, and ultimately to modify the environment to decrease these stressors. The attention comparison received in-home visits of general information on dementia with written informational materials. One scale assessed primary outcomes (agitation/aggression measured by CMAI) at baseline, 2 weeks, 3 months, and 6 months postintervention. The number of aggressive behaviors reported at postintervention was not significantly different between groups. No secondary or intermediate outcomes were reported.

Gitlin et al. randomized 237 caregiver-care recipient dyads in their Care of Persons with Dementia in their Environments (COPE) trial.131 The mean age of caregivers was 62 years, 89 percent were female, 70 percent were white, and 28 were African American. The mean age of the care recipients was 82 years; 68 percent were female, 70 percent were white, and 27 percent were African American. The staff used scripts to ask caregivers about challenges, mailed informational brochures, and reviewed materials in subsequent calls to the caregivers. The intervention consisted of up to 10 sessions with an occupational therapist, one face-to-face session with an advance practice nurse, and one telephone session with an advanced practice nurse over 4 months. Each caregiver was exposed to all of the components of the intervention, including: assessments, caregiver education, and caregiver training to address caregiver-identified concerns and help them reduce stress. Tailored training was given to all caregivers in problem-solving, communication, engaging patients in activities, and simplifying tasks, based on their concerns and patient capabilities. The comparison group (n = 107 for analysis) received up to three 20-minute telephone calls from trained research staff over 4 months. Postintervention agitation/aggression (ABID scores) and patient quality of life (QoL-AD) were similar with intervention and comparison. Caregivers in the intervention group reported greater confidence using activities to manage behaviors measured with an investigator-developed Likert scale with five questions (adjusted mean difference 0.81; 95% CI: 0.30-1.32; Cohen d=0.54). Effect size was moderate according to Cohen's d; scores declined from baseline by 1 percent in the control group and improved by 14 percent in the intervention group.131 Caregiver burden measured using the perceived change in wellbeing improved more in the intervention group (15% vs. 4%; adjusted mean difference 0.22; 95% CI: 0.08-0.36; Cohen d=0.30). This between-group difference represented a small effect size according to Cohen d.

In their Advancing Caregiver Training (ACT) trial, Gitlin et al. randomized 272 care recipient dyads to ACT (n = 137) or no treatment (n = 135).132 The mean age of caregivers was 66 years, 82 percent were female, and 69 percent were white. The mean age of care recipients was 82 years, 53 percent were female, and 69 percent were white. ACT participants received up to 11 home and telephone contacts by health professionals over 4 months, including up to nine occupational therapy sessions and two nursing sessions. Caregivers identified behaviors most upsetting to them. Health professionals then identified communication and environmental triggers of care recipient behaviors along with undiagnosed patient health conditions (through blood and urine samples). Health professionals then trained caregivers in strategies to modify triggers and reduce care recipient upset. Three telephone contacts to reinforce strategy use occurred between 4 and 6 months. Comparison participants were offered a 2-hour in-home education and problem behavior management workshop after the 6-month postintervention. Caregivers selected a wide variety of behaviors to target during the intervention. Frequently mentioned targeted behaviors included refusing care (15%), repetitive questioning (11%), argumentation (8%), waking up at night (8%), toileting problems (8%), verbal aggression (8%), wandering (7%), inappropriate behavior (i.e., loud, destructive) (6%), upset or agitation (5%), safety concerns (5%), and delusions (5%).132

Postintervention outcomes were assessed at 4 months for 117 dyads in the intervention group and 122 dyads in the comparison group, and postintervention outcomes at 6 months for 106 dyads in the intervention group and 114 dyads in the comparison group. ACT caregivers were more likely than comparisons to report reductions in the problem behavior (67.5% vs. 45.8%; χ^2^=8.7; p=.002). The percentage of caregivers who reported that symptoms worsened (18.4% vs. 31.7%; p>.05) or stayed the same (14.0% vs. 22.5%; p>.05) was similar in the intervention and comparison groups. Confidence managing target problem behavior as measured by an investigator-developed Likert scale, improved more with intervention than control (20% vs. 10%; adjusted mean difference 0.33; 95% CI: 0.08-0.58; Cohen's d=.30). The effect size was small according to Cohen's d.132 ACT participants reported significantly higher confidence managing behaviors at postintervention on an investigator-developed postintervention questionnaire to ascertain perceived benefits ([unadjusted] 71.9% vs. 29.1%; χ^2^=41.1; p=.001). Secondary outcomes were reported at postintervention (4 months) and at postintervention (6 months).132 Caregiver burden as measured by ZBI was similar with intervention and comparison postintervention, but had significantly improved with a moderate effect size with intervention at postintervention (adjusted mean difference -1.61; 95% CI: -3.13 to -0.09; d=.67). The effect size was moderate according to Cohen's d; mean scores in the intervention group were over 10 percent higher than in the comparison group at 6 months. Caregiver behavior upset overall improved more with intervention than comparison at both time points (adjusted mean difference -1.07; 95% CI: -1.57 to -0.56; Cohen's d=.47 at 4 months; and -0.82; 95% CI: -1.34 to -0.29; Cohen's d=.43 at 6 months). Effect size was moderate according to Cohen's d; mean scores in the intervention group were over 15 percent higher than in the comparison group at both time points. Perceived change in caregiver wellbeing improved with intervention compared with comparison at both time points (adjusted mean difference 0.45; 95% CI: 0.29 to 0.62; Cohen's d=.62 at 4 months; and 0.29; 95% CI: 0.14 to 0.44; Cohen's d=.43 at 6 months). Effect sizes were moderate according to Cohen's d; mean scores in the intervention group were over 10 percent higher than in the comparison group at both time points.

In another trial, Gitlin et al. randomly assigned 60 caregiver and care recipient dyads to the Tailored Activity Program (TAP) (n = 30) or a waitlist (n = 30).129 The mean age of caregivers was 65 years and 88 percent were female. Caregivers were primarily white (77%). The mean age of care recipients was 79 years and 43 percent were female. TAP dyads received six 90-minute home visits and two 15-minute telephone contacts by occupational therapists over 4 months. Care recipient interests were ascertained and individual programs were presented to the caregiver at the next visits, including activities, goals, and implementation plans. Caregivers were instructed to use deep breathing techniques to manage stress. Waitlist participants received the intervention after the 4-month assessment. Fifty-six dyads were included in the analysis. Agitation/aggression was measured using an investigator-created checklist documenting the occurrence of 24 behaviors (16 from the ABID scale; two from the RMBPC [repetitive questioning/hoarding]; four from previous research [wandering, incontinent incidents, shadowing, boredom], and two others defined by each caregiver). The caregiver completed checklists were used to create two indices, number of behaviors occurring and the mean frequency of occurrence. All behaviors appear to be weighted equally. We classified this outcome as patient agitation/aggression because over half of the questions were from an agitation/aggression scale. Behavioral occurrences decreased more with intervention than comparison (adjusted mean difference = -0.32 points; 95% CI: -0.55-0.09, Cohen's d=0.72). Changes in the number of behaviors reported was similar with intervention and comparison. A binary analysis of specifically agitated behaviors showed a larger reduction with intervention than comparison (adjusted mean difference = 0.6; 95%; CI: 0.01-0.56, Cohen's d=0.75). The effect size was moderate according to Cohen d. Three intermediate outcomes measured using 5-item Likert scales improved more with intervention than comparison. Caregiver mastery improved more with intervention (adjusted mean difference 0.34; 95% CI: 0.08 to 0.60; Cohen's d=.55). Effect size was moderate according to Cohen d; mean score improved by nearly 10 percent with intervention but stayed the same with comparison. Confidence using activities improved more with intervention (adjusted mean difference 1.67; 95% CI: 0.41 to 2.94; Cohen's d=.74). Effect size was moderate according to Cohen d; mean score improved by nearly 40 percent with intervention, but only 3 percent with comparison. Strategy use improved more with intervention than control (adjusted mean difference 0.25; 95% CI: 0.04 to 0.46; Cohen's d=.71). Effect size was moderate according to Cohen d; mean score improved by less than 6 percent with intervention and 4 percent with comparison. Reductions in secondary outcomes of caregiver burden measured with the Zarit Burden and caregiver behavior upset measured on a Likert scale were similar with intervention and control

Bourgeois et al. randomized 63 caregivers to patient-focused skills training (n=22), caregiver-focused skills training (n=21) or attention control (n=20).122 The mean age of caregivers was 73 years and 54 percent were female. The mean age of patients was 75 years and 46 percent were female. Patients met diagnostic criteria for probable Alzheimer's disease. Caregivers received 12 weekly 1-hour in-home training sessions and attended one 3-hour group workshop to enhance skills training. The patient-focused group received training to identify problem behaviors, antecedents and consequences of problem behaviors, and develop a management plan. The caregiver-focused group received training to increase coping skills through increasing pleasant events, improving problem-solving, and learning relaxation techniques. The comparison group was an attention control which received general information and suggestions for problem behaviors. Two scales assessed primary outcomes (aggression/agitation measured by BEHAVE-AD aggressivity/activity disturbance subscale, general behavior measured by BEHAVE-AD total score) at baseline, postintervention (3-month intervention), 3 months postintervention, and 6 months postintervention. Both patient-change (p<0.05) and caregiver change (p<0.01) groups reported significantly lower aggressivity scores than comparison at 6-month postintervention. The caregiver change group reported significantly lower total scores than comparison at 6-month postintervention (p<0.01). Secondary and intermediate outcomes were not reported.

Gerdner et al. randomly assigned 241 caregiver and care recipient dyads, of which 237 were included in the analysis.128 The mean age of caregivers in the final analysis was 65 years and 74 percent were women. Caregivers were primarily white (94%). The mean age of care recipients was 77. The intervention group (n = 132) received individualized care plans that may have included structured routines and rest periods, environmental modifications, and care recipients' past interests in activities. Care plan information was communicated in person, environmental techniques were taught to the caregivers, and care plan information was provided in a written format. The intervention group participants received 4 hours of contact over two in-home visits 1 week apart. The comparison group (n = 105) received general information about Alzheimer's disease, community resources, a caregiver book, and other brochures. The comparison group participants received two 1-hour in-home visits scheduled 2 weeks apart, and were offered the intervention after study completion. Assessments occurred at baseline, 3 months, 6 months, and 12 months. One primary outcome, general behavior, was measured using the Memory and Behavior problems checklist frequency and analyzed based upon relationship with care recipient using a hierarchical linear model; no overall results were provided. Behavior problems increased significantly as reported by nonspouse caregivers in the comparison group (hierarchical linear model estimate 0.77; SE=0.36; p<.001) relative to the intervention group. Behavior problems were similar between spouse caregivers in intervention and comparison groups. No intermediate outcomes were reported. One secondary outcome, caregiver distress, was measured with the Memory and Behavior problems checklist reaction and analyzed using a hierarchical linear model without separating estimates by relationship. Caregivers in the intervention group decreased reactions to problem behaviors compared with those in the comparison group (hierarchical linear model estimate -0.39; SE 0.18; p<.01). Effect sizes for both of these outcomes is likely small given the 0 to 96 range on the instruments.

Gormley et al. randomized 62 caregiver-care recipient dyads to a behavioral management program (n = 34) or comparison group (n = 28).135 The intervention group received four sessions of behavior management training over 2 months. The mean age of caregivers was 68 and 60 percent were female. The mean age of care recipients was 76 and 53 percent were female. Caregivers were trained to identify precipitating factors for aggressive behaviors and subsequent sessions focused on tailored behavioral interventions and modifications. The comparison group received an equivalent number of sessions, consisting of discussions with caregivers and care recipients on care-related issues and recommendations for community resources. Postintervention agitation/aggression measured with the RAGE instrument and general behavior measured with BEHAV-AD were similar with intervention or comparison. Postintervention proportion of care recipients taking antipsychotic drugs and caregiver burden measured with the ZBI was also similar with intervention and comparison.

Marriott et al. randomized 42 caregiver-care recipient dyads to three groups: a family intervention group (n = 14), an interview comparison group (n = 14), and a no-interview comparison group (n = 14).140 The mean age of caregivers was 64 years and 69 percent were female. The mean age of care recipients was 77 years and 71 percent were female. The family intervention consisted of caregiver education (three sessions), stress management (six sessions), and coping skills training (five sessions) over a total of 14 sessions delivered biweekly. Total treatment duration was 7 months. Caregivers in the family intervention also received the Camberwell Family Interview (CFI), booklets about Alzheimer's disease, and booklets listing available services. The interview comparison group received the CFI, taking approximately 90 minutes, and the assessments. The no-interview comparison group received only the assessments. Assessments were conducted at baseline, postintervention, and at 3 months postintervention. General behavior, measured with the MOUSE-PAD instrument was similar across groups at each time point. The study reported a significant difference between the intervention group and the no-interview comparison but not the interview comparison group postintervention. No group differences were seen at postintervention. No intermediate or secondary outcomes were reported.

##### Evidence Synthesis and Strength of Evidence

Trials studying skills-behavior interventions used several types of comparisons. Two trials compared interventions with no treatment. Evidence on behavior was insufficient, but low strength evidence shows that skills-behavior interventions were similar to no treatment in managing caregiver burden. Evidence was insufficient for all other outcomes.

Five trials compared interventions targeting caregiver skills-behaviors with attention controls. Low strength evidence shows that these interventions are similar to attention control in managing care recipient agitation/aggression. However, moderate strength evidence shows that these interventions are better than attention control in improving caregiver caregiving abilities and managing caregiver distress. Evidence on other outcomes was insufficient.

Two trials compared interventions targeting caregiver skills-behaviors with sham treatments. These data provide insufficient evidence to draw conclusions for any outcome.

Trials rarely reported adverse effects. The interventions studied have a low risk for adverse effects.

#### Interventions Addressing Caregiver Skills and Affect

There were two eligible trials that studied interventions primarily addressing caregiver skills and secondarily affect. Belle et al., in their Resources for Enhancing Alzheimer's Caregiver Health (REACH) II trial, randomly assigned 642 caregiver-care recipient dyads to a multicomponent intervention (n=323) or an occasional contact comparison (n=319).121 The mean age of the caregivers included in the final analysis was 61 years and 85 percent were female. Of those caregivers included in the final analysis, 32 percent were Hispanic or Latino, 37 percent were white/Caucasian, and 32 percent were black/African American. The multicomponent intervention consisted of education and training to address problem behaviors as well as caregiver psychosocial support to address depression, burden, and self-care/healthy behaviors through 12 in-home or telephone sessions delivered over a 6-month period. Assessments occurred at baseline and 6 months. Results were reported by racial/ethnic group; overall results were not reported. Two primary outcomes were reported. Patient general behavior was measured using three questions from the RMBPC (covering domains of memory, depression, and disruption). We classified this outcome as general behavior as it consisted of components other than agitation/aggression. No intermediate outcomes were reported. The secondary outcome of caregiver burden was measured using 11 of the 12 items on the brief ZBI. The frequencies reported on the checklist and scores from the ZBI were used to calculate the number of dyads making clinically significant changes (defined as an unadjusted standardized change of +/- 0.5 standard deviation or more from baseline to postintervention). In the Hispanic/Latino subgroup, intervention caregivers were more likely than comparison caregivers to report that problem behaviors decreased (45% vs. 23%) and less likely to report that they worsened (13% vs. 28%). With a net of 36 percent (95% CI: 13.2 to 56.7) more intervention caregivers reporting a clinically significant improvement compared with the comparison caregivers. Hispanic/Latino caregivers in the intervention and comparison groups reported admission of care recipient to nursing home at similar rates. Hispanic/Latino intervention and comparison caregivers reported similar change in burden postintervention. White/Caucasian intervention and comparison caregivers reported similar changes in problem behaviors, admission of care recipient to nursing home, and caregiver burden. Black/African American intervention and comparison caregivers reported similar changes in problem behaviors and admission of care recipient to nursing home, but the intervention was associated with greater improvement in burden. Net burden was reduced in 23 percent more with intervention than comparison.

Mittelman et al. randomized 406 caregiver-care recipient dyads to counseling (n = 203) or usual care (n = 203).141 The mean age of caregivers was 71 years; 60 percent were female and 91 percent were white. The caregiver intervention included two individual and four family counseling sessions over the course of 4 months. The counseling sessions were tailored but focused on communication, problem solving, and management of patient behavior, caregiver support, and education and resources related to Alzheimer's disease. Each session was 1 to 3 hours long. After 4 months, caregivers in the treatment group were required to join weekly support groups. Counselors were continuously available for caregivers and families to deal with various problems. The comparison subjects received usual care (not described). Postintervention occurred every 4 months for the first year and every 6 months thereafter for 4 years after the start of the study. This publication reports agitation/aggression measured with the Memory and Behavior Problems Checklist. Data on problem behavior frequency and reaction were analyzed with a mixed model growth curve. Memory and Behavior Problem Checklist frequency was similar with intervention and comparison as indicated by the nonsignificance of the group variable and the group-time interaction in the model. Our secondary outcome of caregiver distress measured with the Memory and Behavior Problem Checklist reaction improved more with intervention than comparison as indicated by negative estimates and significance of the intervention variable (estimate -2.90; SE=1.27; p=.0226) and the intervention-time interaction (-1.86; SE=0.89; p=.04). The effect sizes are small and may not be clinically meaningful given the score range of 0–96 for this instrument.

##### Evidence Synthesis and Strength of Evidence

Two trials compared interventions addressing caregiver skills and affect with no treatment. This evidence was insufficient to draw conclusions given methodological limitations, imprecision, and inconsistent or unknown consistency with regard to specific outcomes, for all outcomes.