# References

1 American Psychiatric Association. Neurocognitive Disorders. Diagnostic and Statistical Manual of Mental Disorders. Fifth Edition. Arlington, VA. American Psychiatric Association. 2013.
2 Trivedi D, Goodman C, Dickinson A, et al. A protocol for a systematic review of research on managing behavioural and psychological symptoms in dementia for community-dwelling older people: evidence mapping and syntheses. Systematic reviews. 2013;2(1):1-9. [pmid: 23295105].
3 Dementia Initiative. Dementia Care: The Quality Chasm. Available at: www.leadingage.org/uploadedFiles/Content/Members/Nursing_Homes/Quality/DementiaCareTheQualityChasm.pdf. October 17, 2013.
4 Lyketsos CG, Carrillo MC, Ryan JM, et al. Neuropsychiatric symptoms in Alzheimer's disease. Alzheimer's & Dementia. Sep. 2011;7(5):532-9. [pmid: 21889116].
5 Black W, Almeida OP. A systematic review of the association between the Behavioral and Psychological Symptoms of Dementia and burden of care. Int Psychogeriatr. Sep. 2004;16(3):295-315. [pmid: 15559754].
6 Ornstein K, Gaugler JE. The problem with “problem behaviors”: a systematic review of the association between individual patient behavioral and psychological symptoms and caregiver depression and burden within the dementia patient-caregiver dyad. Int Psychogeriatr. Oct. 2012;24(10):1536-52. [pmid: 22612881].
7 Pinquart M, Sorensen S. Associations of stressors and uplifts of caregiving with caregiver burden and depressive mood: a meta-analysis. J Gerontol B Psychol Sci Soc Sci. Mar. 2003;58(2):P112-28. [pmid: 12646594].
8 Desai AK, Schwartz L, Grossberg GT. Behavioral disturbance in dementia. Curr Psychiatry Rep. 2012;14(4):298-309. [pmid: 22644311].
9 British Columbia Ministry of Health. Best Practice Guideline for Accommodating and Managing Behavioural and Psychological Symptoms of Dementia in Residential Care (the guideline). 2011.
10 Cohen-Mansfield J. Agitated behavior in persons with dementia: the relationship between type of behavior, its frequency, and its disruptiveness. J Psychiatr Res. Nov. 2008;43(1):64-9. [pmid: 18394647].
11 Volicer L. Toward better terminology of behavioral symptoms of dementia. J Am Med Dir Assoc. Jan. 2012;13(1):3-4. [pmid: 21450232].
12 Gill SS, Bronskill SE, Normand SL, et al. Antipsychotic drug use and mortality in older adults with dementia. [Summary for patients in Ann Intern Med. 2007 Jun 5;146(11):I52; PMID: 17548405]. Ann Intern Med. Jun. 5. 2007;146(11):775-86. [pmid: 17548409].
13 Schneider LS, Dagerman KS, Insel P. Risk of death with atypical antipsychotic drug treatment for dementia: meta-analysis of randomized placebo-controlled trials. JAMA. Oct. 19. 2005;294(15):1934-43. [pmid: 16234500].
14 Schneider LS, Tariot PN, Dagerman KS, et al. Effectiveness of atypical antipsychotic drugs in patients with Alzheimer's disease. N Engl J Med. Oct. 12. 2006;355(15):1525-38. [pmid: 17035647].
15 Moniz Cook ED, Swift K, James I, et al. Functional analysis-based interventions for challenging behaviour in dementia. Cochrane database of systematic reviews (Online). 2012;2. CD006929. [pmid: 22336826].
16 Mitka M. CMS seeks to reduce antipsychotic use in nursing home residents with dementia. JAMA. 2012;308(2):119-21. [pmid: 22782393].
17 Salzman C, Jeste DV, Meyer RE, et al. Elderly patients with dementia-related symptoms of severe agitation and aggression: consensus statement on treatment options, clinical trials methodology, and policy. J Clin Psychiatry. Jun. 2008;69(6):889-98. [pmid: 18494535].
18 A. P. A. Work Group on Alzheimer's Disease and other Dementias, Rabins PV, Blacker D, et al. American Psychiatric Association practice guideline for the treatment of patients with Alzheimer's disease and other dementias. Second edition. American Journal of Psychiatry. Dec. 2007;164(12 Suppl):5-56. [pmid: 18340692].
19 Lyketsos CG, Colenda CC, Beck C, et al. Position statement of the American Association for Geriatric Psychiatry regarding principles of care for patients with dementia resulting from Alzheimer disease. [Erratum appears in Am J Geriatr Psychiatry. 2006 Sep;14(9):808]. Am J Geriatr Psychiatry. Jul. 2006;14(7):561-72. [pmid: 16816009].
20 American Psychiatric Association Work Group on Alzheimer's Disease and other Dementias. Practice guidelines for the treatment of patients with Alzheimer's Disease and other dementias. 2nd ed. Am J Psychiatry. December. 2007;104(12 Suppl):5-56. [pmid: 18340692].
21 Cohen-Mansfield J. Nonpharmacologic treatment of behavioral disorders in dementia. Curr Treat Options Neurol. Dec. 2013;15(6):765-85. [pmid: 24136714].
22 Gitlin L, Marx K, Stanley I, et al. Assessing neuropsychiatric symptoms in people with dementia: a systematic review of measures. International psychogeriatrics/IPA. 2014:1-44. [pmid: 25096416].
23 Bogner JA, Corrigan JD, Stange M, et al. Reliability of the agitated behavior scale. The Journal of head trauma rehabilitation. 1999;14(1):91-6. [pmid: 9949251].
24 Cohen-Mansfield J. Conceptualization of agitation: results based on the Cohen-Mansfield Agitation Inventory and the Agitation Behavior Mapping Instrument. Int Psychogeriatr. Suppl 3. 1996;8:309-15. discussion 51-4. [pmid: 9154580].
25 Rosen J, Burgio L, Kollar M, et al. The Pittsburgh Agitation Scale: A User-Friendly Instrument for Rating Agitation in Dementia Patients. The American Journal of Geriatric Psychiatry. 1995;2(1):52-9. [pmid: 21629007].
26 Brodaty H, Draper BM, Low LF. Behavioural and psychological symptoms of dementia: a seven-tiered model of service delivery. Med J Aust. Mar. 3. 2003;178(5):231-4. [pmid: 12603188].
27 Gitlin LN, Kales HC, Lyketsos CG. Nonpharmacologic management of behavioral symptoms in dementia. JAMA. Nov. 21. 2012;308(19):2020-9. [pmid: 23168825].
28 Kales HC, Gitlin LN, Lyketsos CG, et al. Management of Neuropsychiatric Symptoms of Dementia in Clinical Settings: Recommendations from a Multidisciplinary Expert Panel. J Am Geriatr Soc. Apr. 2014;62(4):762-9. [pmid: 24635665].
29 Lawton MP, Van Haitsma K, Klapper J, et al. A stimulation-retreat special care unit for elders with dementing illness. International psychogeriatrics / IPA. 1998-. Dec. 1998;10(4):379-95. [pmid: 9924833].
30 Logsdon RG, Teri L, Weiner MF, et al. Assessment of agitation in Alzheimer's disease: the agitated behavior in dementia scale. Alzheimer's Disease Cooperative Study. J Am Geriatr Soc. Nov. 1999;47(11):1354-8. [pmid: 10573447].
31 Cohen-Mansfield J. Agitation in the elderly. Adv Psychosom Med. 1989;19:101-13. [pmid: 2686357].
32 Cohen-Mansfield J. Instruction Manual for the Cohen-Mansfield Agitation Inventory (CMAI). 1991.
33 Finkel SI, Lyons JS, Anderson RL. Reliability and validity of the Cohen–Mansfield agitation inventory in institutionalized elderly. Int J Geriatr Psychiatry. 1992;7(7):487-90. PMID.
34 Fox C, Crugel M, Maidment I, et al. Efficacy of memantine for agitation in Alzheimer's dementia: a randomised double-blind placebo controlled trial. PLoS ONE. 2012;7(5):e35185. [pmid: 22567095].
35 Ballard CG, O'Brien JT, Reichelt K, et al. Aromatherapy as a safe and effective treatment for the management of agitation in severe dementia: The results of a double-blind, placebo-controlled trial with Melissa. J Clin Psychiatry. 2002;63(7):553-8. [pmid: 12143909].
36 Baker R, Bell S, Baker E, et al. A randomized controlled trial of the effects of multi-sensory stimulation (MSS) for people with dementia. British Journal of Clinical Psychology. Mar. 2001;40:81-96. [pmid: 11317951].
37 Cummings JL, Mega M, Gray K, et al. The Neuropsychiatric Inventory: comprehensive assessment of psychopathology in dementia. Neurology. Dec. 1994;44(12):2308-14. [pmid: 7991117].
38 Howard R, Phillips P, Johnson T, et al. Determining the minimum clinically important differences for outcomes in the DOMINO trial. Int J Geriatr Psychiatry. Aug. 2011;26(8):812-7. [pmid: 20848576].
39 Teri L, Truax P, Logsdon R, et al. Assessment of behavioral problems in dementia: the revised memory and behavior problems checklist. Psychol Aging. Dec. 1992;7(4):622-31. [pmid: 1466831].
40 Zarit SH, Todd PA, Zarit JM. Subjective burden of husbands and wives as caregivers: a longitudinal study. Gerontologist. Jun. 1986;26(3):260-6. [pmid: 3721233].
41 Tariot PN. CERAD behavior rating scale for dementia. Int Psychogeriatr. Suppl 3. 1996;8:317-20. discussion 51-4. [pmid: 9154581].
42 Allen NH, Gordon S, Hope T, et al. Manchester and Oxford Universities Scale for the Psychopathological Assessment of Dementia (MOUSEPAD). Br J Psychiatry. Sep. 1996;169(3):293-307. [pmid: 8879715].
43 Greene J, Smith R, Gardner M, et al. Measuring behavioural disturbance of elderly demented patients in the community and its effects on relatives: a factor analytic study. Age and Ageing. 1982;11(2):121-6. [pmid: 7102472].
44 Baker R, Holloway J, Holtkamp CC, et al. Effects of multi-sensory stimulation for people with dementia. J Adv Nurs. Sep. 2003;43(5):465-77. [pmid: 12919265].
45 Baker R, Hall JN. REHAB: a new assessment instrument for chronic psychiatric patients. Schizophrenia Bulletin. 1988;14(1):97. [pmid: 3291097].
46 Reisberg B, Borenstein J, Franssen E, et al. BEHAVE-AD: A clinical rating scale for the assessment of pharmacologically remediable behavioral symptomatology in Alzheimer's disease. Alzheimer's Disease. Springer. 1987:1-16.
47 Helmes E, Csapo KG, Short J-A. Standardization and validation of the multidimensional observation scale for elderly subjects (MOSES). Journal of Gerontology. 1987;42(4):395-405. [pmid: 3598087].
48 Gitlin LN, Winter L, Dennis MP, et al. Assessing perceived change in the well-being of family caregivers: psychometric properties of the Perceived Change Index and response patterns. Am J Alzheimers Dis Other Demen. Oct-Nov. 2006;21(5):304-11. [pmid: 17062548].
49 Bedard M, Molloy DW, Squire L, et al. The Zarit Burden Interview: a new short version and screening version. Gerontologist. Oct. 2001;41(5):652-7. [pmid: 11574710].
50 Zarit SH, Reever KE, Bach-Peterson J. Relatives of the impaired elderly: correlates of feelings of burden. Gerontologist. Dec. 1980;20(6):649-55. [pmid: 7203086].
51 Agency for Healthcare Research and Quality. Grading the strength of a body of evidence when assessing health care interventions--AHRQ and the effective health-care program: An Update Draft Report. Rockville, MD. June. 2012. http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=1752&pageaction=displayproduct.
52 Viswanathan M, Ansari M, Berkman N, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. AHRQ. 2012.
53 R Development Core Team. R: A language and environment for statistical computing. R Foundation for Statistical Computing. 3-900051-07-0. 2008. Available at: www.R-project.org.
54 StataCorp. Stata Statistical Software: Release 13. College Station, TX. StataCorp LP. 2013.
55 Fu R, Gartlehner G, Grant M, et al. Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1187-97. [pmid: 21477993].
56 Berkman ND, Lohr KN, Ansari M, et al. Grading the strength of a body of evidence when assessing health care interventions for the effective health care program of the Agency for Healthcare Research and Quality: an update. 2013.
57 Atkins D, Chang S, Gartlehner G, et al. Assessing the applicability of studies when comparing medical interventions. 2010.
58 Sakamoto M, Ando H, Tsutou A. Comparing the effects of different individualized music interventions for elderly individuals with severe dementia. Int Psychogeriatr. May. 2013;25(5):775-84. [pmid: 23298693].
59 Lin Y, Chu H, Yang CY, et al. Effectiveness of group music intervention against agitated behavior in elderly persons with dementia. Int J Geriatr Psychiatry. Jul. 2011;26(7):670-8. [pmid: 20672256].
60 Raglio A, Bellelli G, Traficante D, et al. Efficacy of music therapy treatment based on cycles of sessions: a randomised controlled trial. Aging Ment Health. Nov. 2010;14(8):900-4. [pmid: 21069596].
61 Remington R. Calming music and hand massage with agitated elderly. Nursing Research. Sep-Oct. 2002;51(5):317-23. [pmid: 12352780].
62 Cooke ML, Moyle W, Shum DH, et al. A randomized controlled trial exploring the effect of music on agitated behaviours and anxiety in older people with dementia. Aging Ment Health. Nov. 2010;14(8):905-16. [pmid: 20635236].
63 Vink AC, Zuidersma M, Boersma F, et al. The effect of music therapy compared with general recreational activities in reducing agitation in people with dementia: a randomised controlled trial. Int J Geriatr Psychiatry. Oct. 2013;28(10):1031-8. [pmid: 23280604].
64 Fu CY, Moyle W, Cooke M. A randomised controlled trial of the use of aromatherapy and hand massage to reduce disruptive behaviour in people with dementia. BMC Altern Med. 2013;13:165. [pmid: 23837414].
65 Fujii M, Hatakeyama R, Fukuoka Y, et al. Lavender aroma therapy for behavioral and psychological symptoms in dementia patients. Geriatr Gerontol Int. Jun. 2008;8(2):136-8. [pmid: 18713168].
66 Lin PW, Chan WC, Ng BF, et al. Efficacy of aromatherapy (Lavandula angustifolia) as an intervention for agitated behaviours in Chinese older persons with dementia: a cross-over randomized trial. Int J Geriatr Psychiatry. May. 2007;22(5):405-10. [pmid: 17342790].
67 Yang MH, Lin LC, Wu SC, et al. Comparison of the efficacy of aroma-acupressure and aromatherapy for the treatment of dementia-associated agitation. BMC Altern Med. 2015;15:93. [pmid: 25880034].
68 Burns A, Perry E, Holmes C, et al. A double-blind placebo-controlled randomized trial of Melissa officinalis oil and donepezil for the treatment of agitation in Alzheimer's disease. Dement Geriatr Cogn Disord. 2011;31(2):158-64. [pmid: 21335973].
69 Ancoli-Israel S, Martin JL, Gehrman P, et al. Effect of light on agitation in institutionalized patients with severe Alzheimer disease. Am J Geriatr Psychiatry. Mar-Apr. 2003;11(2):194-203. [pmid: 12611749].
70 Burns A, Allen H, Tomenson B, et al. Bright light therapy for agitation in dementia: a randomized controlled trial. Int Psychogeriatr. Aug. 2009;21(4):711-21. [pmid: 19323872].
71 Dowling GA, Graf CL, Hubbard EM, et al. Light treatment for neuropsychiatric behaviors in Alzheimer's disease. West J Nurs Res. Dec. 2007;29(8):961-75. [pmid: 17596638].
72 Lyketsos CG, Veiel LL, Baker A, et al. A randomized, controlled trial of bright light therapy for agitated behaviors in dementia patients residing in long-term care. Int J Geriatr Psychiatry. Jul. 1999;14(7):520-5. [pmid: 10440971].
73 Woods DL, Craven RF, Whitney J. The effect of therapeutic touch on behavioral symptoms of persons with dementia. Altern Ther Health Med. Jan-Feb. 2005;11(1):66-74. [pmid: 15712768].
74 Hawranik P, Johnston P, Deatrich J. Therapeutic touch and agitation in individuals with Alzheimer's disease. West J Nurs Res. Jun. 2008;30(4):417-34. [pmid: 18272750].
75 Rodriguez-Mansilla J, Gonzalez-Lopez-Arza MV, Varela-Donoso E, et al. Ear therapy and massage therapy in the elderly with dementia: a pilot study. J Tradit Chin Med. Aug. 2013;33(4):461-7. [pmid: 24187866].
76 Moyle W, Cooke ML, Beattie E, et al. Foot massage versus quiet presence on agitation and mood in people with dementia: a randomised controlled trial. International Journal of Nursing Studies. Jun. 2014;51(6):856-64. [pmid: 24216598].
77 Van Haitsma KS, Curyto K, Abbott KM, et al. A randomized controlled trial for an individualized positive psychosocial intervention for the affective and behavioral symptoms of dementia in nursing home residents. J Gerontol B Psychol Sci Soc Sci. Jan. 2015;70(1):35-45. [pmid: 24304555].
78 van der Ploeg ES, Eppingstall B, Camp CJ, et al. A randomized crossover trial to study the effect of personalized, one-to-one interaction using Montessori-based activities on agitation, affect, and engagement in nursing home residents with Dementia. Int Psychogeriatr. Apr. 2013;25(4):565-75. [pmid: 23237211].
79 Cohen-Mansfield J, Thein K, Marx MS, et al. Efficacy of nonpharmacologic interventions for agitation in advanced dementia: a randomized, placebo-controlled trial. J Clin Psychiatry. Sep. 2012;73(9):1255-61. [pmid: 23059151].
80 Kovach CR, Taneli Y, Dohearty P, et al. Effect of the BACE intervention on agitation of people with dementia. Gerontologist. Dec. 2004;44(6):797-806. [pmid: 15611216].
81 Kolanowski A, Litaker M, Buettner L, et al. A randomized clinical trial of theory-based activities for the behavioral symptoms of dementia in nursing home residents. J Am Geriatr Soc. Jun. 2011;59(6):1032-41. [pmid: 21649633].
82 Kolanowski AM, Litaker M, Buettner L. Efficacy of theory-based activities for behavioral symptoms of dementia. Nursing Research. Jul-Aug. 2005;54(4):219-28. [pmid: 16027564].
83 Telenius EW, Engedal K, Bergland A. Effect of a high-intensity exercise program on physical function and mental health in nursing home residents with dementia: an assessor blinded randomized controlled trial. PLoS ONE. 2015;10(5):e0126102. [pmid: 25974049].
84 Rolland Y, Pillard F, Klapouszczak A, et al. Exercise program for nursing home residents with Alzheimer's disease: a 1-year randomized, controlled trial. J Am Geriatr Soc. Feb. 2007;55(2):158-65. [pmid: 17302650].
85 Hutson C, Orrell M, Dugmore O, et al. Sonas: A pilot study investigating the effectiveness of an intervention for people with moderate to severe dementia. American Journal of Alzheimer's Disease and other Dementias. 20. Dec. 2014;29(8):696-703.
86 Maseda A, Sanchez A, Marante M, et al. Effects of multisensory stimulation on a sample of institutionalized elderly people with dementia diagnosis: A controlled longitudinal trial. American Journal of Alzheimer's Disease and Other Dementias. Aug. 2014;29(5):463-73. [pmid: 24604894].
87 Low L-F, Brodaty H, Goodenough B, et al. The Sydney Multisite Intervention of LaughterBosses and ElderClowns (SMILE) study: cluster randomised trial of humour therapy in nursing homes. BMJ open. 2013;3(1):e002072. [pmid: 23315520].
88 Lin LC, Yang MH, Kao CC, et al. Using acupressure and Montessori-based activities to decrease agitation for residents with dementia: a cross-over trial. J Am Geriatr Soc. Jun. 2009;57(6):1022-9. [pmid: 19507295].
89 Ito T, Meguro K, Akanuma K, et al. A randomized controlled trial of the group reminiscence approach in patients with vascular dementia. Dement Geriatr Cogn Disord. 2007;24(1):48-54. [pmid: 17565213].
90 Lichtenberg PA, Kemp-Havican J, MacNeill SE, et al. Pilot study of behavioral treatment in dementia care units. Gerontologist. Jun. 2005;45(3):406-10. [pmid: 15933281].
91 Beck CK, Vogelpohl TS, Rasin JH, et al. Effects of behavioral interventions on disruptive behavior and affect in demented nursing home residents. Nursing Research. Jul-Aug. 2002;51(4):219-28. [pmid: 12131234].
92 Camberg L, Woods P, Ooi WL, et al. Evaluation of simulated presence: A personalized approach to enhance well-being in persons with Alzheimer's disease. J Am Geriatr Soc. Apr. 1999;47(4):446-52. [pmid: 10203120].
93 McCallion P, Toseland RW, Freeman K. An evaluation of a family visit education program. J Am Geriatr Soc. Feb. 1999;47(2):203-14. [pmid: 9988292].
94 Hozumi S, Hori H, Okawa M, et al. Favorable effect of transcranial electrostimulation on behavior disorders in elderly patients with dementia: a double-blind study. Int J Neurosci. Nov. 1996;88(1-2):1-10. [pmid: 9003961].
95 Robichaud L, Hebert R, Desrosiers J. Efficacy of a sensory integration program on behaviors of inpatients with dementia. American Journal of Occupational Therapy. Apr. 1994;48(4):355-60. [pmid: 8059869].
96 Chenoweth L, King MT, Jeon YH, et al. Caring for Aged Dementia Care Resident Study (CADRES) of person-centred care, dementia-care mapping, and usual care in dementia: a cluster-randomised trial. [Erratum appears in Lancet Neurol. 2009 May;8(5):419]. Lancet Neurology. Apr. 2009;8(4):317-25. [pmid: 19282246].
97 Rokstad AM, Rosvik J, Kirkevold O, et al. The effect of person-centred dementia care to prevent agitation and other neuropsychiatric symptoms and enhance quality of life in nursing home patients: a 10-month randomized controlled trial. Dement Geriatr Cogn Disord. 2013;36(5-6):340-53. [pmid: 24022375].
98 van de Ven G, Draskovic I, Adang EM, et al. Effects of dementia-care mapping on residents and staff of care homes: a pragmatic cluster-randomised controlled trial. PLoS ONE. 2013;8(7):e67325. [pmid: 23844003].
99 Jeon Y-H, Luscombe G, Chenoweth L, et al. Staff outcomes from the Caring for Aged Dementia Care REsident Study (CADRES): a cluster randomised trial. International journal of nursing studies. 2012;49(5):508-18. [pmid: 22078076].
100 Fossey J, Ballard C, Juszczak E, et al. Effect of enhanced psychosocial care on antipsychotic use in nurshig home residents with severe dementia: cluster randomised trial. British Medical Journal. Apr. 1. 2006;332(7544):756-8A. [pmid: 16543297].
101 Rapp MA, Mell T, Majic T, et al. Agitation in nursing home residents with dementia (VIDEANT trial): effects of a cluster-randomized, controlled, guideline implementation trial. J Am Med Dir Assoc. Sep. 2013;14(9):690-5. [pmid: 23827658].
102 Zwijsen SA, Smalbrugge M, Eefsting JA, et al. Coming to grips with challenging behavior: a cluster randomized controlled trial on the effects of a multidisciplinary care program for challenging behavior in dementia. J Am Med Dir Assoc. Jul. 2014;15(7):531.e1-10. [pmid: 24878214].
103 Finnema E, Droes RM, Ettema T, et al. The effect of integrated emotion-oriented care versus usual care on elderly persons with dementia in the nursing home and on nursing assistants: a randomized clinical trial. Int J Geriatr Psychiatry. Apr. 2005;20(4):330-43. [pmid: 15799079].
104 Schrijnemaekers V, van Rossum E, Candel M, et al. Effects of emotion-oriented care on elderly people with cognitive impairment and behavioral problems. Int J Geriatr Psychiatry. Oct. 2002;17(10):926-37. [pmid: 12325052].
105 Teri L, Huda P, Gibbons L, et al. STAR: A dementia-specific training program for staff in assisted living residences. Gerontologist. Oct. 2005;45(5):686-93. [pmid: 16199404].
106 Deudon A, Maubourguet N, Gervais X, et al. Non-pharmacological management of behavioural symptoms in nursing homes. Int J Geriatr Psychiatry. Dec. 2009;24(12):1386-95. [pmid: 19370714].
107 Hoeffer B, Talerico KA, Rasin J, et al. Assisting cognitively impaired nursing home residents with bathing: effects of two bathing interventions on caregiving. Gerontologist. Aug. 2006;46(4):524-32. [pmid: 16921006].
108 Magai C, Cohen CI, Gomberg D. Impact of training dementia caregivers in sensitivity to nonverbal emotion signals. Int Psychogeriatr. Mar. 2002;14(1):25-38. [pmid: 12094904].
109 McCallion P, Toseland RW, Lacey D, et al. Educating nursing assistants to communicate more effectively with nursing home residents with dementia. Gerontologist. Oct. 1999;39(5):546-58. [pmid: 10568079].
110 Proctor R, Burns A, Powell HS, et al. Behavioural management in nursing and residential homes: a randomised controlled trial. Lancet. Jul. 3. 1999;354(9172):26-9. [pmid: 10406361].
111 Wenborn J, Challis D, Head J, et al. Providing activity for people with dementia in care homes: a cluster randomised controlled trial. Int J Geriatr Psychiatry. Dec. 2013;28(12):1296-304. [pmid: 23637069].
112 Clare L, Whitaker R, Woods RT, et al. AwareCare: a pilot randomized controlled trial of an awareness-based staff training intervention to improve quality of life for residents with severe dementia in long-term care settings. Int Psychogeriatr. Jan. 2013;25(1):128-39. [pmid: 22840185].
113 Kovach CR, Logan BR, Noonan PE, et al. Effects of the Serial Trial Intervention on discomfort and behavior of nursing home residents with dementia. Am J Alzheimers Dis Other Demen. Jun-Jul. 2006;21(3):147-55. [pmid: 16869334].
114 Chapman DG, Toseland RW. Effectiveness of advanced illness care teams for nursing home residents with dementia. Soc Work. Oct. 2007;52(4):321-9. [pmid: 18232242].
115 McGilton KS, Rivera TM, Dawson P. Can we help persons with dementia find their way in a new environment?. Aging Ment Health. Sep. 2003;7(5):363-71. [pmid: 12959805].
116 Galik E, Resnick B, Hammersla M, et al. Optimizing function and physical activity among nursing home residents with dementia: testing the impact of function-focused care. Gerontologist. Dec. 2014;54(6):930-43. [pmid: 24092822].
117 Fitzsimmons S, Buettner LL. Therapeutic recreation interventions for need-driven dementia-compromised behaviors in community-dwelling elders. American journal of Alzheimer's disease and other dementias. 2002. 2002;17(6):367-81. [pmid: 12501484].
118 Tibaldi V, Aimonino N, Ponzetto M, et al. A randomized controlled trial of a home hospital intervention for frail elderly demented patients: behavioral disturbances and caregiver's stress. Arch Gerontol Geriatr Suppl. 2004;(9):431-6. [pmid: 15207444].
119 Hattori H, Hattori C, Hokao C, et al. Controlled study on the cognitive and psychological effect of coloring and drawing in mild Alzheimer's disease patients. Geriatr Gerontol Int. Oct. 2011;11(4):431-7. [pmid: 21518170].
120 Steinberg M, Leoutsakos J-MS, Podewils LJ, et al. Evaluation of home-based exercise program in the treatment of Alzheimer's disease: The Maximizing Independence in Dementia (MIND) Study. Int J Geriatr Psychiatry. Jul. 2009;24(7):680-5. [pmid: 19089875].
121 Belle SH, Burgio L, Burns R, et al. Enhancing the quality of life of dementia caregivers from different ethnic or racial groups: a randomized, controlled trial. [Summary for patients in Ann Intern Med. 2006 Nov 21;145(10):I39; PMID: 17116914]. Ann Intern Med. Nov. 21. 2006;145(10):727-38. [pmid: 17116917].
122 Bourgeois MS, Schulz R, Burgio LD, et al. Skills training for spouses of patients with Alzheimer's disease: Outcomes of an intervention study. Journal of Clinical Geropsychology. Jan. 2002;8(1):53-73.
123 Burgener SC, Bakas T, Murray C, et al. Effective caregiving approaches for patients with Alzheimer's disease. Geriatr Nurs. May-Jun. 1998;19(3):121-6. [pmid: 9708136].
124 Burgio L, Stevens A, Guy D, et al. Impact of two psychosocial interventions on white and African American family caregivers of individuals with dementia. Gerontologist. Aug. 2003;43(4):568-79. [pmid: 12937335].
125 Chien WT, Lee YM. A disease management program for families of persons in Hong Kong with dementia. Psychiatr Serv. Apr. 2008;59(4):433-6. [pmid: 18378844].
126 de Rotrou J, Cantegreil I, Faucounau V, et al. Do patients diagnosed with Alzheimer's disease benefit from a psycho-educational programme for family caregivers? A randomised controlled study. Int J Geriatr Psychiatry. Aug. 2011;26(8):833-42. [pmid: 20922772].
127 Gallagher-Thompson D, Wang P-C, Liu W, et al. Effectiveness of a psychoeducational skill training DVD program to reduce stress in Chinese American dementia caregivers: Results of a preliminary study. Aging Ment Health. Apr. 2010;14(3):263-73. [pmid: 20425645].
128 Gerdner LA, Buckwalter KC, Reed D. Impact of a psychoeducational intervention on caregiver response to behavioral problems. Nursing Research. Nov-Dec. 2002;51(6):363-74. [pmid: 12464756].
129 Gitlin LN, Winter L, Burke J, et al. Tailored activities to manage neuropsychiatric behaviors in persons with dementia and reduce caregiver burden: a randomized pilot study. Am J Geriatr Psychiatry. Mar. 2008;16(3):229-39. [pmid: 18310553].
130 Gitlin LN, Winter L, Corcoran M, et al. Effects of the home environmental skill-building program on the caregiver-care recipient dyad: 6-month outcomes from the Philadelphia REACH Initiative. Gerontologist. Aug. 2003;43(4):532-46. [pmid: 12937332].
131 Gitlin LN, Winter L, Dennis MP, et al. A biobehavioral home-based intervention and the well-being of patients with dementia and their caregivers: the COPE randomized trial. JAMA. Sep. 1. 2010;304(9):983-91. [pmid: 20810376].
132 Gitlin LN, Winter L, Dennis MP, et al. Targeting and managing behavioral symptoms in individuals with dementia: a randomized trial of a nonpharmacological intervention. J Am Geriatr Soc. Aug. 2010;58(8):1465-74. [pmid: 20662955].
133 Gonyea JG, O'Connor MK, Boyle PA. Project CARE: a randomized controlled trial of a behavioral intervention group for Alzheimer's disease caregivers. Gerontologist. Dec. 2006;46(6):827-32. [pmid: 17169938].
134 Gonzalez EW, Polansky M, Lippa CF, et al. Enhancing resourcefulness to improve outcomes in family caregivers and persons with Alzheimer's disease: a pilot randomized trial. Int J Alzheimer Dis. 2014;2014:323478. [pmid: 25328754].
135 Gormley N, Lyons D, Howard R. Behavioural management of aggression in dementia: a randomized controlled trial. Age and Ageing. Mar. 2001;30(2):141-5. [pmid: 11395344].
136 Guerra M, Ferri CP, Fonseca M, et al. Helping carers to care: the 10/66 dementia research group's randomized control trial of a caregiver intervention in Peru. Revista Brasileira de Psiquiatria. Mar. 2011;33(1):47-54. [pmid: 20602013].
137 Hebert R, Leclerc G, Bravo G, et al. Efficacy of a support group programme for caregivers of demented patients in the community: A randomized controlled trial. Archives of Gerontology and Geriatrics. Jan-Feb. 1994;18(1):1-14. [pmid: 15374309].
138 Huang H-L, Kuo L-M, Chen Y-S, et al. A home-based training program improves caregivers' skills and dementia patients' aggressive behaviors: A randomized controlled trial. The American Journal of Geriatric Psychiatry. Nov. 2013;21(11):1060-70. [pmid: 23933422].
139 Klodnicka Kouri K, Ducharme FC, Giroux F. A psycho-educational intervention focused on communication for caregivers of a family member in the early stage of Alzheimer's disease: Results of an experimental study. Dementia: The International Journal of Social Research and Practice. Aug. 2011;10(3):435-53.
140 Marriott A, Donaldson C, Tarrier N, et al. Effectiveness of cognitive-behavioural family intervention in reducing the burden of care in carers of patients with Alzheimer's disease. Br J Psychiatry. Jun. 2000;176:557-62. [pmid: 10974962].
141 Mittelman MS, Roth DL, Haley WE, et al. Effects of a caregiver intervention on negative caregiver appraisals of behavior problems in patients with Alzheimer's disease: results of a randomized trial. J Gerontol B Psychol Sci Soc Sci. Jan. 2004;59(1):P27-34. [pmid: 14722336].
142 Moniz-Cook E, Elston C, Gardiner E, et al. Can training community mental health nurses to support family carers reduce behavioural problems in dementia? An exploratory pragmatic randomised controlled trial. Int J Geriatr Psychiatry. Feb. 2008;23(2):185-91. [pmid: 17621379].
143 Nobili A, Riva E, Tettamanti M, et al. The effect of a structured intervention on caregivers of patients with dementia and problem behaviors: a randomized controlled pilot study. Alzheimer Dis Assoc Disord. Apr-Jun. 2004;18(2):75-82. [pmid: 15249851].
144 Ostwald SK, Hepburn KW, Caron W, et al. Reducing caregiver burden: a randomized psychoeducational intervention for caregivers of persons with dementia. Gerontologist. Jun. 1999;39(3):299-309. [pmid: 10396888].
145 Teri L, McCurry SM, Logsdon R, et al. Training community consultants to help family members improve dementia care: A randomized controlled trial. Gerontologist. Dec. 2005;45(6):802-11. [pmid: 16326662].
146 Ulstein ID, Sandvik L, Wyller TB, et al. A one-year randomized controlled psychosocial intervention study among family carers of dementia patients--effects on patients and carers. Dement Geriatr Cogn Disord. 2007;24(6):469-75. [pmid: 17986818].
147 Weiner MF, Tractenberg RE, Sano M, et al. No long-term effect of behavioral treatment on psychotropic drug use for agitation in Alzheimer's disease patients. J Geriatr Psychiatry Neurol. 2002;15(2):95-8. [pmid: 12083600].
148 Wright LK, Litaker M, Laraia MT, et al. Continuum of care for Alzheimer's disease: a nurse education and counseling program. Issues Ment Health Nurs. Apr-May. 2001;22(3):231-52. [pmid: 11885210].
149 Nobili A, Riva E, Tettamanti M, et al. The effect of a structured intervention on Caregivers of patients with dementia and problem behaviors - A randomized controlled pilot study. Alzheimer Dis Assoc Disord. Apr-Jun. 2004;18(2):75-82. [pmid: 15249851].
150 Weiner MF, Tractenberg RE, Jin S, et al. Assessing Alzheimer's disease patients with the Cohen-Mansfield Agitation Inventory: scoring and clinical implications. J Psychiatr Res. Jan-Feb. 2002;36(1):19-25. [pmid: 11755457].
151 Czaja SJ, Gitlin LN, Schulz R, et al. Development of the Risk Appraisal Measure: A Brief Screen to Identify Risk Areas and Guide Interventions for Dementia Caregivers. J Am Geriatr Soc. Jun. 2009;57(6):1064-72. [pmid: 19453305].
152 Ulstein ID, Sandvik L, Wyller TB, et al. A one-year randomized controlled psychosocial intervention study among family carers of dementia patients - Effects on patients and carers. Dementia and Geriatric Cognitive Disorders 2007. 2007;24(6):469-75. [pmid: 17986818].
153 Gitlin LN, Belle SH, Burgio LD, et al. Effect of multicomponent interventions on caregiver burden and depression: The REACH multisite initiative at 6-month follow-up. Psychology and Aging. Sep. 2003;18(3):361-74. [pmid: 14518800].
154 Teri L, Logsdon RG, Peskind E, et al. Treatment of agitation in AD: a randomized, placebo-controlled clinical trial. Neurology. Nov. 14. 2000;55(9):1271-8. [pmid: 11087767].
155 Gozalo P, Prakash S, Qato DM, et al. Effect of the bathing without a battle training intervention on bathing-associated physical and verbal outcomes in nursing home residents with dementia: a randomized crossover diffusion study. J Am Geriatr Soc. May. 2014;62(5):797-804. [pmid: 24697702].
156 Brandt NJ, Pythtila J. Psychopharmacological medication use among older adults with dementia in nursing homes. J Gerontol Nurs. Apr. 2013;39(4):8-14. [pmid: 23616986].
157 Hoffmann TC, Eerueti C, Glasziou PP. Poor description of non-pharmacological iinterventions: analysis of consecutive sample of randomised trials. British Medical Journal. 2013;347. [pmid: 24021722].
158 Ueda T, Suzukamo Y, Sato M, et al. Effects of music therapy on behavioral and psychological symptoms of dementia: A systematic review and meta-analysis. Ageing Research Reviews. March. 2013;12(2):628-41. [pmid: 23511664].
159 Livingston G, Kelly L, Lewis-Holmes E, et al. A systematic review of the clinical effectiveness and cost-effectiveness of sensory, psychological and behavioural interventions for managing agitation in older adults with dementia. Health technology assessment. Jun. 2014;18(39):1-226. v. vi. [pmid: 24947468].
160 Brodaty H, Arasaratnam C. Meta-analysis of nonpharmacological interventions for neuropsychiatric symptoms of dementia. American Journal of Psychiatry. 2012;169(9):946-53. [pmid: 22952073].