# Methods

## Criteria for Inclusion/Exclusion of Studies in the Review

Studies were included based on the PICOTS framework outlined above; the study-specific inclusion criteria are described in Table 4.

Table 4 Study inclusion criteria

Category | Criteria for Inclusion
Study Enrollment | Studies that enroll one of the following:; - Residents of nursing home, assisted living, individuals diagnosed with dementia (any type) with agitation/aggression; - Long-term care staff caring for individuals with dementia and associated agitation/aggression; - Community-dwelling individuals diagnosed with dementia (any type) with agitation/aggression; - Caregivers of community-dwelling individuals with dementia and associated agitation/aggression
Study Objective | Nonpharmacologic intervention aiming to prevent and/or decrease agitation/aggression associated with dementia
Study Design | Randomized controlled trials
Time of Publication | Literature published from 1994 forward (reflects interventions used today)
Publication Type | Published in peer reviewed journals
Language of Publication | English

## Searching for the Evidence: Literature Search Strategies for Identification of Relevant Studies To Answer the Key Questions

We searched Ovid Medline®, Ovid Embase®, and the Cochrane Central Register of Controlled Trials (CENTRAL) to identify randomized controlled trials (RCTs). Our search strategy included relevant medical subject headings and natural language terms for concepts of dementia and behavioral symptoms (Appendix A). These concepts were combined with filters to select RCTs. We screened bibliographic database search results for studies relevant to our PICOTS framework and study-specific criteria. Titles and abstracts were reviewed by two independent investigators to identify studies meeting PICOTS framework and inclusion/exclusion criteria. Titles and abstracts identified as potentially eligible by either investigator underwent full-text screening. Two investigators decided eligibility based on full-text review, consulting with a third investigator as necessary to resolve differences. We documented the exclusion status of articles undergoing full-text screening (Appendix B).

We searched ClinicalTrials.gov using “dementia” as the condition. Search results were scanned to identify studies, outcomes, and analyses not reported in the published literature. These results also informed our assessment of publication and reporting bias and inform future research needs. However, search results for this topic were not typically on target. Trial registration of behavioral intervention and/or in psychiatric, psychological, or dementia research does not appear to be common.

## Data Abstraction and Data Management

RCTs meeting inclusion criteria were distributed among investigators for data extraction. Data fields extracted included author, year of publication, setting, subject inclusion and exclusion criteria, intervention, and control characteristics (intervention components, timing, frequency, and duration). We extracted additional data from studies assessed as low or moderate risk of bias (assessment method described below). Relevant data were extracted into evidence tables. These data will be uploaded into the Systematic Review Data Repository after completion of final report.51

## Assessment of Methodological Risk of Bias of Individual Studies

Two investigators independently assessed risk of bias of eligible studies using instruments developed for the project based on AHRQ guidance.52 Risk of bias refers to the level of concerns about whether the design, conduct, and reporting of a trial threatens the ability to believe the results. We assessed several risk of bias domains including selection bias (adequate randomization methods, allocation concealment); performance bias (participant and personnel blinding, intervention definition); detection bias (outcome assessor blinding, outcomes measurement, statistical analysis); attrition bias (amount, nature, and handling of incomplete data); reporting bias (selective outcome or analysis reporting); and other risks of bias not captured by the selected domains. Summary risk of bias assessments for each trial were classified as low, moderate, or high based on the collective risk of bias inherent in each domain and confidence that the results were believable given the study's limitations. Investigators conferred to reconcile discrepancies in overall risk of bias assessments when only one investigator assessed a trial as high risk of bias. In certain situations, a third party was consulted to reconcile the summary judgment.

## Data Synthesis

We summarized the results in detailed tables for each unique population and intervention type. We did not identify established minimum important differences for key outcomes measurement instruments. We primarily synthesized results across conceptually similar comparisons and outcomes using qualitative synthesis. When comparisons could be reasonably pooled (i.e., comparable interventions and outcomes), we conducted a meta-analysis of the data using a Knapp-Hartung random effects model in R53 and constructed Forest plots with Stata.54 We calculated risk ratios (RR) and/or absolute risk differences (ARD) with the corresponding 95 percent confidence intervals (CI) for binary primary outcomes. Weighted mean differences (WMD) and/or standardized mean differences (SMD) with the corresponding 95 percent CIs were calculated for continuous outcomes. We assessed the clinical and methodological heterogeneity and variation in effect size to determine appropriateness of pooling data.55 We assessed the magnitude of statistical heterogeneity with the I^2^ statistic.55

## Grading the Strength of Evidence for Major Comparisons and Outcomes

In contrast to risk of bias, overall strength of evidence was assessed across all studies that address a pairing of outcomes and intervention. Strength of evidence was evaluated based on five domains: (1) study limitations (the pattern of risk of bias across all relevant studies); (2) directness (single, direct link between intervention and outcome); (3) consistency (similarity of effect direction and size); (4) precision (degree of certainty around an estimate), and (5) reporting bias.56 Based on study design and risk of bias of the individual studies within the comparison, study limitations were rated as low, medium, or high. Consistency was rated consistent, inconsistent, or unknown/not applicable (e.g., single study) based on whether intervention effects were similar in direction and magnitude, and the statistical significance of all studies. Directness was rated direct or indirect based on whether the outcome was a final patient-centered outcome or an intermediate or secondary outcome. Precision was rated precise or imprecise based on the degree of certainty surrounding each effect estimate or qualitative finding. Imprecise estimates include clinically distinct conclusions within the confidence interval. Reporting bias was evaluated by the potential for publication bias by comparing studies identified and considered potentially eligible from grey literature searches to identified published studies. Other factors considered in assessing strength of evidence included dose-response relationship, the presence of confounders, and strength of association.

Based on these factors, the overall strength of evidence for each outcome was assessed:56

High: Very confident that estimate of effect lies close to true effect. Few or no deficiencies in body of evidence, findings believed to be stable.

Moderate: Moderately confident that estimate of effect lies close to true effect. Some deficiencies in body of evidence; findings likely stable, but some doubt remains.

Low: Limited confidence that estimate of effect lies close to true effect; major or numerous deficiencies in body of evidence. Additional evidence is necessary before concluding that findings are stable or that estimate of effect is close to true effect.

Insufficient: No evidence, unable to estimate an effect, or no confidence in estimate of effect. No evidence is available or the body of evidence precludes judgment.

## Assessing Applicability

Applicability of studies was determined according to the PICOTS framework. Study characteristics affecting applicability included the population from which the study participants are enrolled, diagnostic assessment processes, narrow eligibility criteria, and patient and intervention characteristics different than those described by population studies behavioral symptoms in dementia.57