# Introduction

## Background and Objectives

The most recent edition of the American Psychiatric Association's Diagnostic and Statistical Manual of Mental Disorders, Fifth Edition (DSM-5) categorizes individuals with acquired cognitive deficits as having major or mild neurocognitive disorders (NCD).1 Subtypes of NCDs include major and mild NCD due to Alzheimer's disease, due to frontotemporal disorder, due to Lewy bodies, and vascular NCD. Historically, patients with these NCDs have been referred to as having dementia. Because dementia is the far more familiar term, we have used it rather than NCD throughout this report.

Up to 90 percent of those with dementia exhibit behavioral or psychological symptoms at some point, more often in advanced stages of the disease.2 Symptoms tend to occur in clusters and can include depression, psychosis, aggression, agitation, anxiety, and wandering.2-4 Behavioral and psychological symptoms cause considerable patient distress and are associated with accelerated functional and cognitive decline. Dementia-related symptoms challenge both formal and informal caregivers and are associated with increases in caregiver anger, resentment toward the patient, stress, and decreased psychological health.5-7 Not surprisingly, dementia-related symptoms are the leading predictors of institutionalization.8 However, staff in nursing homes and assisted living facilities are also challenged by behavioral and psychological symptoms, which affect an estimated 80 percent of nursing home and assisted living facility residents with dementia.

Among dementia-related symptoms, agitation and aggression are especially distressing to patients, family caregivers, and nursing home and assisted living facility staff. Agitation and aggression are costly to manage and are associated with institutionalization among community-dwelling patients, social isolation, and other negative outcomes.8 The terms agitation and aggression are used to describe many types of behaviors and many adjectives are used to describe agitated and aggressive behaviors (e.g., disruptive, problem, difficult, and challenging). Agitation is defined as “excessive motor activity with a feeling of inner tension and characterized by a cluster of related symptoms including anxiety and irritability, motor restlessness and abnormal vocalization, often associated with behaviors such as pacing, wandering, aggression, shouting, and nighttime disturbance.”9 Aggression is commonly described to be a subtype of agitation10 consisting of overt harmful actions (physical or verbal) that are clearly not accidental.9

Ultimately, terms describing agitation and aggression in the literature are confusing and inconsistent.11 Agitation and aggression are typically grouped together as part of a spectrum, although they have different manifestations and implications. Agitation affects primarily the person with dementia (although the behaviors may be disruptive for others in his/her environment). By contrast, aggression directly involves at least one other person (the target of the aggression) and can represent a real risk to that person. As a result, one might argue that although it makes sense to identify and treat the underlying cause of agitation whenever possible, some manifestations of agitation may not need intervention per se; they can simply be tolerated. By contrast, aggression needs to be dealt with because of the possible risk to others. We refer to these symptoms or behaviors as agitation/aggression.

Historically, drugs have been used to manage behavioral symptoms in patients with dementia, particularly for agitation/aggression. Pharmacotherapy for behavioral symptoms is based on a biological/genetic framework for the etiology of the condition. However, drug therapies generally, and antipsychotic medications specifically, have limited efficacy and increased risk for adverse effects, including mortality.12-14 Drug treatments for dementia are also associated with reduced quality of life.15 Evidence of effective nonpharmacological approaches would strengthen the efforts to urge less use of inappropriate psychoactive drugs, but the absence of that evidence should not diminish such efforts in light of the harmful effects of these medications. By contrast, the nonpharmacological approaches have virtually no reports of adverse effects.

Clinical guidelines recommend nonpharmacologic interventions as the first choice for agitation/aggression in patients with dementia.16-19 However, nonpharmacologic interventions are under-used in clinical practice. In part this is because clinicians lack knowledge regarding their efficacy and possible risks, but caregivers are also reluctant to forsake drugs until they are confident in managing agitation/aggression without them. To reduce inappropriate use of antipsychotics and other psychotropic drugs for behavioral symptoms in patients with dementia will require evidence for the effectiveness and harms of nonpharmacologic treatments. Clinicians and caregivers will also need education on the use of these approaches.

Nonpharmacologic interventions aim to (1) prevent agitation/aggression behaviors, (2) respond to episodes of agitation/aggression to reduce their severity and duration, and/or (3) reduce caregiver distress. Individuals with dementia may reside in nursing homes or assisted living facilities or in their own homes or with family members (community-dwelling).

Interventions delivered in nursing homes and assisted living facilities can be at the patient level, where a therapy is delivered directly to the patient, or care delivery level, involving the approach, staff, and/or environment used in care delivery. Examples of patient-level interventions used in residential settings include sensory-based approaches such as aroma, bright light, or touch, as well as activity-based approaches involving music, art, or horticulture.20 Care-delivery level interventions include a variety of care-delivery models, staff/caregiver education and training, and environmental approaches.21 Examples include trainings to enhance staff knowledge and skills in managing behavioral symptoms among residents, care-delivery models such as patient-centered care or dementia care mapping, and enhancements to the environment aimed at reducing exposure to agitation/aggression triggers.

Interventions delivered to community-dwelling individuals with dementia can be at the patient or caregiver level. The caregiver is typically an informal family caregiver. Patient-level interventions would be similar to those in residential settings. However, patient-level interventions may also include activities, such as exercise classes, that are accessible to individuals in less advanced stages of dementia. Caregiver-level interventions to address agitation/aggression address the family caregiver approach to caregiving. These interventions provide education and skills training to enhance understanding of the disease process, specific symptoms, and how to best address agitation/aggression. Table 1 provides a description and examples of the types of interventions used in various settings.

Table 1 Types of interventions addressing agitation/aggression in dementia

Setting | Intervention Level | Intervention Type | Goals | Examples
Nursing Homes and Assisted Living Facilities | Patient level | Sensory | Preventing incidents | Music therapy (listening), aromatherapy, bright light therapy, multisensory stimulation.
Nursing Homes and Assisted Living Facilities | Patient level | Structured Activities | Preventing incidents | Dancing, exercise, social interaction, music therapy (playing, singing), art therapy, outdoor walks
Nursing Homes and Assisted Living Facilities | Patient level | Complementary and Alternative Medicine | Preventing incidents; treating incidents | Aromatherapy, reflexology, acupuncture, acupressure, massage, Reiki
Nursing Homes and Assisted Living Facilities | Patient level | Psychological | Preventing incidents | Validation therapy, reality orientation, reminiscence therapy, support groups
Nursing Homes and Assisted Living Facilities | Care Delivery Level | Care Delivery Models | Preventing incidents; treating incidents | Dementia care mapping; patient centered care
Nursing Homes and Assisted Living Facilities | Care Delivery Level | Staff Training and Education | Preventing incidents; treating incidents | Specific curriculums for communication, managing behaviors
Nursing Homes and Assisted Living Facilities | Care Delivery Level | Environmental | Preventing incidents | Walled in areas, wandering areas, wayfinding enhancement, reduced stimulation areas, enhanced environments
Community Dwelling | Patient level | Same as patient-level above | | Same as patient-level above
Community Dwelling | Caregiver level | Caregiver education | Preventing incidents; treating incidents | Specific curricula to educate caregivers about dementia.
Community Dwelling | Caregiver level | Caregiver education and training | Preventing incidents; treating incidents | Specific curricula to education caregivers about dementia and build skills to manage behaviors.
Community Dwelling | Caregiver level | Caregiver education and training with psychosocial support | Preventing incidents; treating incidents | Specific curricula to educate caregivers about dementia and build skills to manage behaviors with additional components such as support groups or counseling.

The expected effectiveness of interventions will vary with their nature and purpose. Interventions designed to respond to a behavior are different from those designed to prevent the occurrence or intensity of such behaviors. In the former case, a successful intervention ends an episode, but the duration of effect is likely to be short. By contrast, a more preventive approach aims to have a longer lasting effect, marked by fewer events over a period of time. Although we attempted to classify interventions on the basis of the intent (i.e., responsive or preventive), we found that many studies failed to make the distinction clear.

Measuring behavioral outcomes is a complex process for which a wide variety of instruments are available. These instruments (1) are based on different theoretical frameworks, (2) are designed to evaluate behaviors in different settings (e.g., in-home, hospital, or long-term care), (3) are administered by different individuals (e.g., caregiver, nurse, or patient), and (4) use different mechanisms to obtain responses (e.g., interviews with patients or direct observation). More than 45 instruments are used to evaluate behavioral symptoms in dementia, with no gold standard.22 The appropriate instrument depends on disease severity and context of care (e.g., setting, severity of disease, and whether the purpose is to identify any behavior or to identify specific behaviors). Instruments for evaluating behavioral symptoms fall into two broad categories: general and specific.22 Table 2 describes commonly used instruments.

Table 2 Instruments measuring intermediate, primary, and secondary outcomes

Outcome Category | Outcome | Instrument | Measurement/Instrument Properties | MIDs Reported in Literature
Intermediate Outcomes | Caregiver Behavior Change | Caregiving Mastery Index, a subscale of the Caregiving Appraisal Measure | 12 items assessing caregiving mastery Range 12-60; higher scores indicate greater mastery29 | None identified
Primary Outcomes | Patient Agitation/Aggression | Agitated Behavior in Dementia Scale (ABID) | 16 items assessing the frequency of agitation/aggression (verbally and physically threatening or aggressive; harmful to self; inappropriate screaming or crying out; destroying property; refusing to accept appropriate care; leaving/trying to leave; socially inappropriate behaviors; inappropriate sexual behavior; restlessness; worrying/fearful; easily agitated; nighttime waking; incorrect, distressing beliefs; sensing distressing people that are not truly present) over the past 2 weeks (each week rated separately and added together for each item) and caregiver distress and reaction once in the last 2 weeks; to be used in noninstitutionalized patients Range 0 to 48 (care recipient); higher scores indicate greater agitation Range 0 to 64 (caregiver); higher scores indicate greater reaction30 | None identified
Primary Outcomes | Patient Agitation/Aggression | Brief Agitation Rating Scale (BARS) | 10 items assessing the frequency of agitated behavior (based on CMAI) over the past two weeks. Range 10 to 70; higher scores indicate greater agitation.22 | None identified
Primary Outcomes | Patient Agitation/Aggression | Cohen-Mansfield Agitation Inventory (CMAI) | Number of items varies by form (29 items for standard form, 14 items for the short form, 37 items for the community form); assesses the frequency of agitation/aggression over the past 2 weeks. Range 0-203; higher scores indicate greater agitation31-33 | ≥45 indicates clinically significant agitation requiring treatment34 30% change in overall score35
Primary Outcomes | Patient Agitation/Aggression | Disruptive Behavior Rating Scales (DBRS) | 21 items assessing the frequency and severity of disruptive behavior across four dimensions (physical aggression, verbal aggression, agitation, wandering) assessed daily for 1 week; range 0 to 105; higher scores indicate greater agitation.22 | None identified
Primary Outcomes | Patient Agitation/Aggression | Pittsburgh Agitation Scale (PAS) | 4 items assessing aberrant vocalization, motor agitation, aggressiveness, and resistance to care over period of 1 to 8 hours; Range 0 to 4 per item (scores are not totaled); higher scores indicate greater agitation22,25 | None identified
Primary Outcomes | General Behavior | Behaviour Rating Scale (BMD) | Designed for carers to assess behavior and mood at home.36 | None identified
Primary Outcomes | General Behavior | Neuropsychiatric inventory (NPI, and its variants NPI-C, NPI-Q) | 12-91 items, varying by domain screening responses; assesses aberrant motor behavior, agitation, anxiety, apathy, appetite and eating behaviors, caregiver distress, delusions, disinhibition, dysphoria, euphoria, hallucinations, irritability, nighttime behavior issues. Range depends on screening responses for each domain and responses for frequency and severity; higher scores indicate greater behavioral problems37 | 8 points38
Primary Outcomes | General Behavior | Revised Memory and Behavior Problem Checklist (RMBPC) | 24 items; assesses caregiver reactions, depression problems, disruptive behaviors, and memory-related problems Range 0-96 for patient behaviors and 0-96 for caregiver reactions; higher scores indicate greater frequency of behavior problems and greater caregiver distress39 | None identified
Primary Outcomes | General Behavior | Memory and Behavior Problem Checklist (MBPC) | Previous version of RMBPC40 | None identified
Primary Outcomes | General Behavior | CERAD Behavior Rating Scale for Dementia (BRSD) | 51 items in original version, 46 items in revised version, 17 items in short form; assesses affect, aggression, agitation/irritability, apathy, defective self-regulation, depressive features, vegetative features, psychotic features Range unclear; higher scores indicate greater behavioral problems41 | None identified
Primary Outcomes | General Behavior | MOUSEPAD | 59 items assessing psych symptoms and behavioral disturbances (delusions, hallucinations, misidentifications, reduplications, walking, eating, sleeping, sexual behavior, aggression) Range 0-3 per item that assesses severity after yes/no response; higher scores indicate greater behavioral problems42 | None identified
Primary Outcomes | General Behavior | Behavior and Mood Disturbance (BMD) | 34 items assessing behavioral and mood disturbances (apathy, depression, disinterest, irritability, pacing, wandering, withdrawn behaviors) Range 0-136 (0-4 per item); includes Apathetic-Withdrawn subscale, Active-Disturbed subscale, and Mood-Disturbance subscale; higher scores indicate greater behavioral problems43 | None identified
Primary Outcomes | General Behavior | Rehabilitation Evaluation Hall and Baker tool (REHAB) | 23 items assessing deviant behavior (physical and verbal aggression) and general behavior (community skills, disturbed speech, self-care, social activity) Range 0-126 for the general behavior subscale and 0-21 for the deviant behavior subscale; higher scores indicate greater behavioral problems44,45 | None identified
Primary Outcomes | General Behavior | Behavioral Pathology in Alzheimer's disease (BEHAVE-AD) | 25 items assessing activity disturbances, affective disturbances, aggressiveness, anxieties and phobias, diurnal rhythm disturbances, hallucinations, paranoid, and delusional ideation Range 0-75 plus a 4-point global assessment; higher scores indicate greater behavioral problems46 | None identified
Primary Outcomes | General Behavior | Multi-dimensional observation scale for elderly patients (MOSES) | 40 items assessing depressed/anxious mood, disoriented behavior, irritable behavior, self-care functioning, and withdrawn behavior Range 0-4 or 0-5 per item, total range varies by subscale; higher scores indicate greater behavioral problems47 | None identified
Secondary Outcomes | Caregiver Distress | Perceived Change Index | 13 items assessing affect, managing caregiving challenges, and somatic symptoms Range 13-65; higher scores indicate worsening in well-being48 | None identified
Secondary Outcomes | Caregiver Burden | Zarit Burden Interview (Brief version) | 12 assessing caregiver burden Scores 0-4 per item, total range 0 to 48; higher scores indicate greater burden49 | None identified
Secondary Outcomes | Caregiver Burden | Zarit Burden Interview | 29 items assessing caregiver burden Scoring is 0-4 per item, total range 0 to 116; higher scores indicate greater burden50 | None identified

ABID = Agitated Behavior in Dementia; BARS = Brief Agitation Rating Scale; BEHAVE-AD = Behavioral Pathology in Alzheimer's disease; BMD = Behavior and Mood Disturbance; BRSD = Behavior Rating Scale for Dementia; CMAI = Cohen-Mansfield Agitation Inventory; DBRS = Disruptive Behavior Rating Scale; MBPC = Memory and Behavior Problem Checklist; MID = minimally important difference; MOSES = Multi-dimensional Observation Scale for Elderly Patients; NPI = Neuropsychiatric Inventory; PAS = Pittsburgh Agitation Scale; REHAB = Rehabilitation Evaluation Hall and Baker; RMBPC = Revised Memory and Behavior Problem Checklist

Several instruments measure agitation/aggression specifically. These include the Agitated Behavior in Dementia Scale (ABID),23 the Cohen-Mansfield Agitation Inventory (CMAI),24 and the Pittsburgh Agitation Scale (PAS).25 Also, some general behavioral symptom instruments include subscales specific to agitation/aggression.

General measures evaluate a host of behaviors across multiple domains (e.g., agitation, depression, and wandering). Most studies that report results from general behavioral symptom measures report overall summary scores. Examples of general behavioral measurement instruments include the Neuropsychiatric Inventory (NPI and its variants NPI-C, NPI-Q). The NPI is one of the most commonly used instruments to measure behavior. The Revised Memory and Behavior Problem Checklist and the CERAD Behavior Rating Scale for Dementia are other examples of instruments measuring general behavioral symptoms in individuals with dementia.

Our understanding and measurement of agitation/aggression in individuals with dementia has changed over time. Agitation/aggression are now more often considered distinct behaviors. For example, an early version of the NPI combined agitation/aggression into a single domain. In contrast, the Neuropsychiatric Inventory Clinician (NPI-C), a second-generation survey designed to incorporate input from clinicians, separates the behaviors into two distinct domains.4 The context in which agitation/aggression occur is considered paramount to determining appropriate interventions. Clinical algorithms have been developed to help identify the presence and causes of symptoms in order to effectively manage behaviors.26-28 However, instruments often document the occurrence of behavioral symptoms without identifying their source or cause. Ideally, algorithms are used alongside specific instruments to provide appropriate context for the occurrence of behaviors.

Evidence synthesis on the efficacy and comparative effectiveness of nonpharmacologic interventions specifically for agitation/aggression in patients with dementia could reduce the frequency and severity of those behaviors and improve functioning, reduce distress, and reduce or delay residential long-term care. These interventions may also reduce the use of antipsychotic drugs. Results from this review will inform practice regarding the appropriate and effective management of agitation/aggression in individuals with dementia.

To address these gaps in the literature, we conducted a systematic review based on an analytical framework (Figure 1) to address the Key Questions (KQs):

## Key Questions

Key Question 1a: What is the comparative effectiveness of nonpharmacologic interventions in preventing and responding to agitation/aggression among individuals with dementia who reside in nursing home and assisted living settings?

Key Question 1b: What are the comparative harms of nonpharmacologic interventions in preventing and responding to agitation/aggression among individuals with dementia who reside in nursing home and assisted living settings?

Key Question 2a: What is the comparative effectiveness of nonpharmacologic interventions in preventing and responding to agitation/aggression among community-dwelling individuals with dementia?

Key Question 2b: What are the comparative harms of nonpharmacologic interventions in preventing and responding to agitation/aggression among community-dwelling individuals with dementia?

## Analytical Framework

Figure 1 Analytic framework for nonpharmacologic interventions to manage agitation/aggression in dementia

KQ = Key Question

Figure 1 is the analytical framework describing the flow of dementia patients with agitation and aggression through exposure to interventions aimed at preventing and/or reducing the frequency and severity of these behaviors. Interventions can be general or targeted to specific behaviors. Interventions can have associated harms. Outcomes include clinically reductions in the frequency and severity of agitation and aggression in the dementia patient, reductions and improvements in quality of life among patients, staff, and caregivers.

## Populations, Interventions, Comparisons, Outcomes, Timing, and Setting (PICOTS)

The PICOTS (populations, interventions, comparisons, outcomes, timing, and setting) addressed in this review are described in Table 3.

Table 3 Populations, interventions, comparisons, outcomes, timing, and setting (PICOTS)

PICOTS Element | Description
Populations | [underlined: KQ1:] Individuals with dementia residing in nursing home and assisted living settings; nursing home and assisted living facility staff [underlined: KQ2:] Community-dwelling individuals with dementia; informal caregivers of individuals with dementia
Interventions | Nonpharmacologic interventions aimed at preventing or responding to agitation/aggression
Comparisons | Usual care (as specified by trial investigators) or no treatment Attention control or placebo Other nonpharmacologic interventions Pharmacologic interventions
Outcomes | [underlined: Final (Patient) Health Outcomes] [underlined: KQ1 & KQ2:] Frequency, duration, and severity of agitation/aggression; frequency, duration and severity of aggressive behaviors; general behavior of person with dementia; distress; quality of life; injuries to patients, staff, others [underlined: KQ2:] Injuries to patients, caregivers; admission to nursing home [underlined: Secondary Outcomes] [underlined: KQ1:] Staff distress, burden, quality of life [underlined: KQ2:] Caregiver distress, burden, quality of life [underlined: Intermediate Outcomes] [underlined: KQ1:] Staff behavior change, reduction in antipsychotic use [underlined: KQ2:] Caregiver behavior change, reduction in antipsychotic use [underlined: Adverse Effects of Intervention(s)] Increase in other difficult behaviors (i.e., wandering) Increase in other symptoms (i.e., depression, anxiety)
Timing | Any duration of followup. Relevant timing will vary with the nature of the intervention
Setting | [underlined: KQ1:] Nursing homes and assisted living facilities [underlined: KQ2:] Community-dwelling (patients living at home)

KQ = Key Question