# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Cornelia Beck, Ph.D., R.N.
  University of Arkansas for Medical Sciences
  Little Rock, AR
- Alice Bonner, Ph.D., M.S.N.^*^
  * Provided input on Draft Report.
  Bouve College of Health Sciences
  Northeastern University
  Boston, MA
- Joseph Gaugler, Ph.D.^*^
  School of Nursing
  University of Minnesota
  Minneapolis, MN
- Laura Gitlin, Ph.D., M.A.
  Center for Innovative Care in Aging
  Johns Hopkins University
  Baltimore, MD
- Kathleen Kelly, M.P.A.
  Family Caregiver Alliance
  National Center on Caregiving
  San Francisco, CA
- Katie Maslow, M.S.W.^*^
  National Academy of Sciences
  Institute of Medicine
  Washington, DC
- Laurie Ryan, Ph.D.^*^
  National Institute on Aging
  National Institutes of Health
  Bethesda, MD
- Glenn Smith, Ph.D.^*^
  College of Public Health and Health Professions
  University of Florida
  Gainesville, FL