# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- Alice Bonner, Ph.D., M.S.N.
  Bouve College of Health Sciences
  Northeastern University
  Burlington, MA
- Richard H. Fortinsky, Ph.D.
  Center on Aging
  University of Connecticut Health Center
  Farmington, CT
- Delores Gallagher-Thompson, Ph.D.
  Center for Longevity
  Stanford University School of Medicine
  Stanford, CA
- Laura Gitlin, Ph.D., M.A.
  Center for Innovative Care in Aging
  Johns Hopkins University
  Baltimore, MD
- Michele Laughman
  Division of Nursing Homes
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- Katie Maslow, M.S.W.
  National Academy of Sciences
  Institute of Medicine
  Washington, DC
- Bruce E. Robinson, M.D., M.P.H.
  Medical Education and Palliative Care Services
  Sarasota Memorial Hospital
  Sarasota, FL
- Glenn Smith, Ph.D.
  College of Public Health and Health Professions
  University of Florida
  Gainesville, FL
- Peter Whitehouse, M.D., Ph.D.
  Brain Health and Memory Center
  Case Western Reserve University
  Cleveland, OH