# Acknowledgments

We thank Marilyn Eells and Cheryl Cole-Hill for their editorial help bringing the report to completion. We also thank Kim Wittenberg and Kathleen Lohr for their helpful editorial comments.