# Discussion

Reducing off-label use of antipsychotic drugs for individuals with dementia is a priority. Ideally, strong evidence that nondrug treatments can effectively reduce agitation/aggression and improve patient quality of life could support this treatment change; but even in the absence of strong evidence about the effectiveness of nonpharmacological treatment, due to their potential risks and limited efficacy, efforts should continue to reduce the use of psychoactive medications in these patients. Evidence is mounting about the risks of this type of drug treatment. Patients who are overmedicated with antipsychotics and robbed of experiencing life due to sedatives experience a clear detriment. For people with dementia, psychoactive medications can cause harm and even death. The Centers for Medicare & Medicaid Services has launched an active campaign to reduce the use of psychoactive medications.16,156 Even in clinical circumstances when psychoactive drugs are appropriate, they must be used sparingly and for a specific documented behavior, and they must also use the lowest effective dose. Ideally, nonpharmacologic approaches, which have few, if any, adverse effects, would be substituted as psychoactive medication use was reduced, creating a win-win situation. Caregivers who are confident about the efficacy of nonpharmacologic options may be more willing to reduce and forgo medications.

Unfortunately, despite the urgent need for strong evidence, the current literature on nonpharmacologic options is weak. Research on the nonpharmacologic management of aggression in dementia is not well coordinated and has some major problems. Trials are mostly small and vary widely in interventions, instruments used to measure outcomes, analysis techniques, and reporting. Each investigator seems anxious to add something new. Given the heterogeneity in comparisons and outcomes, pooling for meta-analysis was rarely possible. Wherever possible, we tried to identify patterns within groups of conceptually similar comparisons, but the evidence was insufficient to draw conclusions for a large number of comparisons and outcomes.

In some cases, low strength evidence showed that interventions were not effective in reducing agitation/aggression. For example, among patient-focused interventions in nursing home and assisted living settings, music, aromatherapy with lavender, and bright light therapy had similar effects on agitation/aggression as inactive control (placebo, attention controls, usual care). Further, among interventions implemented at the care-delivery level in nursing home and assisted living settings, dementia care mapping and patient-centered care had similar effects on agitation/aggression as usual care. Low strength evidence also showed that tailored caregiver education and training combined with a caregiver psychosocial component was similar to inactive control in managing general behavior in dementia, improved caregiver confidence, and reduced caregiver burden.

## Limitations of Available Studies

Our review reflects the limitations of the available literature. We found substantial heterogeneity in interventions and outcomes across trials and methodological problems within trials. While we did identify a large number of trials that tested interventions for improving behavioral symptoms in dementia; fewer specifically measured agitation/aggression. Few groups of studies had sufficient similarity in interventions, comparisons, and outcomes to allow appropriate data pooling. When pooling was not appropriate, we attempted a qualitative synthesis of similar comparisons and outcomes. Despite these attempts, our analysis still consists of several unique comparisons, often from small studies with methodological limitations, resulting in evidence insufficient to draw conclusions about efficacy or comparative effectiveness.

Our primary outcome was agitation/aggression. Because the research has tended to combine these two, we followed that practice. However, as noted earlier, they have different manifestations and implications. Our primary outcome was agitation/aggression. Agitation affects primarily the person with dementia (although the behaviors may be disruptive for others in his/her environment). By contrast, aggression directly involves at least one other person (the target of the aggression) and can represent a real risk to that person. As a result, one might argue that although it makes sense to identify and treat the underlying cause of agitation whenever possible, some regular manifestations of agitation may not need intervention per se; they can simply be tolerated. By contrast, aggression needs to be dealt with because of the possible risk to others.

Several different instruments were used to assess this agitation/aggression. Certain instruments are best suited to certain settings and patients. Whether each study selected the most appropriate instrument was unclear, and we found little information regarding changes in these scores associated with a clinically meaningful difference. None of the studies we analyzed used instrument-specific thresholds to assess efficacy or comparative effectiveness. Additionally, although the CMAI is a very widely used instrument in nursing home and assisted living settings and has been determined valid and reliable, many studies reported only subscales of the CMAI. Whether these subscales are valid or reliable or sensitive to changes occurring in response to treatment is unclear.

Changes in aggression and agitation will vary with the goal of the intervention. Interventions designed to respond to a behavior are different from those designed to prevent the occurrence or reduce the intensity of future behaviors. If the former case, a successful intervention ends an episode but its duration of effect is likely to be short. By contrast, a more preventive approach aims to have a longer lasting effect, marked by fewer or less severe future events. Although we attempted to classify interventions on the basis of the intent (i.e., responsive or preventive), we found that many studies failed to make the distinction clear. Future research should address this distinction more overtly in presenting their conceptual model for the effectiveness of the intervention being tested.

Understanding that we may not find studies that reported agitation/aggression per se, we included studies that assessed behavioral symptoms with more general instruments. These instruments (NPI, MOSES) contain items across a wide variety of behavioral symptoms. Changes in overall scores on these instruments are not easily interpreted nor directly related to agitation/aggression.

We found few references documenting established minimal important differences for any of the instruments used to assess agitation/aggression, general behavior, or intermediate and secondary outcomes. Without an understanding of what constitutes a clinically meaningful change, interpretation of statistically significant differences and assessment of precision was challenging.

Individual studies assessed as having a low or moderate risk of bias still presented several methodological problems. Many trials were underpowered. Underpowered studies that cannot be pooled add little value to the field and should not be conducted. Calculating sample sizes necessary for appropriately powered RCTs should incorporate the high attrition rate commonly found in this population of older adults with health problems. Sample size calculations should also take into consideration that individuals with dementia may change living status (e.g., move from the community to a facility) and face a higher risk of death compared with similarly aged individuals. Withdrawals and dropouts created considerable loss of participants from already small sample sizes in some studies. Although attrition was predictably high in the studies we reviewed, it was not always adequately described and intention to treat analysis was rarely conducted.

Details regarding the population, setting, and methodology were often inadequately described. Few studies provided details on dementia type or severity/stage of illness. Few clearly described the control groups.

Current study designs are not well described, which is a common problem in nonpharmacologic research.157 Control conditions are also poorly described, including the concomitant use of antipsychotic medications. This was especially a problem in older studies. Usual care was rarely described when it was used as a comparison. Often, sample selection and method of randomization were not reported. Few studies described and accounted for simultaneous treatments, especially psychoactive medications. When use of psychoactive medications was reported, trials rarely eliminated their use; at most, medications were held constant during the study and/or medication changes were recorded as an outcome. Outcome assessors were often aware of the intervention status of participants or of the research question, potentially biasing the findings. Many studies used multiple outcomes and analyzed multiple comparisons, but most failed to make statistical adjustments for the multiple comparisons.

Moreover, when studies were compared with “usual care,” the usual treatment was rarely defined. People with dementia, especially in group residential settings, were typically exposed to a hodgepodge of activities and therapies designed to improve functioning and quality of life. Indeed, RCTs of one intervention were sometimes used as an attention control for another intervention. Similarly, the physical environments and rules for conduct in the residential settings of the studies were seldom described, yet could have powerful effects on reducing or ameliorating agitation/aggression. In some instances the intervention was added to this usual care; in others it was offered as an alternative. It was frequently not even clear if psychoactive medications were being given concurrently.

Many trials tended to combine aggression and agitation/aggression as an outcome, but these are not synonymous. Although aggression is a form of agitation, it differs from agitation and anxiety in a caregiving context. Agitation/aggression was rarely described other than reports of instrument scores. Further, agitation/aggression was reported in a variety of ways. Some instruments combined them; others separated them. However, when the behaviors were separately assessed with certain elements of an instrument, we could not always determine whether that instrument was designed to yield valid and reliable subsets of questions. Scales to measure agitation include elements such as restlessness or aimless pacing, repetitive requests and “verbalizations,” and so forth.

Agitation may be prompted by loss of memory or it may reflect anxiety. If the anxiety is the patient's and not the caregiver's, then its underlying cause must be ascertained (e.g., pain or discomfort or some specific stimulus). Agitated verbal or physical behavior may be annoying and even frustrating to caregivers but is not necessarily a problem requiring treatment. By contrast, verbal and especially physical aggression often require treatment. At minimum, aggression may arouse fear or disturb the calm of other patients in group settings; at worst, it may cause injury to caregivers or other patients. Aggression is also likely to harm its perpetrator in the form of increased restrictions or temporary or permanent removal to another setting, resulting in increased confusion. For these reasons, aggression is likely to be treated more assertively than various forms of agitation. Ironically, the epidemiology of agitation/aggression is not well understood, from the distribution of agitated behavior to how often various behaviors occur separately or together in the same patient and whether any discernable progression can be observed.

Agitation and aggression are typically grouped together as part of a spectrum, although they have different manifestations and implications.

These two goals may imply different strategies. Preventing or minimizing events can rely on environmental manipulation such as music or light, or activities that create a diversion or draw on strengths of remote memories. It may involve individually based approaches to identify triggers for a given person and subsequently avoid them (this is essentially the basis for dementia care mapping and for the general stance that agitation/aggression is communication that caregivers need to try to decipher and respond to). Conversely, managing events once they arise may involve distraction, calming behavior by staff, or moving individuals to a calming environment.

Given this distinction, preventive strategies should be enacted over long time periods in order to reduce the frequency and/or intensity of events. Likewise, treatments designed to prevent agitation/aggression should produce long-lasting effects, and thus longer-term followup is appropriate. Some of these treatments require staff to change their approach to dealing with individuals with dementia. Sustaining any behavior changes that follow may require additional caregiver or staff support beyond that involved in the initial intervention. Other techniques aim to squash or at least diminish agitation/aggression when they arise. Unlike preventive strategies, reactive strategies are in the moment and need to work immediately; however, their effect may not last beyond the episode. Therefore, the measures of success for preventive and reactive approaches should differ. However, we found substantial confusion in distinguishing strategies and measures.

We might expect to see interventions tested for effectiveness before being used as the basis for training, but such was not the case. Instead, the line between training studies and interventions proved hard to draw. Several interventions required that staff be trained to behave differently, but the training was sparsely described. Some studies used a combination of outside experts and trained staff to implement interventions.

Changing the behavior of caregiving staff is challenging, especially in nursing homes, where training and oversight are modest at best. Nursing home staff are notoriously overworked and may not be eager to take on new tasks, especially ones that require them to radically alter their typical behavior and routines. Although all nursing homes are required to have in-service educators and to conduct training at intervals, staff training tends to be perfunctory and brief with sparse oversight and encouragement. Maintaining a new behavior requires regular feedback to engender a sense that it is working. Staff training is even more difficult when the staffing is unstable or staff feel great pressure to complete other assigned tasks. The more that interventions require clinical judgment, the more difficult they are to implement, especially within nursing home hierarchies.

In regard to assisted living and other group residential settings and in-home care services, training requirements are even fewer, dependent largely on state rules. Furthermore, the appropriate staff to conduct interventions in such settings is harder to define. Some studies used external staff to establish the effectiveness of the behavior; and the effects of these interventions tend to have short half-lives because implementation disappears when the study ends. Relying on staff to administer the intervention increases chances of longer-term success, but doing so is far more complicated. As mentioned, staff must then be trained and supervised. Ultimately, the more an intervention depends on staff, the harder it is to separate it from a training study in research.

Many studies used multiple outcome measures; most failed to make statistical adjustments for the multiple outcomes. The large number of measures may reflect uncertainty about the goals of the intervention or the lack of a good measure.

Few studies accounted for or even described simultaneous therapies, especially psychoactive medications. Further, physical environment was rarely addressed (e.g., private or shared rooms, freedom or restrictions of movement, policies for dining, bathing, and care routines that may generate resistance). We found few studies of such environmental and practice shifts (other than the training to generate more effective staff) and the environments for these studies were rarely described. Even studies of bathing interventions did not describe usual routines for bathing. In studies of individualized activities, authors provided little sense of the spaces available for such efforts. Most of the nursing home studies took place in multiple facilities, either with facilities or units randomized or with intervention and control groups in each study site. In these cases we know little about how settings varied. Studies didn't account for potential differences in study sites in statistical analyses, but even if they had, sample size would make facility differences in effects hard to find.

Our findings are consistent with many prior reviews, but more pessimistic than others, which showed benefit for certain interventions. A recent systematic review of music therapy for a broad range of behavioral and psychological symptoms found a small effect for anxiety and behavior (broadly defined).158 This review included a broader range of symptoms and study designs and did not specifically address agitation/aggression. Another recent review that specifically addressed agitation concluded that music therapy following protocol failed to produce a sustained benefit.159 The same review found no evidence of efficacy for aromatherapy or light therapy.159 In contrast, Livingston et al. concluded that the available evidence showed that dementia care mapping and person-centered care showed efficacy.159 They included a broader range of study designs, failed to conduct a meta-analysis, and may have concluded efficacy when changes from baseline were present in the absence of differences from control group. Brodaty et al. concluded that caregiver interventions improved behavioral outcomes in community-dwelling individuals with dementia.160 However, this study included a broad range of psychological and behavioral symptoms and the strongest effects were from studies focusing on depression.

In summary, the evidence for nonpharmacologic treatment of agitation/aggression in individuals with dementia is weak and obfuscated by an inconsistent and confusing terminology. A clearer taxonomy of interventions and more precise terms are needed to outline the variations in the problem and the links between specific interventions and problem elements. Given the variation in intervention fidelity and complexity in RCT reports and the great difficulties of addressing selection bias even in RCTs, we believed that observational studies would be difficult to interpret. Trials should be designed to adequately address treatment goals within appropriate timelines. Simultaneous treatments such as psychoactive treatments must be accounted for. Nonetheless, this line of research will continue to be difficult. The incidence of problems is unpredictable and nursing home environments are unstable.

## Applicability

Our conclusions are likely relevant to the broad population of individuals with dementia. The populations described appear similar to the overall population with dementia within each setting, at least by age and sex. The ethnic composition is less representative. Nursing home residents and dementia patients are more often female, likely due to their longer life expectancy. When dementia type was described, Alzheimer's disease was typically the most prevalent, consistent with national estimates. While the populations reflect the population of individuals with dementia, it is more challenging to assess the applicability of results of studies conducted in nursing homes and assisted living facilities. These facilities vary greatly in size, environments, and staffing models. Few studies described these characteristics, so applicability is unclear.

## Future Research Needs

This review sought to identify and synthesize RCTs testing nonpharmacologic interventions for agitation/aggression in dementia. The evidence is weak and offers no insight about promising practices. The discussion of study limitations above points to many issues that must be addressed in future work. Future research should be thoughtfully planned and rigorously conducted (Table 13). Several conceptual issues must be addressed. A clearer map of specific types of agitation/aggression and links to specific interventions may prove more valuable than addressing the general dementia population with broadly defined behavioral symptoms. Also needed are more consistent measures and clearer rationales for how the measures address treatment goals as well as appropriate timelines. A roadmap that uncouples agitation and aggression and links each of them to treatment goals may be helpful. More attention to the role of environment would help elucidate the effectiveness of interventions. If the pathway is via changing staff (or informal caregiver) behavior, evidence of that intermediate effect would be helpful.

Table 13 Future research needs

Key Question | Results of Literature Review | Types of Studies; Needed To Answer Question | Future Research Needs
General methodological issues | Agitation and aggression not consistently described, defined, or treated as separate behaviors | Consensus conference | Consensus among experts to arrive at standard definitions of specific behavioral symptoms.
General methodological issues | Improvement and agreement on instruments to measure agitation/aggression. | Consensus conference | Consensus among experts to identify or develop instruments with adequate psychometric properties to measure agitation/aggression and guidance on which measures to use in select settings, populations.
General methodological issues | Few groups of studies with sufficient similarity in interventions, comparisons, and outcomes allowing appropriate data pooling. | Consensus conference | It would be beneficial to standardize promising practices and study those practices in RCT studies. It would also be beneficial to develop guidance to assist researchers in selecting the appropriate instruments to measure agitation/aggression.
General methodological issues | No established minimum important differences for commonly used instruments measuring agitation/aggression outcomes. | Original research | It would be beneficial to conduct studies to determine thresholds for commonly used instruments that indicate clinically meaningful changes. These threshold values could be used in comparative effectiveness research.
General methodological issues | Wide heterogeneity in interventions, comparisons, outcomes, and analysis techniques. | Consensus conference | Consensus among experts about which interventions might be most appropriate, effective in which populations and settings. Prioritization of interventions with specific characteristics could lead to a more homogeneous set of trials that could provide sufficient evidence to draw conclusions.
General methodological issues | Agitation/aggression not specifically studied; many trials address behaviors broadly. | RCTs | Trials should address agitation or aggression specifically, enrolling persons with dementia with similar symptoms to better study the potential of interventions to manage these specific behaviors.
General methodological issues | Objectives of interventions not well-specified | RCTs | Interventions should be designed to prevent or respond to agitation/aggression; trial should be designed according to objective.
General methodological issues | Small, underpowered studies | RCTs | Funding/conducting RCTs with power adequate to answer the research question is necessary to avoid underpowered studies which do not strengthen available evidence. Power calculations should incorporate the expected higher rate of attrition common in this population.
KQ 1a: What is the comparative effectiveness of nonpharmacologic interventions in preventing and responding to [underlined: agitation/aggression] among individuals with dementia in [underlined: long-term care]? | Study populations in nursing home settings often had a wide variety of agitation/aggression behaviors that might respond differently to specific treatments. | RCTs | Persons with dementia with similar symptoms could provide the population for intervention trials. Larger trials would provide more valuable information and strengthen the evidence base.
| Few trials studied particular environmental interventions | RCTs | Trials that assess environmental changes.
KQ 1b: What are the comparative [underlined: harms] of nonpharmacologic interventions in preventing and responding to [underlined: agitation/aggression] among individuals with dementia in [underlined: long-term care] settings? | Harms were rarely reported; most interventions were unlikely to have serious harms. | RCTs | It would be beneficial to record and report harms or lack thereof for each treatment group.
KQ 2a: What is the comparative effectiveness of nonpharmacologic interventions in preventing and responding to [underlined: agitation/aggression] among [underlined: community-dwelling] individuals with dementia? | Tailored interventions did not demonstrate an effect on behaviors. Few trials specifically targeted agitation/aggression. | RCTs | Persons with dementia with similar symptoms could provide the population for intervention trials to determine if certain behavioral symptoms do not respond to nonpharmacologic treatment.
| Caregiver tailored education and training showed benefits to caregivers (improved confidence of managing behaviors). It is unclear if these benefits are maintained after the intervention ends. | RCTs | Long-term followup is necessary to determine if caregiver benefits are maintained after intervention ends. Testing could be conducted to determine if booster sessions or long-term psychosocial interventions help maintain intervention benefits.
KQ 2b: What are the comparative [underlined: harms] of nonpharmacologic interventions in preventing and responding to [underlined: agitation/aggression] among [underlined: community-dwelling] individuals with dementia? | Harms were rarely reported; most interventions were unlikely to have serious harms. | RCTs | It would be beneficial to record and report harms or lack thereof for each treatment group.

KQ=Key Question; RCT=randomized controlled trial

Future research should take a more systematic approach. Variations in treatment should be tested sequentially and under more defined conditions. This type of research could move the field forward. Interventions need to be more precisely described with attention to what is done (how much, how often), under what circumstances, and by whom. Fidelity needs to be documented. Likewise the nature of “usual care” needs to be explicated and any concurrent treatment delineated. An order of procedure that would be clinically acceptable might start with adding a candidate treatment. That approach, if it produced a substantial effect, could then be tested instead of existing drug therapy.

Future RCTs should be adequately powered and power calculations should incorporate the expected high attrition rate when calculating necessary sample sizes. Given that many studies showed little or no effect for most interventions, accumulating more studies with the small sample sizes is unlikely to change the results. Future trials should adequately describe the intervention and control condition, blind outcomes assessors, and use instruments appropriate to the intervention. They should also appropriately correct for multiple comparisons and account for simultaneous treatments such as psychoactive medications. In addition, more work needs to be done on establishing minimal important differences for the major outcomes.

## Conclusions

Research on nonpharmacologic treatment of agitation/aggression seems to have developed in a piecemeal fashion without overarching coordination. Our review found insufficient evidence to draw conclusions regarding most of the interventions that have been studied to address agitation/aggression in individuals with dementia. The few interventions with low strength evidence had null effects. Despite the urgent need for alternatives to medication for the treatment of problem behaviors, the current state of the literature provides little information useful to changing practice. Nonetheless, efforts should continue to find alternatives to psychoactive medication treatment.