# References for Appendixes

1 Ancoli-Israel S, Martin JL, Gehrman P, et al. Effect of light on agitation in institutionalized patients with severe Alzheimer disease. Am J Geriatr Psychiatry. Mar-Apr. 2003;11(2):194-203. [pmid: 12611749].
2 Baillon S, Van Diepen E, Prettyman R, et al. A comparison of the effects of Snoezelen and reminiscence therapy on the agitated behaviour of patients with dementia. Int J Geriatr Psychiatry. Nov. 2004;19(11):1047-52. [pmid: 15481068].
3 Baker R, Holloway J, Holtkamp CC, et al. Effects of multi-sensory stimulation for people with dementia. J Adv Nurs. Sep. 2003;43(5):465-77. [pmid: 12919265].
4 Ballard CG, O'Brien JT, Reichelt K, et al. Aromatherapy as a safe and effective treatment for the management of agitation in severe dementia: The results of a double-blind, placebo-controlled trial with Melissa. J Clin Psychiatry. 2002;63(7):553-8. [pmid: 12143909].
5 Beck CK, Vogelpohl TS, Rasin JH, et al. Effects of behavioral interventions on disruptive behavior and affect in demented nursing home residents. Nursing Research. Jul-Aug. 2002;51(4):219-28. [pmid: 12131234].
6 Burns A, Allen H, Tomenson B, et al. Bright light therapy for agitation in dementia: a randomized controlled trial. Int Psychogeriatr. Aug. 2009;21(4):711-21. [pmid: 19323872].
7 Camberg L, Woods P, Ooi WL, et al. Evaluation of simulated presence: A personalized approach to enhance well-being in persons with Alzheimer's disease. J Am Geriatr Soc. Apr. 1999;47(4):446-52. [pmid: 10203120].
8 Clark ME, Lipe AW, Bilbrey M. Use of music to decrease aggressive behaviors in people with dementia. J Gerontol Nurs. Jul. 1998;24(7):10-7. [pmid: 9801526].
9 Cohen-Mansfield J, Thein K, Marx MS, et al. Efficacy of nonpharmacologic interventions for agitation in advanced dementia: a randomized, placebo-controlled trial. J Clin Psychiatry. Sep. 2012;73(9):1255-61. [pmid: 23059151].
10 Cohen-Mansfield J, Libin A, Marx MS. Nonpharmacological treatment of agitation: a controlled trial of systematic individualized intervention. J Gerontol A Biol Sci Med Sci. Aug. 2007;62(8):908-16. [pmid: 17702884].
11 Cooke ML, Moyle W, Shum DH, et al. A randomized controlled trial exploring the effect of music on agitated behaviours and anxiety in older people with dementia. Aging Ment Health. Nov. 2010;14(8):905-16. [pmid: 20635236].
12 Deponte A, Missan R. Effectiveness of validation therapy (VT) in group: preliminary results. Arch Gerontol Geriatr. Mar-Apr. 2007;44(2):113-7. [pmid: 16712981].
13 Dowling GA, Graf CL, Hubbard EM, et al. Light treatment for neuropsychiatric behaviors in Alzheimer's disease. West J Nurs Res. Dec. 2007;29(8):961-75. [pmid: 17596638].
14 Fu CY, Moyle W, Cooke M. A randomised controlled trial of the use of aromatherapy and hand massage to reduce disruptive behaviour in people with dementia. BMC Altern Med. 2013;13:165. [pmid: 23837414].
15 Fujii M, Hatakeyama R, Fukuoka Y, et al. Lavender aroma therapy for behavioral and psychological symptoms in dementia patients. Geriatr Gerontol Int. Jun. 2008;8(2):136-8. [pmid: 18713168].
16 Garland K, Beer E, Eppingstall B, et al. A comparison of two treatments of agitated behavior in nursing home residents with dementia: simulated family presence and preferred music. Am J Geriatr Psychiatry. Jun. 2007;15(6):514-21. [pmid: 17293386].
17 Gerdner LA. Effects of individualized versus classical “relaxation” music on the frequency of agitation in elderly persons with Alzheimer's disease and related disorders. Int Psychogeriatr. Mar. 2000;12(1):49-65. [pmid: 10798453].
18 Hatakeyama R, Fukushima K, Fukuoka Y, et al. Personal home made digital video disk for patients with behavioral psychological symptoms of dementia. Geriatr Gerontol Int. Jul. 2010;10(3):272-4. [pmid: 20629763].
19 Hawranik P, Johnston P, Deatrich J. Therapeutic touch and agitation in individuals with Alzheimer's disease. West J Nurs Res. Jun. 2008;30(4):417-34. [pmid: 18272750].
20 Hicks-Moore SL, Robinson BA. Favorite music and hand massage: Two interventions to decrease agitation in residents with dementia. Dementia: The International Journal of Social Research and Practice. Feb. 2008;7(1):95-108.
21 Houser WS, George DR, Chinchilli VM. Impact of TimeSlips creative expression program on behavioral symptoms and psychotropic medication use in persons with dementia in long-term care: a cluster-randomized pilot study. Am J Geriatr Psychiatry. Apr. 2014;22(4):337-40. [pmid: 23602304].
22 Hozumi S, Hori H, Okawa M, et al. Favorable effect of transcranial electrostimulation on behavior disorders in elderly patients with dementia: a double-blind study. Int J Neurosci. Nov. 1996;88(1-2):1-10. [pmid: 9003961].
23 Hutson C, Orrell M, Dugmore O, et al. Sonas: A pilot study investigating the effectiveness of an intervention for people with moderate to severe dementia. American Journal of Alzheimer's Disease and other Dementias. 20. Dec. 2014;29(8):696-703.
24 Ito T, Meguro K, Akanuma K, et al. A randomized controlled trial of the group reminiscence approach in patients with vascular dementia. Dement Geriatr Cogn Disord. 2007;24(1):48-54. [pmid: 17565213].
25 Janata P. Effects of widespread and frequent personalized music programming on agitation and depression in assisted living facility residents with Alzheimer-type dementia. Music and Medicine. Jan. 2012;4(1):8-15.
26 Jablonski RA, Reed D, Maas ML. Care intervention for older adults with Alzheimer's disease and related dementias: effect of family involvement on cognitive and functional outcomes in nursing homes. J Gerontol Nurs. Jun. 2005;31(6):38-48. [pmid: 16138529].
27 Kolanowski AM, Buettner L, Costa PT Jr., et al. Capturing interests: Therapeutic recreation activities for persons with dementia. Therapeutic Recreation Journal. 2001;35(3):220-35.
28 Kolanowski AM, Litaker M, Buettner L. Efficacy of theory-based activities for behavioral symptoms of dementia. Nursing Research. Jul-Aug. 2005;54(4):219-28. [pmid: 16027564].
29 Kolanowski A, Litaker M, Buettner L, et al. A randomized clinical trial of theory-based activities for the behavioral symptoms of dementia in nursing home residents. J Am Geriatr Soc. Jun. 2011;59(6):1032-41. [pmid: 21649633].
30 Kovach CR, Taneli Y, Dohearty P, et al. Effect of the BACE intervention on agitation of people with dementia. Gerontologist. Dec. 2004;44(6):797-806. [pmid: 15611216].
31 Landi F, Russo A, Bernabei R. Physical activity and behavior in the elderly: a pilot study. Arch Gerontol Geriatr Suppl. 2004;(9):235-41. [pmid: 15207420].
32 Lawton MP, Van Haitsma K, Klapper J, et al. A stimulation-retreat special care unit for elders with dementing illness. International psychogeriatrics / IPA. 1998-. Dec. 1998;10(4):379-95. [pmid: 9924833].
33 Lichtenberg PA, Kemp-Havican J, MacNeill SE, et al. Pilot study of behavioral treatment in dementia care units. Gerontologist. Jun. 2005;45(3):406-10. [pmid: 15933281].
34 Lin PW, Chan WC, Ng BF, et al. Efficacy of aromatherapy (Lavandula angustifolia) as an intervention for agitated behaviours in Chinese older persons with dementia: a cross-over randomized trial. Int J Geriatr Psychiatry. May. 2007;22(5):405-10. [pmid: 17342790].
35 Lin LC, Yang MH, Kao CC, et al. Using acupressure and Montessori-based activities to decrease agitation for residents with dementia: a cross-over trial. J Am Geriatr Soc. Jun. 2009;57(6):1022-9. [pmid: 19507295].
36 Lin Y, Chu H, Yang CY, et al. Effectiveness of group music intervention against agitated behavior in elderly persons with dementia. Int J Geriatr Psychiatry. Jul. 2011;26(7):670-8. [pmid: 20672256].
37 Low L-F, Brodaty H, Goodenough B, et al. The Sydney Multisite Intervention of LaughterBosses and ElderClowns (SMILE) study: cluster randomised trial of humour therapy in nursing homes. BMJ open. 2013;3(1):e002072.
38 Lyketsos CG, Veiel LL, Baker A, et al. A randomized, controlled trial of bright light therapy for agitated behaviors in dementia patients residing in long-term care. Int J Geriatr Psychiatry. Jul. 1999;14(7):520-5. [pmid: 10440971].
39 Mariko A, Matsuda H, Takahashi M, et al. Touch on the acupoint of shinchuu of Alzheimer's disease patients. Geriatr Gerontol Int. Mar. 2015;15(3):385-6. [pmid: 25752667].
40 McCallion P, Toseland RW, Freeman K. An evaluation of a family visit education program. J Am Geriatr Soc. Feb. 1999;47(2):203-14. [pmid: 9988292].
41 McGilton KS, Rivera TM, Dawson P. Can we help persons with dementia find their way in a new environment?. Aging Ment Health. Sep. 2003;7(5):363-71. [pmid: 12959805].
42 Milev RV, Kellar T, McLean M, et al. Multisensory stimulation for elderly with dementia: a 24-week single-blind randomized controlled pilot study. Am J Alzheimers Dis Other Demen. Aug-Sep. 2008;23(4):372-6. [pmid: 18453647].
43 Narme P, Clement S, Ehrle N, et al. Efficacy of musical interventions in dementia: evidence from a randomized controlled trial. J Alzheimers Dis. 2014;38(2):359-69. [pmid: 23969994].
44 Raglio A, Bellelli G, Traficante D, et al. Efficacy of music therapy treatment based on cycles of sessions: a randomised controlled trial. Aging Ment Health. Nov. 2010;14(8):900-4. [pmid: 21069596].
45 Remington R. Calming music and hand massage with agitated elderly. Nursing Research. Sep-Oct. 2002;51(5):317-23. [pmid: 12352780].
46 Ridder HM, Stige B, Qvale LG, et al. Individual music therapy for agitation in dementia: an exploratory randomized controlled trial. Aging Ment Health. 2013;17(6):667-78. [pmid: 23621805].
47 Robichaud L, Hebert R, Desrosiers J. Efficacy of a sensory integration program on behaviors of inpatients with dementia. American Journal of Occupational Therapy. Apr. 1994;48(4):355-60. [pmid: 8059869].
48 Rodriguez-Mansilla J, Gonzalez-Lopez-Arza MV, Varela-Donoso E, et al. Ear therapy and massage therapy in the elderly with dementia: a pilot study. J Tradit Chin Med. Aug. 2013;33(4):461-7. [pmid: 24187866].
49 Rolland Y, Pillard F, Klapouszczak A, et al. Exercise program for nursing home residents with Alzheimer's disease: a 1-year randomized, controlled trial. J Am Geriatr Soc. Feb. 2007;55(2):158-65. [pmid: 17302650].
50 Sakamoto M, Ando H, Tsutou A. Comparing the effects of different individualized music interventions for elderly individuals with severe dementia. Int Psychogeriatr. May. 2013;25(5):775-84. [pmid: 23298693].
51 Sloane PD, Hoeffer B, Mitchell CM, et al. Effect of person-centered showering and the towel bath on bathing-associated aggression, agitation, and discomfort in nursing home residents with dementia: a randomized, controlled trial. J Am Geriatr Soc. Nov. 2004;52(11):1795-804. [pmid: 15507054].
52 Smallwood J, Brown R, Coulter F, et al. Aromatherapy and behaviour disturbances in dementia: a randomized controlled trial. Int J Geriatr Psychiatry. Oct. 2001;16(10):1010-3. [pmid: 11607948].
53 Staal JA, Sacks A, Matheis R, et al. The effects of Snoezelen (multi-sensory behavior therapy) and psychiatric care on agitation, apathy, and activities of daily living in dementia patients on a short term geriatric psychiatric inpatient unit. Int J Psychiatry Med. 2007;37(4):357-70. [pmid: 18441625].
54 Sung HC, Chang SM, Lee WL, et al. The effects of group music with movement intervention on agitated behaviours of institutionalized elders with dementia in Taiwan. Complement Ther Med. Jun. 2006;14(2):113-9. [pmid: 16765849].
55 Sung HC, Lee WL, Li TL, et al. A group music intervention using percussion instruments with familiar music to reduce anxiety and agitation of institutionalized older adults with dementia. Int J Geriatr Psychiatry. Jun. 2012;27(6):621-7. [pmid: 21823174].
56 Svansdottir HB, Snaedal J. Music therapy in moderate and severe dementia of Alzheimer's type: a case-control study. Int Psychogeriatr. Dec. 2006;18(4):613-21. [pmid: 16618375].
57 Telenius EW, Engedal K, Bergland A. Effect of a high-intensity exercise program on physical function and mental health in nursing home residents with dementia: an assessor blinded randomized controlled trial. PLoS ONE. 2015;10(5):e0126102. [pmid: 25974049].
58 Van de Winckel A, Feys H, De Weerdt W, et al. Cognitive and behavioural effects of music-based exercises in patients with dementia. Clin Rehabil. May. 2004;18(3):253-60. [pmid: 15137556].
59 van der Ploeg ES, Eppingstall B, Camp CJ, et al. A randomized crossover trial to study the effect of personalized, one-to-one interaction using Montessori-based activities on agitation, affect, and engagement in nursing home residents with Dementia. Int Psychogeriatr. Apr. 2013;25(4):565-75. [pmid: 23237211].
60 Van Haitsma KS, Curyto K, Abbott KM, et al. A randomized controlled trial for an individualized positive psychosocial intervention for the affective and behavioral symptoms of dementia in nursing home residents. J Gerontol B Psychol Sci Soc Sci. Jan. 2015;70(1):35-45. [pmid: 24304555].
61 Vink AC, Zuidersma M, Boersma F, et al. The effect of music therapy compared with general recreational activities in reducing agitation in people with dementia: a randomised controlled trial. Int J Geriatr Psychiatry. Oct. 2013;28(10):1031-8. [pmid: 23280604].
62 Woods DL, Craven RF, Whitney J. The effect of therapeutic touch on behavioral symptoms of persons with dementia. Altern Ther Health Med. Jan-Feb. 2005;11(1):66-74. [pmid: 15712768].
63 Woods DL, Beck C, Sinha K. The effect of therapeutic touch on behavioral symptoms and cortisol in persons with dementia. Forsch Komplementarmed. Jun. 2009;16(3):181-9. [pmid: 19657203].
64 Yang MH, Lin LC, Wu SC, et al. Comparison of the efficacy of aroma-acupressure and aromatherapy for the treatment of dementia-associated agitation. BMC Altern Med. 2015;15:93. [pmid: 25880034].
65 Burns A, Perry E, Holmes C, et al. A double-blind placebo-controlled randomized trial of Melissa officinalis oil and donepezil for the treatment of agitation in Alzheimer's disease. Dement Geriatr Cogn Disord. 2011;31(2):158-64. [pmid: 21335973].
66 Moyle W, Cooke ML, Beattie E, et al. Foot massage versus quiet presence on agitation and mood in people with dementia: a randomised controlled trial. International Journal of Nursing Studies. Jun. 2014;51(6):856-64. [pmid: 24216598].
67 Maseda A, Sanchez A, Marante M, et al. Effects of multisensory stimulation on a sample of institutionalized elderly people with dementia diagnosis: A controlled longitudinal trial. American Journal of Alzheimer's Disease and Other Dementias. Aug. 2014;29(5):463-73.
68 Chapman DG, Toseland RW. Effectiveness of advanced illness care teams for nursing home residents with dementia. Soc Work. Oct. 2007;52(4):321-9. [pmid: 18232242].
69 Chenoweth L, King MT, Jeon YH, et al. Caring for Aged Dementia Care Resident Study (CADRES) of person-centred care, dementia-care mapping, and usual care in dementia: a cluster-randomised trial. [Erratum appears in Lancet Neurol. 2009 May;8(5):419]. Lancet Neurology. Apr. 2009;8(4):317-25. [pmid: 19282246].
70 Clare L, Whitaker R, Woods RT, et al. AwareCare: a pilot randomized controlled trial of an awareness-based staff training intervention to improve quality of life for residents with severe dementia in long-term care settings. Int Psychogeriatr. Jan. 2013;25(1):128-39. [pmid: 22840185].
71 Davison TE, McCabe MP, Visser S, et al. Controlled trial of dementia training with a peer support group for aged care staff. Int J Geriatr Psychiatry. Sep. 2007;22(9):868-73. [pmid: 17191270].
72 Deudon A, Maubourguet N, Gervais X, et al. Non-pharmacological management of behavioural symptoms in nursing homes. Int J Geriatr Psychiatry. Dec. 2009;24(12):1386-95. [pmid: 19370714].
73 Finnema E, Droes RM, Ettema T, et al. The effect of integrated emotion-oriented care versus usual care on elderly persons with dementia in the nursing home and on nursing assistants: a randomized clinical trial. Int J Geriatr Psychiatry. Apr. 2005;20(4):330-43. [pmid: 15799079].
74 Fossey J, Ballard C, Juszczak E, et al. Effect of enhanced psychosocial care on antipsychotic use in nurshig home residents with severe dementia: cluster randomised trial. British Medical Journal. Apr. 1. 2006;332(7544):756-8A. [pmid: 16543297].
75 Galik E, Resnick B, Lerner N, et al. Function Focused Care for Assisted Living Residents With Dementia. Gerontologist. Jun. Suppl 1. 2015;55:S13-26. [pmid: 26055774].
76 Galik E, Resnick B, Hammersla M, et al. Optimizing function and physical activity among nursing home residents with dementia: testing the impact of function-focused care. Gerontologist. Dec. 2014;54(6):930-43. [pmid: 24092822].
77 Gozalo P, Prakash S, Qato DM, et al. Effect of the bathing without a battle training intervention on bathing-associated physical and verbal outcomes in nursing home residents with dementia: a randomized crossover diffusion study. J Am Geriatr Soc. May. 2014;62(5):797-804. [pmid: 24697702].
78 Kovach CR, Logan BR, Noonan PE, et al. Effects of the Serial Trial Intervention on discomfort and behavior of nursing home residents with dementia. Am J Alzheimers Dis Other Demen. Jun-Jul. 2006;21(3):147-55. [pmid: 16869334].
79 Magai C, Cohen CI, Gomberg D. Impact of training dementia caregivers in sensitivity to nonverbal emotion signals. Int Psychogeriatr. Mar. 2002;14(1):25-38. [pmid: 12094904].
80 McCabe MP, Bird M, Davison TE, et al. An RCT to evaluate the utility of a clinical protocol for staff in the management of behavioral and psychological symptoms of dementia in residential aged-care settings. Aging Ment Health. Sep. 2015;19(9):799-807. [pmid: 25319535].
81 McCallion P, Toseland RW, Lacey D, et al. Educating nursing assistants to communicate more effectively with nursing home residents with dementia. Gerontologist. Oct. 1999;39(5):546-58. [pmid: 10568079].
82 Proctor R, Burns A, Powell HS, et al. Behavioural management in nursing and residential homes: a randomised controlled trial. Lancet. Jul. 3. 1999;354(9172):26-9. [pmid: 10406361].
83 Rapp MA, Mell T, Majic T, et al. Agitation in nursing home residents with dementia (VIDEANT trial): effects of a cluster-randomized, controlled, guideline implementation trial. J Am Med Dir Assoc. Sep. 2013;14(9):690-5. [pmid: 23827658].
84 Rokstad AM, Rosvik J, Kirkevold O, et al. The effect of person-centred dementia care to prevent agitation and other neuropsychiatric symptoms and enhance quality of life in nursing home patients: a 10-month randomized controlled trial. Dement Geriatr Cogn Disord. 2013;36(5-6):340-53. [pmid: 24022375].
85 Schrijnemaekers V, van Rossum E, Candel M, et al. Effects of emotion-oriented care on elderly people with cognitive impairment and behavioral problems. Int J Geriatr Psychiatry. Oct. 2002;17(10):926-37. [pmid: 12325052].
86 Teri L, Huda P, Gibbons L, et al. STAR: A dementia-specific training program for staff in assisted living residences. Gerontologist. Oct. 2005;45(5):686-93. [pmid: 16199404].
87 Testad I, Aasland AM, Aarsland D. The effect of staff training on the use of restraint in dementia: a single-blind randomised controlled trial. Int J Geriatr Psychiatry. Jun. 2005;20(6):587-90. [pmid: 15920716].
88 Testad I, Ballard C, Bronnick K, et al. The Effect of Staff Training on Agitation and Use of Restraint in Nursing Home Residents With Dementia: A Single-Blind, Randomized Controlled Trial. J Clin Psychiatry. Jan. 2010;71(1):80-6. [pmid: 20129008].
89 van de Ven G, Draskovic I, Adang EM, et al. Effects of dementia-care mapping on residents and staff of care homes: a pragmatic cluster-randomised controlled trial. PLoS ONE. 2013;8(7):e67325. [pmid: 23844003].
90 Visser SM, McCabe MP, Hudgson C, et al. Managing behavioural symptoms of dementia: Effectiveness of staff education and peer support. Aging Ment Health. 2008. 2008;12(1):47-55. [pmid: 18297478].
91 Wells DL, Dawson P, Sidani S, et al. Effects of an abilities-focused program of morning care on residents who have dementia and on caregivers. J Am Geriatr Soc. Apr. 2000;48(4):442-9. [pmid: 10798473].
92 Wenborn J, Challis D, Head J, et al. Providing activity for people with dementia in care homes: a cluster randomised controlled trial. Int J Geriatr Psychiatry. Dec. 2013;28(12):1296-304. [pmid: 23637069].
93 Zwijsen SA, Smalbrugge M, Eefsting JA, et al. Coming to grips with challenging behavior: a cluster randomized controlled trial on the effects of a multidisciplinary care program for challenging behavior in dementia. J Am Med Dir Assoc. Jul. 2014;15(7):531.e1-10. [pmid: 24878214].
94 Baker R, Bell S, Baker E, et al. A randomized controlled trial of the effects of multi-sensory stimulation (MSS) for people with dementia. British Journal of Clinical Psychology. Mar. 2001;40:81-96. [pmid: 11317951].
95 Fitzsimmons S, Buettner LL. Therapeutic recreation interventions for need-driven dementia-compromised behaviors in community-dwelling elders. American journal of Alzheimer's disease and other dementias. 2002. 2002;17(6):367-81. [pmid: 12501484].
96 Hattori H, Hattori C, Hokao C, et al. Controlled study on the cognitive and psychological effect of coloring and drawing in mild Alzheimer's disease patients. Geriatr Gerontol Int. Oct. 2011;11(4):431-7. [pmid: 21518170].
97 Steinberg M, Leoutsakos J-MS, Podewils LJ, et al. Evaluation of home-based exercise program in the treatment of Alzheimer's disease: The Maximizing Independence in Dementia (MIND) Study. Int J Geriatr Psychiatry. Jul. 2009;24(7):680-5. [pmid: 19089875].
98 Tibaldi V, Aimonino N, Ponzetto M, et al. A randomized controlled trial of a home hospital intervention for frail elderly demented patients: behavioral disturbances and caregiver's stress. Arch Gerontol Geriatr Suppl. 2004;(9):431-6. [pmid: 15207444].
99 Belle SH, Burgio L, Burns R, et al. Enhancing the quality of life of dementia caregivers from different ethnic or racial groups: a randomized, controlled trial. [Summary for patients in Ann Intern Med. 2006 Nov 21;145(10):I39; PMID: 17116914]. Ann Intern Med. Nov. 21. 2006;145(10):727-38. [pmid: 17116917].
100 Bourgeois MS, Schulz R, Burgio LD, et al. Skills training for spouses of patients with Alzheimer's disease: Outcomes of an intervention study. Journal of Clinical Geropsychology. Jan. 2002;8(1):53-73.
101 Burgener SC, Bakas T, Murray C, et al. Effective caregiving approaches for patients with Alzheimer's disease. Geriatr Nurs. May-Jun. 1998;19(3):121-6. [pmid: 9708136].
102 Burgio L, Stevens A, Guy D, et al. Impact of two psychosocial interventions on white and African American family caregivers of individuals with dementia. Gerontologist. Aug. 2003;43(4):568-79. [pmid: 12937335].
103 Chien WT, Lee YM. A disease management program for families of persons in Hong Kong with dementia. Psychiatr Serv. Apr. 2008;59(4):433-6. [pmid: 18378844].
104 de Rotrou J, Cantegreil I, Faucounau V, et al. Do patients diagnosed with Alzheimer's disease benefit from a psycho-educational programme for family caregivers? A randomised controlled study. Int J Geriatr Psychiatry. Aug. 2011;26(8):833-42. [pmid: 20922772].
105 Gallagher-Thompson D, Wang P-C, Liu W, et al. Effectiveness of a psychoeducational skill training DVD program to reduce stress in Chinese American dementia caregivers: Results of a preliminary study. Aging Ment Health. Apr. 2010;14(3):263-73. [pmid: 20425645].
106 Gerdner LA, Buckwalter KC, Reed D. Impact of a psychoeducational intervention on caregiver response to behavioral problems. Nursing Research. Nov-Dec. 2002;51(6):363-74. [pmid: 12464756].
107 Gitlin LN, Winter L, Corcoran M, et al. Effects of the home environmental skill-building program on the caregiver-care recipient dyad: 6-month outcomes from the Philadelphia REACH Initiative. Gerontologist. Aug. 2003;43(4):532-46. [pmid: 12937332].
108 Gitlin LN, Winter L, Burke J, et al. Tailored activities to manage neuropsychiatric behaviors in persons with dementia and reduce caregiver burden: a randomized pilot study. Am J Geriatr Psychiatry. Mar. 2008;16(3):229-39. [pmid: 18310553].
109 Gitlin LN, Winter L, Dennis MP, et al. A biobehavioral home-based intervention and the well-being of patients with dementia and their caregivers: the COPE randomized trial. JAMA. Sep. 1. 2010;304(9):983-91. [pmid: 20810376].
110 Gitlin LN, Winter L, Dennis MP, et al. Targeting and managing behavioral symptoms in individuals with dementia: a randomized trial of a nonpharmacological intervention. J Am Geriatr Soc. Aug. 2010;58(8):1465-74. [pmid: 20662955].
111 Gonyea JG, O'Connor MK, Boyle PA. Project CARE: a randomized controlled trial of a behavioral intervention group for Alzheimer's disease caregivers. Gerontologist. Dec. 2006;46(6):827-32. [pmid: 17169938].
112 Gonzalez EW, Polansky M, Lippa CF, et al. Enhancing resourcefulness to improve outcomes in family caregivers and persons with Alzheimer's disease: a pilot randomized trial. Int J Alzheimer Dis. 2014;2014:323478. [pmid: 25328754].
113 Gormley N, Lyons D, Howard R. Behavioural management of aggression in dementia: a randomized controlled trial. Age and Ageing. Mar. 2001;30(2):141-5. [pmid: 11395344].
114 Guerra M, Ferri CP, Fonseca M, et al. Helping carers to care: the 10/66 dementia research group's randomized control trial of a caregiver intervention in Peru. Revista Brasileira de Psiquiatria. Mar. 2011;33(1):47-54. [pmid: 20602013].
115 Hebert R, Leclerc G, Bravo G, et al. Efficacy of a support group programme for caregivers of demented patients in the community: A randomized controlled trial. Archives of Gerontology and Geriatrics. Jan-Feb. 1994;18(1):1-14. [pmid: 15374309].
116 Huang H-L, Kuo L-M, Chen Y-S, et al. A home-based training program improves caregivers' skills and dementia patients' aggressive behaviors: A randomized controlled trial. The American Journal of Geriatric Psychiatry. Nov. 2013;21(11):1060-70. [pmid: 23933422].
117 Klodnicka Kouri K, Ducharme FC, Giroux F. A psycho-educational intervention focused on communication for caregivers of a family member in the early stage of Alzheimer's disease: Results of an experimental study. Dementia: The International Journal of Social Research and Practice. Aug. 2011;10(3):435-53.
118 Marriott A, Donaldson C, Tarrier N, et al. Effectiveness of cognitive-behavioural family intervention in reducing the burden of care in carers of patients with Alzheimer's disease. Br J Psychiatry. Jun. 2000;176:557-62. [pmid: 10974962].
119 Mittelman MS, Roth DL, Haley WE, et al. Effects of a caregiver intervention on negative caregiver appraisals of behavior problems in patients with Alzheimer's disease: results of a randomized trial. J Gerontol B Psychol Sci Soc Sci. Jan. 2004;59(1):P27-34. [pmid: 14722336].
120 Moniz-Cook E, Elston C, Gardiner E, et al. Can training community mental health nurses to support family carers reduce behavioural problems in dementia? An exploratory pragmatic randomised controlled trial. Int J Geriatr Psychiatry. Feb. 2008;23(2):185-91. [pmid: 17621379].
121 Nobili A, Riva E, Tettamanti M, et al. The effect of a structured intervention on caregivers of patients with dementia and problem behaviors: a randomized controlled pilot study. Alzheimer Dis Assoc Disord. Apr-Jun. 2004;18(2):75-82. [pmid: 15249851].
122 Ostwald SK, Hepburn KW, Caron W, et al. Reducing caregiver burden: a randomized psychoeducational intervention for caregivers of persons with dementia. Gerontologist. Jun. 1999;39(3):299-309. [pmid: 10396888].
123 Teri L, Logsdon RG, Peskind E, et al. Treatment of agitation in AD: a randomized, placebo-controlled clinical trial. [Erratum appears in Neurology 2001 Feb 13;56(3):426]. Neurology. Nov. 14. 2000;55(9):1271-8. [pmid: 11087767].
124 Ulstein ID, Sandvik L, Wyller TB, et al. A one-year randomized controlled psychosocial intervention study among family carers of dementia patients - Effects on patients and carers. Dementia and Geriatric Cognitive Disorders 2007. 2007;24(6):469-75.
125 Weiner MF, Tractenberg RE, Sano M, et al. No long-term effect of behavioral treatment on psychotropic drug use for agitation in Alzheimer's disease patients. J Geriatr Psychiatry Neurol. 2002;15(2):95-8. [pmid: 12083600].
126 Wright LK, Litaker M, Laraia MT, et al. Continuum of care for Alzheimer's disease: a nurse education and counseling program. Issues Ment Health Nurs. Apr-May. 2001;22(3):231-52. [pmid: 11885210].