# Caregiver-Level Interventions for Agitation/Aggression in Community-Dwelling Individuals With Dementia

Table F1 Caregiver-level interventions for agitation/aggression in community-dwelling individuals with dementia: risk of bias assessments

Study | Risk of Bias Assessment
Belle, 2006^99^ | Moderate - Assessors blinded, unsure about participants; attention control; minor missing data issues as they used only available data.
Bourgeois, 2002^100^ | Moderate - Manualized and good fidelity, but statistical power unclear.
Burgener, 1998^101^ | High - Random assignment only mentioned in abstract; randomization method unclear; blinding unclear; no methods section.
Burgio, 2003^102^ | High - Minimization randomization technique used; staff not blinded, unsure about participants. Handling of missing data unclear, possibly used only complete data.
Chien, 2008^103^ | Moderate - Appropriate statistics, some key intervention details unclear, attrition unclear.
De Rotrou, 2011^104^ | Moderate - Adequate randomization, manualized protocol, waitlist controls; appropriate analysis methods.
Gallagher-Thompson, 2010^105^ | Moderate - Adequate randomization, manualized intervention with high fidelity likely, information control; low attrition.
Gerdner, 2002^106^ | Moderate - Not a crossover study; extremely high attrition; outcome assessors blinded; participant blinding unclearly only included outcomes from one measure, did not include from another scale used. Nearly ITT analysis (excluded 4 people, only about 1.5% of this study).Unclear randomization method, no mention of blinding of participants, interventionists and fidelity checks. Outcome assessors blinded. No mention of power analysis, high attrition.
Gitlin, 2003^107^ | Moderate - Blinding unclear; not corrected for multiple comparisons; high attrition.
Gitlin, 2008^108^ | Moderate - Blinding unclear; not ITT analysis, waitlist control, low attrition.
Gitlin, 2010a109 | Moderate - Attrition at 9 months (over 20%), though okay at 4 months. Blinding unclear. Unsure where .5 SD clinical significance comes from (cites Belle, but only says it's consistent with this article, not a reason why it matters). Not ITT analysis. Does not report 9 month results adequately.
Gitlin, 2010b110 | Moderate - Blinding unclear. Differential attrition approaching 20% in one group. Call it an ITT analysis, but they do not include those lost to followup in analyses.
Gonyea, 2006^111^ | High - Participant blinding unclear; assessors not blinded; not ITT analysis.
Gonzalez, 2014^112^ | Moderate - Lack of important study design and analysis details, unclear if monthly fidelity checks adequate.
Gormley, 2001^113^ | Moderate - Participant blinding unclear; assessor blinded; no attrition.
Guerra, 2011^114^ | Low - Participant blinding unclear, but staff and outcomes assessors blinded; very low attrition.
Hebert, 1994^115^ | High - Moderate attrition, lack of intervention and study design detail.
Huang, 2013^116^ | Moderate - Intervention manualized and theory-based, likely good fidelity, but randomization and outcome assessment methods unclear.
Klodnicka, 2011^117^ | Moderate - Manualized, fidelity adequate, information control; low attrition.
Marriott, 2000^118^ | Moderate - Single-blind (assessors); very low attrition (only one dyad).
Mittelman, 2004^119^ | Moderate - Blinding unclear; extremely high attrition after 4 month followup; ITT analysis.
Moniz-Cook, 2008^120^ | High - Poor randomization method. Extremely high attrition. Blinding unclear. Not ITT analysis, but data were analyzed unless patients died or were institutionalized.
Nobili, 2004^121^ | High - Blinding unclear; extremely high attrition; last observation carried forward used for missing data, poor method.
Ostwald, 1999^122^ | Moderate - Blinding unclear; 19.7% attrition; not ITT analysis.
Teri, 2000^123^ | Moderate - Very high attrition at 6 months. Outcome assessors blinded, unclear about participants and caregivers. ITT analyses, though using last value carried forward is a biased method.
Ulstein, 2007^124^ | Moderate - Staff and outcomes assessors not blinded. ITT analyses, though using last value carried forward is a based method. Moderate attrition at 12 months, but lower before that.
Weiner, 2002^125^ | High - Secondary data analysis; very high attrition; possibly not eligible due to no valid control group (placebo pill or medications with behavior therapy only); most study information unclear; original study was Teri 2000.
Wright, 2001^126^ | High - Difference in minority group representation and severity of dementia despite randomization; outcome assessors not blinded, same providers who delivered intervention; ITT analysis.

## Descriptions of Community-Level Intervention Trials Rated High Risk of Bias

The Geriatric Home Hospitalization Service in Torino conducted a randomized controlled trial on 109 elderly, demented patients requiring admission for acute illnesses.98 They compared home hospital care to a general medical ward care in reducing behavioral disturbances in elderly individuals with dementia.

Burgener et al. randomized 54 home-dwelling patients with dementia and their caregivers to educational and behavioral intervention or a control group.101 There were no group differences in outcomes relevant to our review.

Burgio et al. developed and studied manual-guided, replicable interventions based on common needs and cultural preferences of White and African American family caregivers of community-dwelling individuals with dementia.102 Caregivers (70 White and 48 African American) were randomized to either a skills training condition or a minimal support control condition. Both interventions were delivered. according to protocol and well received by caregivers. Both groups reported decreasing levels of problem behavior and appraisals of behavioral bother.

Gonyea et al. reported on Project CARE, a randomized controlled trial designed to test the effectiveness of a caregiver-based multicomponent behavioral intervention aimed to reduce caregiver burden/distress associated with behavioral symptoms and reduce behavioral symptom severity among individuals with Alzheimer's disease.111 The behavioral intervention involved five weekly sessions designed to teach caregivers specific techniques for managing patient behavioral symptoms in the home environment. Eighty caregivers were assigned to either the behavioral intervention group or a psychoeducational control group. Caregivers in the intervention group displayed greater reductions in caregiver distress (p=.005). Global caregiver burden, however, did not decrease significantly for caregivers in either group (p>.05). Although it was not statistically significant, there was a trend toward greater reductions in care recipients' neuropsychiatric symptom severity in the intervention group (p=.10).

Hebert et al., in an unblinded design, randomized 41 caregivers to a support group or waitlist control.115 Randomization and allocation methods were not reported. The support group consisted of eight weekly 2-hour sessions to discuss behavioral problems, develop stress management skills, and provide support. It was unclear if the intervention was manualized or theory-based. There was no effect of treatment on patients' behavior as measured by RMBPC at posttreatment.

Moniz-Cook et al. evaluated the effects of training community health nurses in a systematic psychosocial intervention to help family carers manage behavioural changes in individuals with dementia.120 One hundred and thirteen family carers received the intervention or a 'usual practice'. Problem behaviour reduced with intervention with some but not all community health nurses. Carer management and mood improved with PSI support. In contrast, by 18 months, families supported by the intervention reported reduced coping resources, increased problem behaviour and their level of depression worsened.

Nobili et al. assessed the effects of a structured intervention on caregiver stress and the institutionalization rate among individuals with dementia and problem behaviors.121 Caregivers were recruited through the Federazione Alzheimer Italia. Eligible caregiver-patient dyads were randomized to intervention or usual care. Mean problem behavior score in the 39 families completed the 12-month followup was significantly lower with intervention than control (p <0.03).

Weiner et al. randomized caregivers to behavior management techniques, trazodone, and haloperidol for the treatment of agitated behaviors in individuals with dementia.125 This study reports on the 12-month outcomes, 4 month outcomes were reported in another publication. After 4 months, treatment was allowed with any agent. Nearly half of the individuals with dementia received additional psychotropics between 4 and 12 months. The relative risk of being prescribed any psychotropic drug was similar across groups.

Wright et al. evaluated a 1-year long course education and counseling program with 93 family caregivers of individuals with dementia.126 Individuals with dementia received treatment for agitation in an inpatient setting and were subsequently discharged. Caregivers were randomly assigned to intevention (n = 68) or control (n = 25). There were no significant treatment effects for care recipient agitation, caregiver stress and no significant differences between groups in rates of institutionalization. Longitudinal data revealed several important trends. Agitation in individuals with dementia rose steadily with control but declined for intervention.

Table F2 Caregiver-level interventions: strength of evidence assessments

Setting Intervention vs. Comparison | Outcome | Summary Statistics | Risk of Bias | Directness | Precision | Consistency | Reporting Bias | Strength of Evidence
Knowledge-skills vs. no treatment Guerra, 2012 Ostwald, 1999 | Patient General Behavior K=2; n=140 | NPI-Q severity score114 ASMD (CI): -0.10 (-0.66 to 0.48) RMBPC, disruptive behavior subscale122 Baseline, mean (SD): 6.75 (5.55) vs. 5.32 (4.10) 3-months, mean (SD): 6.16 (5.26) vs. 4.87 (3.54) 5-months, mean (SD): 6.35 (5.20) vs. 6.68 (4.50) | Moderate | Direct | Imprecise | Consistent | Undetected | Insufficient
Knowledge-skills vs. no treatment Guerra, 2012 Ostwald, 1999 | Patient distress/QoL k=1; n=56 | DEMQOL114 ASMD (CI): 0.32 (-0.84 to 1.48) | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Knowledge-skills vs. no treatment Guerra, 2012 Ostwald, 1999 | Caregiver Burden K=2; n=140bars | ZBS114 ASMD (CI): -1.02 (-0.53 to 0.51) ZBS122 Baseline, mean (SD): 56.18 (13.29) vs. 56.54 (15.97) 3-months, mean (SD): 56.82 (11.83) vs. 55.43 (15.91) 5-months, mean (SD): 54.13 (11.29) vs. 59.81 (15.23) | Moderate | Indirect | Imprecise | Consistent | Undetected | Insufficient
Knowledge-skills vs. no treatment Guerra, 2012 Ostwald, 1999 | Caregiver QoL k=1; n=88 | WHO-QoL-Bref, Psych 114 ASMD (CI): 0.10 (-0.47 to 0.68) | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Knowledge-skills vs. no treatment Guerra, 2012 Ostwald, 1999 | Caregiver Behavior k=1; n=84 | RMBPC, caregiver response to disruptive behavior subscale122 Baseline, mean (SD): 6.76 (6.27) vs. 5.20 (5.10) 3-months, mean (SD): 5.00 (5.38) vs. 4.42 (4.23) 5-months, mean (SD): 4.08 (4.44) vs. 5.73 (4.42) | Moderate | Direct | Imprecise | Unknown | Undetected | Insufficient
Knowledge-affect vs. attention control Chein, 2008^103^ | Patient General Behavior K=1; n=88 | NPI103 [underlined: Mean(SD) posttreatment (6 mo)] 68.1 (10.2) vs. 84.5 (9.8) [underlined: Mean (SD) at 12 mo followup:] 64.2(11.8) vs. 85.1(12.1) | Moderate | Direct | Imprecise | Unknown | Undetected | Insufficient
Knowledge-affect vs. attention control Chein, 2008^103^ | Caregiver Burden K=1; n=88 | Family Caregiver Burden Inventory103 [underlined: Mean (SD) posttreatment (6 mo)] 56.7 (15.7) vs. 63.0 (15.1) [underlined: Mean (SD) at 12 mo followup:] 48.3 (13.9) vs. 65.9 (16.3) | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Knowledge-affect vs. attention control Chein, 2008^103^ | Caregiver QoL k=1; n=88 | WHO-QoL103 [underlined: Mean (SD) posttreatment (6 mo)] 75.1 (16.8) vs. 69.8 (16.7) [underlined: Mean (SD) at 12 mo followup:] 81.4 (16.0) vs. 65.2(17.5) | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Skills-Knowledge vs. waitlist, usual care, or info control De Rotrou, 2011 Klondnica, 2011 Gallagher-Thompson, 2010 Ulstein, 2007 Gitlin, 2003 | Patient General Behavior K=5; n=657 | NPI104 [underlined: Mean (SD) posttreatment (3 mo):] 16.56 (17.20) vs. 16.29 (13.78) [underlined: Mean (SD) at 6 mo followup:] 15.8 (16.0) vs. 14.2 (13.0); p=0.57 RMBPC (communication difficulties) – Adjusted mean (SD) at 6 wk117 1.74 (0.55) vs. 1.70 (0.59); F=69.1 (p<0.001) RMBPC – Mean (SD) 4 months105 11.6 (5.2) vs. 11.0 (4.2) RMPBC no. of disruption-related behaviors AMD (CI)107 -.07 (-46 to .33) NPI-S, 4.5 month MD in MC (SD)124 0.8 (-3.61 to 5.28) NPI-S, 12 month MD in MC (SD)124 -2.2 (-2.65 to 7.06) | Moderate | Direct | Imprecise | Consistent | Undetected | Low
Skills-Knowledge vs. waitlist, usual care, or info control De Rotrou, 2011 Klondnica, 2011 Gallagher-Thompson, 2010 Ulstein, 2007 Gitlin, 2003 | Caregiver Burden K=2; n=337 | ZBI104 [underlined: Mean (SD) posttreatment (3 mo):] 22.18 (12.49) vs. 23.56 (16.99); [underlined: Mean (SD) at 6 mo followup:] 23.0 (14.6) vs. 26.5 (17.0); p=0.25 RSS, 4.5 month, MD in MC (SD)124 -0.1 (-2.50 to 2.32) RSS, 12 month MD in MC (SD)124 -1.2 (-4.23 to 1.79) | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Skills-Knowledge vs. waitlist, usual care, or info control De Rotrou, 2011 Klondnica, 2011 Gallagher-Thompson, 2010 Ulstein, 2007 Gitlin, 2003 | Caregiver Behavior k=1; n=190 | Perceived change in ability to manage caregiving AMD (CI)107 .12 (-.05 to .30) Mastery AMD (CI)107 .11 (-.05 to .27) | Moderate | Direct | Imprecise | Unknown | Undetected | Insufficient
Skills-Knowledge vs Haloperidol Teri, 2000 | Patient Agitation/Aggression K=1; n=75 | Improved score on ADCS-CGIC, RR (CI)123 1.0 [0.7 to 1.4] CMAI, MC (SD)123 -3.37 (11.45) vs. -7.26 (22.51) ABID Frequency MC(SD)123 -3.61 (9.88) vs. -6.74 (16.22) | Moderate | Direct | Imprecise | Unknown | Undetected | Insufficient
Skills-Knowledge vs Haloperidol Teri, 2000 | Patient General Behavior K=1; n=75 | BRSD, MC (SD)123 -3.56 (12.85) vs. -5.35 (22.41) RMBPC Total Frequency123 -0.08 (0.54) vs. -0.17 (0.65) | Moderate | Direct | Imprecise | Unknown | Undetected | Insufficient
Skills-Knowledge vs Haloperidol Teri, 2000 | CG Distress K=1; n=75 | ABID Reaction, MC (SD)123 -2.41 (6.71) vs. -3.27 (9.10) | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Skills-Knowledge vs Haloperidol Teri, 2000 | CG Burden K=1; n=75 | SCB Subjective, MC (SD)123 -2.95 (7.29) vs. -1.88 (8.89) SCB Objective, MC (SD)123 -1.23 (3.32) vs. -0.44 (3.22) | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Skills-Knowledge vs placebo Teri, 2000 | Patient Agitation/Aggression K=1; n=75 | Improved score on ADCS-CGIC, RR(CI)123 1.0 [0.7 to 1.4] CMAI, MC (SD)123 -3.37 (11.45) vs. -5.94 (18.50) ABID Frequency MC (SD)123 -3.61 (9.88) vs. -3.94 (15.44) | Moderate | Direct | Imprecise | Unknown | Undetected | Insufficient
Skills-Knowledge vs placebo Teri, 2000 | Patient General Behavior K=1; n=75 | BRSD, MC (SD)123 -3.56 (12.85) vs. -5.28 (24.36) RMBPC Total Frequency123 -0.08 (0.54) vs. -0.10 (0.52) | Moderate | Direct | Imprecise | Unknown | Undetected | Insufficient
Skills-Knowledge vs placebo Teri, 2000 | CG Distress K=1; n=75 | ABID Reaction, MC (SD)123 -2.41 (6.71) vs. -2.58 (10.28) | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Skills-Knowledge vs placebo Teri, 2000 | CG Burden K=1; n=75 | SCB Subjective, MC (SD)123 -2.95 (7.29) vs. -2.58 (9.67) SCB Objective, MC (SD)123 -1.23 (3.32) vs. -1.25 (4.02) | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Skills-behavior vs. waitlist/information control 2^108,112, 118^ Gonzalez, 2014 Gitlin, 2008 Marriot, 2000 | Patient Agitation/Aggression K=1; n=56 | Specific Behaviors-agitated108 AMD (CI)^c^: .06 (.01 to .56) Behavioral Occurrences108 AMD (CI)^c^: -.32 (-.55 to -.09) Number of Behaviors108 AMD (CI)^c^: -.98 (-2.67 to .71) | Moderate | Direct | Imprecise | Unknown | Undetected | Insufficient
Skills-behavior vs. waitlist/information control 2^108,112, 118^ Gonzalez, 2014 Gitlin, 2008 Marriot, 2000 | Patient General Behavior K=2; n=144 | RMBPC112 [underlined: Adjusted mean (SD) posttreatment:] 1.31 (.64) vs. 1.34 (.64); p=0.83 [underlined: Adjusted mean(SD) at 12 wk followup:] 1.3 (0.6) vs. 1.6 (0.6); p=0.11 MOUSE-PAD-Behavioral disturbance118 Baseline, mean (SD) 5.1 (2.1) vs. 5.1 (2.2) Post-treatment, mean (SD): 4.9 (0.2) vs. 5.6 (0.2) Followup, mean (SD): 5.3 (2.0) vs. vs. 5.2 (2.0) | Moderate | Direct | Imprecise | Inconsistent | Undetected | Insufficient
Skills-behavior vs. waitlist/information control 2^108,112, 118^ Gonzalez, 2014 Gitlin, 2008 Marriot, 2000 | Caregiver Behavior k=1; n=56 | Mastery108 AMD (CI)^c^: .34 (.08 to .60) Confidence using activities108 AMD (CI)^c^: 1.67 (.41 to 2.94) Strategy use108 AMD (CI)^c^: 0.25; (0.04 to 0.46) | Moderate | Direct | Precise | Unknown | Undetected | Insufficient
Skills-behavior vs. waitlist/information control 2^108,112, 118^ Gonzalez, 2014 Gitlin, 2008 Marriot, 2000 | Caregiver Burden K=2; n=158 | ZBS Subjective - Burden AMD (CI) ^c^ 108 .75 (-3.36 to 4.85) Caregiver Role Strain (global strain subscale) 112 [underlined: Mean (SD) posttreatment:] 1.94 (.83) vs. 1.84 (.83); p=0.43 [underlined: Mean (SD) at 12 wk followup:] 1.90 (0.88) vs. 1.85 (0.88); p=0.78 | Moderate | Indirect | Precise | Consistent | Undetected | Low
Skills-behavior vs. waitlist/information control 2^108,112, 118^ Gonzalez, 2014 Gitlin, 2008 Marriot, 2000 | Caregiver Distress K=1; n=56 | ZBS Subjective - Behavior Upset, AMD (CI) ^c^ 108 -.01 (-1.21 to 1.18) | Moderate | Indirect | Precise | Unknown | Undetected | Insufficient
Skills-behavior vs. attention control 5^106,109, 110,116, 118^ Huang, 2013 Gitlin, 2010a Gitlin, 2010b Gerdner, 2002 Marriot, 2000 | Patient Agitation/Aggression K=3; n=575 | CMAI – n(%) at 6 mo116 9 (16.4) vs. 14 (26.4); p=0.20 ABID109 AMD (CI)^a^: -.65 (-3.05 to 1.74) MBPC frequency (hierarchical linear model): Coefficient (SE) 106 Non-spouse experimental: REF Non-spouse comparison: 0.77 (0.36); p<.001 Spouse experimental: 0.18 (0.26) Spouse comparison: 0.18 (0.26) | Moderate | Direct | Imprecise | Consistent | Undetected | Low
Skills-behavior vs. attention control 5^106,109, 110,116, 118^ Huang, 2013 Gitlin, 2010a Gitlin, 2010b Gerdner, 2002 Marriot, 2000 | Patient General Behavior K=2; n=281 | Improvement in occurrence of targeted behavior, 16 weeks110 67.5% vs. 45.8%; p=.002 Target symptoms worsened/stayed the same, 16 weeks110 18.4%/14% vs. 31.7%%/22.5%; p>.05 MOUSE-PAD-Behavioral disturbance118 Baseline, mean (SD): 5.1 (2.1) vs. 5.4 (2.5) Post-treatment, mean (SD): 4.9 (0.2) vs. 5.0 (0.2) Followup, mean (SD): 5.3 (2.0) vs. 5.5 (2.4) | Moderate | Direct | Imprecise | Inconsistent | Undetected | Insufficient
Skills-behavior vs. attention control 5^106,109, 110,116, 118^ Huang, 2013 Gitlin, 2010a Gitlin, 2010b Gerdner, 2002 Marriot, 2000 | Patient Quality of Life K=1; n=209 | Patient QoL-AD109 AMD (CI)^a^: 0.10 (0.00 to 0.20) | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Skills-behavior vs. attention control 5^106,109, 110,116, 118^ Huang, 2013 Gitlin, 2010a Gitlin, 2010b Gerdner, 2002 Marriot, 2000 | Caregiver Behavior K=2; n=448 | Confidence using activities AMD (CI)^a^ 109 0.81 (0.30 to 1.32) Confidence managing behavior, 16 weeks AMD (CI)^b^ 110 0.33 (0.08 to 0.58) 24 weeks: 71.9% vs 29.1%; χ2=41.1; p=.001 | Moderate | Direct | Precise | Consistent | Undetected | Moderate
| Caregiver Burden K=2; n=448 | Caregiver Burden ZBS, 16 weeks110 AMD (CI) ^b^: -1.37 (-2.75 to 0.01) ZBS, 24 weeks110 AMD (CI) ^b^: -1.61 (-3.13 to -0.09) | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
| Caregiver Distress K=3; n=685 | MBPC reaction hierarchical linear model estimate106 -0.39; SE 0.18; p<.01 Perceived change in well-being Gitlin,109 AMD (CI)^a^: 0.22 (0.08 to 0.36) Perceived Change Index, 16 weeks110 AMD (CI) ^b^: 0.45 (0.29 to 0.62) Perceived Change Index, 24 weeks110 AMD (CI) ^b^: 0.29 (0.14 to 0.44) | Moderate | Indirect | Precise | Consistent | Undetected | Moderate
Skills-behavior vs. sham treatment K=2 100,113 (125) | Patient Agitation/Aggression K=2; n=125 | BEHAVE-AD aggressivility/activity disturbance subscale100 – Adjusted mean, (SD) posttreatment: 5.4 (4.2) vs. 5.3 (3.4) vs. 6.9 (3.3); NS adjusted mean(SD) at 6 mo followup: 5.6(3.8) vs. 5.2(3.6) vs. 8.4(2.4); treatments 1 &2 significantly lower than control (p<0.05) RAGE, postintervention mean(SD)113 6.9 (3.6) vs. 8.6 (4.5) | Moderate | Direct | Imprecise | Consistent | Undetected | Insufficient
Skills-behavior vs. sham treatment K=2 100,113 (125) | Patient General Behavior K=2; n=125 | BEHAVE-AD total score100 [underlined: Adjusted mean, (SD) posttreatment:] 15.2 (10.1) vs. 13.5 (6.3) vs. 18.4 (10.8); only self-change sig lower than control (p<0.05) [underlined: Adjusted mean(SD) at 6 mo followup:] 17.5(10.4) vs. 14.8(10.5) vs. 23.1(11.4); treatment 2 score significantly lower than control (p<0.01) BEHAVE-AD, postintervention113 Mean (SD)=6.5 (2.8) vs. 7.8 (3.4) | Moderate | Direct | Imprecise | Consistent | Undetected | Insufficient
Skills-behavior vs. sham treatment K=2 100,113 (125) | Taking psychotropic drugs K=1; n=62 | Postintervention, n/N (%)113 18 (52.9) vs. 17 (60.7) RR: 0.87 (0.56 to 1.35) | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Skills-behavior vs. sham treatment K=2 100,113 (125) | Caregiver Burden K=1; n=62 | ZBS, postintervention113 Mean (SD)=36 (12.3) vs. 41.2 (12.0) | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Skills-affect Belle, 2006 Mittleman, 2004 | Patient General Behavior K=2; n=924 | Problem behavior Change (%) in net improvement (CI)99 [underlined: Hispanic-Latino]: 36.3 (13.2 to 56.7) [underlined: Caucasian:] 13.6 (-6.3 to 35.3) [underlined: African-American:] -3.6 (-25.2 to 16.7) MBPC-frequency log growth model119 Estimate for group (SE): 0.24 (1.23); p=.84 Estimate for group x time (SE): -0.03 (0.86); p=.96 | Moderate | Indirect | Imprecise | Inconsistent | Undetected | Insufficient
Skills-affect Belle, 2006 Mittleman, 2004 | NH Admission K=1; n=518 | NH Admission Change (%) in net improvement (CI)99 [underlined: Hispanic-Latino]: -4.2 (-16.9 to 25.7) [underlined: Caucasian:] 0.51 (0.21 to 1.22) [underlined: African-American:] 1.54 (0.45 to 5.31) | Moderate | Indirect | Imprecise | Inconsistent | Undetected | Insufficient
Skills-affect Belle, 2006 Mittleman, 2004 | Caregiver Burden K=1; n=518 | Burden Change (%) in net improvement (CI)99 [underlined: Hispanic-Latino:] -4.6 (-23.7 to 15.4) [underlined: Caucasian:] 0.51 (0.21 to 1.22) [underlined: African-American:] 23.1 (0.6 to 45.7) | Moderate | Direct | Imprecise | Inconsistent | Undetected | Insufficient
Skills-affect Belle, 2006 Mittleman, 2004 | Caregiver Distress K=1; n=406 | MBPC-reaction: Estimate for group (SE): -2.90 (1.27) p=.02 Estimate for group x time (SE): -1.86; (0.89) p=.04 | Moderate | Direct | Precise | Unknown | Undetected | Insufficient

ABID=Agitated Behavior in Dementia; BEHAVE-AD=Behavioral Pathology in Alzheimer's disease; BRSD=Behavior Rating Scale for Dementia; CMAI=Cohen-Mansfield Agitation Inventory; NPI=Neuropsychiatric Inventory; RMBPC=Revised Memory and Behavior Problem Checklist