# Patient-Level Interventions for Agitation/Aggression in Community-Dwelling Individuals With Dementia

Table E1 Patient-level interventions for agitation/aggression in community-dwelling individuals with dementia: risk of bias assessments

Study | Risk of Bias Assessment
Baker, 2001^94^ | Moderate - Patient blinding unclear; assessor not blinded; attrition was low; ITT analyses attempted.
Fitsimmons, 2002^95^ | High - Results not presented in a way consistent with how we will need to analyze it. Pre-/post-test design with participants included in both groups in analyses likely to increase sample size.
Hattori, 2011^96^ | Moderate - Unblinded, standardization and fidelity to intervention unclear, multiple comparisons not corrected.
Steinberg, 2009^97^ | High - Not based on theory, randomization and allocation methods not described, standardization and fidelity to intervention unclear, very high attrition.
Tibaldi, 2004^98^ | High - Selection and detection bias; attrition and blinding unclear.

## Patient-Level Interventions for Agitation/Aggression in Community-Dwelling Individuals With Dementia: Descriptions of Trials Rated High Risk of Bias

Fitzsimmons et al. studied an at-home recreational therapy for community dwelling individuals with dementia and disturbing behaviors.95 Agitation was measured after 2 weeks of daily, individualized recreational therapy interventions.

Steinberg et al. reported randomizing 27 participants to an exercise program delivered by their caregivers, or control (home-safety assessment).97 Randomization and allocation methods were not described. The exercise program, which was not manualized or theory-based, incorporated aerobic exercises, strength training, and balance and flexibility training to be performed every day. A random effects model showed no effects of treatment on NPI scores.

Tibaldi et al. randomized 109 patients with severe dementia who were admitted to a hospital emergency room in Italy to either home hospitalization service or general medical ward control.98 The intervention was a service providing interactive treatment in patients' homes via geriatric health specialists. Significantly fewer behavioral disturbances were reported at posttreatment (discharge) in the intervention compared to regular in-patient care. However, there were issues with selection and detection bias, and pre-test scores were not available for all results.

Table E2 Patient-level interventions for agitation/aggression in community-dwelling individuals with dementia: strength of evidence assessments

Setting Intervention vs. Comparison | Outcome | Summary Statistics | Risk of Bias | Directness | Precision | Consistency | Reporting Bias | Strength of Evidence
Multisensory Stimulation vs. attention control94 | Patient Agitation/Aggression K=1; n=50 | REHAB deviant behavior AMD (CI)^c^: -.32 (-.55 to -.09) BRS social disturbance AMD (CI)^c^: -.32 (-.55 to -.09) | Moderate | Direct | Imprecise | Unknown | Undetected | Insufficient
Multisensory Stimulation vs. attention control94 | Patients General Behavior K=1; n=50 | REHAB general behavior MD (CI): ND BMD MD in MC: ND | Moderate | Direct | Unclear | Unknown | Undetected | Insufficient
Art therapy vs. activity vs. specialized activity96 | Patients General Behavior K=1; n=43 | Dementia Behavior Disturbance Scale, Mean (SD) Posttreatment: 16.8 (12.9) vs. 14.5 (12.7) | Moderate | Direct | Imprecise | Unknown | Undetected | Insufficient
Art therapy vs. activity vs. specialized activity96 | Patients Distress/QoL K=1; n=43 | SF-8, mental subscale Posttreatment mean (SD) 53.4 (3.3) vs. 52.9 (6.7) | Moderate | Indirect | Precise | Unknown | Undetected | Insufficient
Art therapy vs. activity vs. specialized activity96 | Caregiver Burden K=1; n=43 | ZBI Posttreatment, Mean (SD) 1 6.9 (9.1) vs. 16.5 (10.5) | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient

ABID=Agitated Behavior in Dementia; BARS=Brief Agitation Rating Scale; BEHAVE-AD=Behavioral Pathology in Alzheimer's disease; BMD=Behavior and Mood Disturbance; BRSD=Behavior Rating Scale for Dementia; CMAI=Cohen-Mansfield Agitation Inventory; DBRS=Disruptive Behavior Rating Scale; MBPC=Memory and Behavior Problem Checklist; MD=mean difference; MOSES=Multi-dimensional Observation Scale for Elderly Patients; NPI=Neuropsychiatric Inventory; PAS=Pittsburgh Agitation Scale; REHAB=Rehabilitation Evaluation Hall and Baker; RMBPC=Revised Memory and Behavior Problem Checklist; RR=risk ratio