# Care Delivery–Level Interventions for Agitation/Aggression in Nursing Home and Assisted Living Facilities

Table D1 Care delivery–level interventions for agitation/aggression in nursing home and assisted living facilities: risk of bias assessments

Study | Risk of Bias Assessment
Chapman, 2007^68^ | Moderate - Risk of contamination across groups; crossover design with incomplete reporting; attrition unclear.
Chenoweth, 2009^69^ | Moderate - Unclear: not balanced on several facility and patient level variables; low attrition, attrition higher than 20% in the control group at followup.
Clare, 2013^70^ | Low - Slightly underpowered in terms of patients but provided power calculation.
Davison, 2007^71^ | High - Intervention has been described elsewhere in greater detail; as a standalone article difficult to fully understand implementation; no power calculation, small sample, assessors not blinded; high attrition of staff; high detection bias.
Deudon, 2009^72^ | Moderate - Randomization unclear, groups unbalanced on key outcomes; even through no power calculation there was a relatively large number of observations in treatment and control.
Finnema, 2005^73^ | Low - Assessors not blinded but used a validation method to determine if this impacted results and found it did not; patient attrition >20% and staff attrition = 20%.
Fossey, 2006^74^ | Moderate - The unit of analysis is the NH but patients were not stable in the study and both groups experienced a large amount of turnover in terms of residents.
Galik, 2015^75^ (Assisted Living) | High - Unclear randomization method, attrition unclear.
Galik, 2014^76^ (Nursing Homes) | Moderate - Potential risk of bias due to detection bias (assessors could easily determine group assignment), attrition bias, and bias in the reporting of outcomes by group assignment).
Gozolo, 2014^77^ | High - Potential risk of bias due to detection bias (assessors could easily determine group assignment), attrition bias, and bias in the reporting of outcomes by group assignment).
Kovach, 2006^78^ | Moderate - Potential selection bias (method of randomization not clear) and detection bias (assessors not blinded).
Magai, 2002^79^ | Moderate - Reporting of outcomes is unclear and method of randomization was not adequately explained, unbalanced on race; method of randomization unclear, not balanced on race; unclear if reported CMAI or Behavioral Pathology in Alzheimer Disease Rating Scale; no power calculation.
McCabe, 2015^80^ | High - Adequacy of randomization unclear; intervention not adequately defined; no fidelity checks; blinding unclear, no ITT analysis, no group comparisons.
McCallion, 1999^81^ | Moderate – Unclear; method of randomization not clear, not balanced on some baseline variables including overall disease severity; no power calculation; only provided attrition info on staff; in control group attrition greater than 20% for staff; unclear regarding selection, detection, and attrition bias.
McGilton, 2003^41^ | Moderate - No ITT analysis; unclear if participants blinded; 15% attrition; groups similar at baseline on demographic characteristics, possibly different on agitation; intervention dose, fidelity issues, small sample size.
Proctor, 1999^82^ | Moderate - Unclear method of randomization; unclear performance bias; unclear blinding.
Rapp, 2013^83^ | Moderate - Performance bias (unclear application of the intervention) and detection bias (not blinding assessors).
Rokstad, 2013^84^ | Moderate - Not balanced on secondary outcomes; high attrition but no difference in groups in terms of attrition or reasons for attrition; unbalanced on some baseline measures.
Schrijneamaekers, 2002^85^ | Moderate - Facility selection unclear; different sources for reporting, risk of contamination; unclear (use of staff for reporting of outcomes); problems with missing data; paired group-randomized trial; unblinded assessors; participant blinding unclear; appropriate analysis; low attrition except at 12 months due to deaths.
Teri, 2005^86^ | Moderate - Unbalanced on baseline data, no info on attrition, focus on paper is really on implementation and development of intervention not testing it; method of randomization not clear and not balanced on baseline variables; no power calculation and small sample size; no information regarding attrition.
Testad, 2005^87^ | High - Not balanced on key baseline variables; unbalanced at baseline and high attrition; attrition in both groups at 6 months and 12 months higher than 20%; very high staff turnover; no power calculation and high attrition led to smaller sample sizes.
Testad, 2010^88^ | High - Attrition in both groups at 6 months and 12 months higher than 20%; also very high staff turnover.
van de Ven, 2013^89^ | Moderate - Unclear regarding performance and detection bias; unit of analysis is patient and NH but patients lost to followup were replaced with new patients but imputed missing data for resident questionnaires not completed; unclear if assessors blinded to the intervention; unclear if fidelity checks conducted.
Visser, 2008^90^ | High - Unclear regarding method of randomization and high detection bias; high attrition in one group but this group excluded from analysis; no power calculation and had small sample size, outcome assessors not blinded; not clear regarding fidelity; method of randomization unclear.
Wells, 2000^91^ | High – Randomization methods unclear, no power calculation, and high attrition; unclear: no power calculation; attrition was 28.5%, complete reasons for attrition not given, not clear how handled missing or incomplete data.
Wenborn, 2013^92^ | Moderate - Issues related to fidelity and high dropout; not clear if protocol followed exactly some residents could have received more activity; attrition >20% but similar in both groups, also say use ITT but clear how handled drop outs.
Zwijsen, 2014^93^ | Moderate - Bias in randomization and analysis unclear; complex cross-over design; fidelity checks not reported; unclear blinding of outcomes assessors.

## Care Delivery–Level Interventions for Agitation/Aggression in Nursing Home and Assisted Living Facilities: Description of Trials Rated High Risk of Bias

Eight studies were assessed as having a high risk of bias.71,75,77,80,87,88,90,91 These studies were not included in our narrative analysis but are described below.

Testad et al. compared a staff-training program designed to reduce restraint use (n = 55) and a control group (n = 96).87 The 7-month intervention consisted of educating staff on dementia-related behaviors and alternatives to the use of restraints. Intervention staff members were also provided with an hour of monthly guidance for 6 months. Treatment effects were tested with the Mann-Whitney U-test and Wilcoxon matched pairs signed rank test. At followup, use of restraints was significantly lower in the intervention group than in the control (p = 0.017). The intervention and control groups did not statistically significantly differ on the measure of agitation or use of psychotropic drugs. This study had a high risk of bias due to high detection bias (potentially underpowered given no power calculation [resident N = 151] and unclear if assessor were blinded) and high attrition bias.

Visser et al. compared two interventions, staff education only (n = 21) and staff education with peer support (n = 23), to a control group over a 3-month period (n = 32).90 The education-only program trained staff members to manage behaviors with individualized approaches. The education and peer support intervention combined training in individualized approaches to behavior management with support to staff members. Treatment effects were evaluated with a mixed analysis of variance. Neither intervention group nor the control group differed significantly on measures of agitation on the CMAI or CMAI subscales. This study had a high risk of bias due to possible selection bias (unclear method of randomization), high detection bias (potentially underpowered given no power calculation and small sample size), and high performance bias (fidelity inadequately explained).

Wells et al. compared a staff-training program (n = 20) with a control group (n = 20).91 Over a 3-month period staff members in the intervention group attended five sessions on providing abilities-focused care. Treatment effects were estimated with repeated measures analysis of variance. Residents in the intervention group improved significantly in agitated behavior (measured by the agitation subscale of the MIBM) compared with the control group (p = 0.021). On the PAS, the intervention group exhibited nonsignificant improvements compared with the control (p = 0.19). Staff outcomes of stress and ease of caregiving did not differ between intervention and control. This study had a high risk of bias due to potential selection bias (unclear regarding method of randomization), potential detection bias (potentially underpowered given no power calculation and small sample size [resident N = 44] and failure to adjust for multiple comparisons), and high attrition bias.

Galik et al. compared function-focused care (n = 40) with attention control (n = 41). Assisted living facilities were randomized to treatment conditions and eligible residents within facilities were identified for participation.75 The intervention consisted for four components: 1) evaluation of person-fit within the environment; 2) staff education; 3) establish resident care plan and goals; and 4) provide support to staff. Treatment effects were evaluated using repeated measures regression. There was no significant difference in agitation (CMAI) between treatment and control group. There was no significant difference in staff outcomes (job satisfaction or observed performance) between groups. This study had a high risk of bias due to detection bias (assessors could easily determine group assignment), attrition bias, and bias in the reporting of outcomes by group assignment).

Gozalo et al. compared an intervention designed to reduce agitation during bathing (n = 134) with a wait-list control (n = 106).77 Up to five staff members from each intervention home attended a 2-day training session focused on effective communication strategies and interpreting behaviors as an unmet need. These five staff then trained other staff at their home institution. Fixed-effects regressions were estimated to evaluate treatment effects. We could not determine the effect of the intervention compared with the wait-list control group from the results presented. This study had a high risk of bias due to detection bias (assessors could easily determine group assignment), attrition bias, and bias in the reporting of outcomes by group assignment).

McCabe et al. compared a staff educational workshop with structured clinical protocol (n = 53), staff educational workshop with clinical support visits (n = 49), staff training in use of structured clinical protocol (n = 48), and usual care (n = 37).80 Staff in treatment groups with an educational workshop received an overview of the epidemiology of dementia and person-centered care strategies. Clinical support consisted of a trained mental health professional providing person-centered care strategies and support to staff. A mental health professional also helped to implement a clinical protocol. No details were provided regarding usual care. Treatment effects were evaluated using analysis of covariance. There was no significant difference in agitation (CMAI) between treatment groups. Staff in the training/support condition had lower stress than staff in the support only condition (p <0.05). There was no difference between groups on measures of staff disruption. This study had a high risk of bias due selection bias (unclear method of randomization) and performance bias (unclear if assessors blinded, poor fidelity, and poor description of intervention).

Davison et al. compared a staff-training program only (n = 46), a staff training combined with a peer-support program (n = 35), and usual care (n = 32).71 Staff training consisted of eight 60 to 90 minute sessions on care for dementia-related behaviors. The peer-support program consisted of facilitated informal group session among staff members to discuss challenging behaviors of residents. Analysis of covariance was used to evaluate treatment effects. Treatment and control groups did not differ significantly on staff emotional exhaustion or resident agitation as measured by CMAI. This study had a high risk of bias due to high performance bias (intervention not adequately described), high detection bias (potentially underpowered given no power calculation and small sample size [resident N = 113] and assessors not blinded), and high attrition bias.

Testad et al. compared a staff-training program designed to reduce the use of restraints (n = 75) with usual care (n = 70).88 All staff in intervention nursing homes were provided a 2-day seminar. In addition, study investigators led six monthly group guidance meetings. Repeated measures analysis of variance was used to evaluate treatment effects. At 6 months the proportion of residents who started, remained unchanged, or stopped interactional restrain differed between the intervention and control (Mann-Whitney test, p = 0.021). However, whether this difference favored the intervention or control is not clear. At 12 months (6 months post intervention) no evidence of treatment effect was observed. The intervention group improved significantly in CMAI scores relative to the control group over a 12-month period (mean difference -5.6 95% CI -10.2 – 1.0). Use of antipsychotic drugs over time did not differ significantly between intervention and control. This study had a high risk of bias due to high selection bias (not balanced on key baseline variables), high detection bias (potentially underpowered given no power calculation (resident n = 145) and attrition bias.

Table D2 Care delivery–level interventions for agitation/aggression in nursing home and assisted living facilities: strength of evidence assessments

Intervention vs. Comparison | Outcome (Instrument) | Summary Statistics | Risk of Bias | Directness | Precision | Consistency | Reporting Bias | Strength of Evidence
Dementia Care Mapping K=3; n=643 | Staff Behavior K=1; n=180 | QEAW emotion reactions, baseline Mean (SE)=13.69 (1.51) vs. 9.48 (1.40) QEAW emotion reactions, 4 months postintervention Mean (SE)=23.38 (1.67) vs. 25.97 (1.59) QEAW emotion reactions, 8 months postintervention Mean (SE)=53.28 (1.20) vs. 53.09 (1.12) Linear mixed-effect model p-value for group: 0.719 | Moderate | Direct | Precise | Unknown | Undetected | Insufficient
Dementia Care Mapping K=3; n=643 | Neuroleptic Drug Use K=1; n=159 | Antipsychotic use adjusted proportion, baseline 0.15% vs. 0.19% Antipsychotic use adjusted proportion, 4 months postintervention 0.19% vs. 0.14% Antipsychotic adjusted proportion, 8 months postintervention Adjusted Proportion=0.15% vs. 0.14% Hierarchical linear model: p-value for group: 0.01 | Low | Indirect | Imprecise | Unknown | Undetected | Insufficient
Dementia Care Mapping K=3; n=643 | Patient Agitation/Aggression K=3; n=643 | SMD: -0.12 (-0.66 to 0.42) | Moderate | Direct | Imprecise | Consistent | Undetected | Low
Dementia Care Mapping K=3; n=643 | Patient General Behavior K=3; n=643 | NPI, baseline69 Adjusted Mean (SE)=12.7 (5.1) vs. 16.9 (5.3) NPI, 4 months postintervention69 Adjusted Mean (SE)=16.8 (5.1) vs. 20.2 (5.4) NPI, 8 months postintervention69 Adjusted Mean (SE)=12.7 (5.1) vs. 16.9 (5.3) Hierarchical linear model:69 p-value for group: 0.68 NPI-Q84 MC(p-value between group) -0.2 vs. 1.4 (<0.01) NPI-Q84 Multivariate regression Coefficient (CI)= -2.7 (-4.6 to -0.7) NPI-NH, baseline89 Mean (SE)=5.35 (0.94) vs. 6.28 (0.88) NPI-NH, 4 months postintervention89 Mean (SE)=7.19 (0.95) vs. 4.45 (0.88) NPI-NH, 8 months postintervention89 Mean (SE)=6.28 (0.92) vs. 4.13 (0.86) Linear mixed-effect model89 p-value for group: 0.23 | Moderate | Indirect | Imprecise | Inconsistent | Undetected | Insufficient
Dementia Care Mapping K=3; n=643 | Injuries K=1; n=159 | Falls, injuries, drug errors, behavioral events, baseline Adjusted Proportion=0.40% vs. 0.25% Falls, injuries, drug errors, behavioral events, 4 months postintervention Adjusted Proportion=0.49% vs. 0.37% Falls, injuries, drug errors, behavioral events, 8 months postintervention) Adjusted Proportion=0.46% vs. 0.37% Hierarchical linear model: p-value for group: 0.15 | Moderate | Indirect | Unclear | Unknown | Undetected | Insufficient
Dementia Care Mapping K=3; n=643 | Staff Distress, Burden, QoL K=1; n=180 | GHQ 12, baseline Mean (SE)=17.48 (0.33) vs. 16.67 (0.29) GHQ 12, 4 months postintervention Mean (SE)=15.72 (0.38) vs. 14.89 (0.34) GHQ 12, 8 months postintervention Mean (SE)=14.57 (0.37) vs. 14.42 (0.32) Linear mixed-effect model: p-value for group: 0.122 Linear mixed-effect model p-value for group * time: 0.43 MJSS-HC, baseline Mean (SE)=76.98 (1.36) vs. 77.29 (1.44) MJSS-HC, 4 months postintervention Mean (SE) =76.40 (1.34) vs. 75.10 (1.43) MJSS-HC, 8 months postintervention Mean (SE)=78.08 (1.40) vs. 75.58 (1.46) Linear mixed-effect model p-value for group: 0.56 Linear mixed-effect model p-value for group * time: 0.069 | Moderate | Indirect | Precise | Unknown | Undetected | Insufficient
Person Centered Care K=3; n=775 | Neuroleptic Drug Use K=2; n=487 | Adjusted proportion, baseline69 0.42% vs. 0.19% Adjusted proportion, 4 months postintervention69 0.30% vs. 0.14% Adjusted proportion, 8 months postintervention69 0.34% vs. 0.14% Hierarchical linear model Chenoweth 2009) p-value for group: 0.01 Proportion taking neuroleptics74 MD (CI) = -19.5% (-47.1% to 3.0%) Dose of neuroleptics74 AMD (CI) = -4.0% (-29.9% to 22.0%) | Moderate | Indirect | Imprecise | Inconsistent | Undetected | Insufficient
Person Centered Care K=3; n=775 | Patient Agitation/Aggression K=2; n=487 | Standardized Mean Difference, 95% CI: -0.15 (-0.67 to 0.38) | Moderate | Direct | imprecise | Consistent | Undetected | Low
Person Centered Care K=3; n=775 | Patient General Behavior K=2; n=429 | NPI, baseline69 Adjusted Mean (SE)=21.3(6.8) vs. 16.9 (5.3) NPI, 4 months postintervention69 Adjusted Mean (SE)=16.8(5.1) vs. 20.2 (5.4) General Behavior NPI, 8 months postintervention69 Adjusted Mean (SE)=13.5 (5.1) vs. 15.3 (5.3) Hierarchical linear model69 p-value for group: 0.68 Hierarchical linear model69 p-value for group x time: p = 0.30 NPI-Q84 MC (p-value between group)=-0.7 vs. 1.4 (<0.01) Multivariate regression84 Coefficient (CI)= -2.4 (-4.1 to -0.6) | Low to Moderate | Indirect | Imprecise | inconsistent | Undetected | Insufficient
Person Centered Care K=3; n=775 | Injuries K=1; n=141 | Falls, injuries, drug errors, behavioral events, baseline Adjusted Proportion=0.43% vs. 0.25% Falls, injuries, drug errors, behavioral events, 4 months postintervention Adjusted Proportion=0.53% vs. 0.37% Falls, injuries, drug errors, behavioral events, 8 months postintervention Adjusted Proportion=0.44% vs. 0.37% Hierarchical linear model: p-value for group: 0.15 | Moderate | Indirect | Unclear | Unknown | Undetected | Insufficient
Protocols to reduce Neuroleptic Use K=3; n=1,263 | Neuroleptic Drug Use K=3; n=1,263 | Daily Dose SMD postintervention: -0.28 (-3.50 to 2.94) pooled | Low to Moderate | Indirect | Imprecise | Inconsistent | Undetected | Insufficient
Protocols to reduce Neuroleptic Use K=3; n=1,263 | Patient Agitation/Aggression K=2; n=604 | CMAI postintervention MD: -4.50 (-38.83 to 29.83) pooled | Low to Moderate | Direct | Imprecise | Inconsistent | Undetected | Insufficient
Emotion Oriented Care K=2; n=297 | Neuroleptic Drug Use K=1; n=151 | Psychotropic use ward unit caregivers linear multilevel model adjusted MD per month (p-value): 0.00 (NS) Psychotropic use 3-month ward unit caregivers linear multilevel model adjusted MD per month (p-value): 0.00 (NS) Psychotropic use 6-month ward unit caregivers linear multilevel model adjusted MD per month (p-value): 0.07 (NS) Psychotropic use 12-month ward unit caregivers linear multilevel model adjusted MD per month (p-value): 0.02 (NS) | Moderate | Indirect | Unclear | Unknown | Undetected | Insufficient
Emotion Oriented Care K=2; n=297 | Patient Agitation/Aggression K=2; n=297 | Combined CMAI, CMAI-physically aggressive, CMAI-verbally aggressive, BIP10-resltess behavior73 Multivariate Analysis of Variance Adjusted Means (F-test, p-value): 3.34 vs. 3.63 (0.43, 0.51) CMAI-verbal aggression Day-care unit caregivers linear multilevel model85 adjusted MD per month (p-value): 0.04 (NS) CMAI-verbal aggression 3-month day-care unit caregivers linear multilevel model85 adjusted MD per month (p-value): 1.54 (NS) CMAI-verbal aggression 6-month day-care unit caregivers linear multilevel model85 adjusted MD per month (p-value): 0.78 (NS) CMAI-verbal aggression 12-month day-care unit caregivers linear multilevel model85 adjusted MD per month (p-value): 0.41 (NS) CMAI-verbal aggression Ward unit caregivers linear multilevel model85 adjusted MD per month (p-value): -0.14 (NS) CMAI-verbal aggression 3-month ward unit caregivers linear multilevel model85 adjusted MD per month (p-value): -0.07 (NS) CMAI-verbal aggression 6-month ward unit caregivers linear multilevel model85 adjusted MD per month (p-value): -1.10 (NS) CMAI-verbal aggression 12-month ward unit caregivers linear multilevel model85 adjusted MD per month (p-value): -1.41 (NS) CMAI aggression Day-care unit caregivers linear multilevel model85 adjusted MD per month (p-value): 0.04 (NS) CMAI aggression 3-month day-care unit caregivers linear multilevel model85 adjusted MD per month (p-value): 0.59 (NS) CMAI aggression 6-month day-care unit caregivers linear multilevel model85 adjusted MD per month (p-value): 0.12 (NS) CMAI aggression 12-month day-care unit caregivers linear multilevel model85 adjusted MD per month (p-value): 0.67 (NS CMAI aggression Ward unit caregivers linear multilevel model85 adjusted MD per month (p-value): -0.13 (NS) CMAI aggression 3-month ward unit caregivers linear multilevel model85 adjusted MD per month (p-value): -0.87 (NS) CMAI aggression 6-month ward unit caregivers linear multilevel model85 adjusted MD per month (p-value): -0.83 (NS) CMAI aggression 12-month ward unit caregivers linear multilevel model85 adjusted MD per month (p-value): -1.18 (NS) CMAI physical nonaggression Day-care unit caregivers linear multilevel model85 adjusted MD per month (p-value): 0.03 (NS) CMAI physical nonaggression 3-month day-care unit caregivers linear multilevel model85 adjusted MD per month (p-value): 0.70 (NS) CMAI physical nonaggression 6-month day-care unit caregivers linear multilevel model85 adjusted MD per month (p-value): -0.85 (NS) CMAI physical nonaggression 12-month day-care unit caregivers linear multilevel model85 adjusted MD per month (p-value): 0.97 (NS CMAI physical nonaggression Ward unit caregivers linear multilevel model85 adjusted MD per month (p-value): -0.14 (NS) CMAI physical nonaggression 3-month ward unit caregivers linear multilevel model85 adjusted MD per month (p-value): -0.28 (NS) CMAI physical nonaggression 6-month ward unit caregivers linear multilevel model85 adjusted MD per month (p-value): -2.26 (<0.01) in favor of control CMAI physical nonaggression 12-month ward unit caregivers linear multilevel model85 adjusted MD per month (p-value): -1.27 (NS) | Low to Moderate | Direct | Imprecise | Consistent | Undetected | Insufficient
Emotion Oriented Care K=2; n=297 | Staff Distress, Burden, QoL K=1; n=146 | GHQ 12 Multivariate Analysis of Variance Adjusted Means improved and not improved (F-test, p-value): treatment 15.42 and 20.47 and control 19.14 and 14.19 (9.11, 0.003). QOS Multivariate Analysis of Variance Adjusted Means improved and not improved (F-test, p-value): treatment 23.02 and 24.73 and control 22.59 and 23.70 (1.51, 0.54) | Low | Indirect | Imprecise | Unknown | Undetected | Insufficient
MiscellaneousDeudon 2009)72 K=1; n=306 | Patient Agitation/Aggression K=1; n=306 | CMAI Linear mixed effect model coefficient for MC (SD) [p-value for difference between intervention and control]: -0.26 (0.05) vs. 0.02 (0.06) [0.001] CMAI physically nonaggressive behavior Linear mixed effect model coefficient for MC (SD) [p-value for difference between intervention and control]: -0.02 (0.002) vs. -0.003 (0.03) [<0.0001] CMAI verbally nonaggressive behavior Linear mixed effect model coefficient for MC (SD) [p-value for difference between intervention and control]: -0.02 (0.003) vs. 0.001 (0.004) [<0.001] CMAI physically aggressive behavior Linear mixed effect model coefficient for MC (SD) [p-value for difference between intervention and control]: -0.001 (0.002) vs. 0.004 (0.002) [0.142] CMAI verbally aggressive behavior Linear mixed effect model coefficient for MC for MC(SD) [p-value for difference between intervention and control]: -0.01 (0.004) vs. -0.001 (0.004) [0.571] | Low to Moderate | Direct | Precise | Unknown | Undetected | Insufficient
Miscellaneous Proctor 1999^82^ K=1; n=120 | Patient General Behavior K=1; n=120 | CRB AMD (CI)= -0.7 (-3.0 to 1.6) | Low to Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Miscellaneous Clare 2013^70^ K=1; n=65 | Staff Behavior K=1; n=65 | MBI Depersonalization Analysis of Covariance Adjusted Means (SE): 1.32 (0.04) vs. 0.53 (0.07) Analysis of Covariance F-test (p-value) of group * time: 2.55 (0.12) | Low | Indirect | Imprecise | Unknown | Undetected | Insufficient
Miscellaneous Clare 2013^70^ K=1; n=65 | Patient General Behavior K=1; n=65 | PRS Analysis of Covariance Adjusted Means (SE): 37.39 (2.32) vs. 34.71 (2.17) Analysis of Covariance F-test (p-value) of group * time: 0.25 (0.62) | Low | Indirect | Imprecise | Unknown | Undetected | Insufficient
Miscellaneous Clare 2013^70^ K=1; n=65 | Staff Distress, Burden, QoL K=1; n=65 | GHQ Analysis of Covariance Adjusted Means(SE): 6.63 (0.82) vs. 7.12(1.05) Analysis of Covariance F-test (p-value) of group * time: 0.22 (0.64) Emotional Exhaustion Analysis of Covariance Adjusted Means (SE):12.36(0.07) vs. 12.38 (0.07) Analysis of Covariance F-test (p-value) of group * time: 0.00 (0.99) | Low | Indirect | Imprecise | Unknown | Undetected | Insufficient
Miscellaneous Wenborn 2013^92^ K=1; n=159 | Neuroleptic Drug Use K=1; n=159 | Total Medications 4-week MD (CI)= 0.10 (-0.53 to 0.34, 0.66) 12-week AMD (CI)= -0.15 (-0.55 to 0.24 | Low to Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Miscellaneous Wenborn 2013^92^ K=1; n=159 | Patient Agitation/Aggression K=1; n=159 | CBS 4-week MD (CI)= 1.15 (-9.23 to 11.52) 12-week AMD (CI)= 4.13 (-21.10 to 29.36) | Low to Moderate | Direct | Imprecise | Unknown | Undetected | Insufficient
Miscellaneous Wenborn 2013^92^ K=1; n=159 | Patient General Behavior K=1; n=159 | CAPE BRS 4-week MD (CI)= 1.08 (-0.18 to 2.34) 12-week AMD (CI)= 0.52 (-1.63 to 2.67) | Low to Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Miscellaneous Kovach 2006^78^ K=1; n=114 | Patient General Behavior K=1; n=144 | BEHAVE AD, baseline Mean (SD)=7.43 (6.75) vs. 6.80 (5.47) BEHAVE AD, 2 weeks postintervention Mean (SD)=5.56 (5.64) vs. 6.15 (5.55) BEHAVE AD, 4 weeks postintervention Mean (SD)=4.68 (4.06) vs. 4.96 (4.39) Repeated Measures Analysis of Variance F-test (p-value) group x time: 0.70 (0.5) | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Miscellaneous Magai 2002^79^ K=1; n=95 | Patient Agitation/Aggression K=1; n=95 | Aggregate measure incorporating CDS, CMAI, and BEHAVE-AD, baseline Mean (SD)=83.7 (51.2) vs. 25.2 (5.2) vs. 40.6 (7.8) Aggregate measure incorporating CDS, CMAI, and BEHAVE-AD, 3 weeks postintervention Mean (SD)=69.1 (36.1) vs. 49.6 (27.2) vs. 75.4 (41.4) Aggregate measure incorporating CDS, CMAI, and BEHAVE-AD, 6 weeks postintervention Mean (SD)=69.1 (36.1) vs. 49.6 (27.2) vs. 75.4 (41.4) Aggregate measure incorporating CDS, CMAI, and BEHAVE-AD, 9 weeks postintervention Mean (SD)=71.8 (37.6) vs. 44.6 (23.7) vs. 63.1 (42.0) Aggregate measure incorporating CDS, CMAI, and BEHAVE-AD, 12 weeks postintervention Mean (SD)=65.5 (37.7) vs. 39.2 (15.2) vs. 61.6 (31.1) Repeated Measures Analysis of Variance F-test (p-value) for group: 2.28 (NS) Repeated Measures Analysis of Variance F-test (p-value) for group x interaction: 1.15 (NS) | Moderate | Direct | Imprecise | Unknown | Undetected | Insufficient
Miscellaneous McCallion 1999^81^ K=1; n=95 | Staff Behavior K=1; n=105 | Restraints use, baseline Mean (SD)=1.20 (1.34) vs. 1.82 (1.62) Restraints use, 3 months postintervention Mean (SD)=1.53 (1.56) vs. 2.04 (1.78) Random effects regression F-test (p-value) 3-month group: 43.99 (NS) F-test (p-value) 3-month group x interaction: 0.00 (NS) Restraints use, 6 months postintervention Mean (SD)=1.88 (1.82) vs. 1.75 (1.42) F-test (p-value) 6-month group: 7.20 (NS) F-test (p-value) 6-month group x interaction: 9.54 (<0.01) | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Miscellaneous McCallion 1999^81^ K=1; n=95 | Neuroleptic Drug Use K=1; n=105 | Psychotropic use, baseline Mean (SD)=0.98 (1.41) vs. 1.62(1.70) Psychotropic use, 3 months postintervention Mean (SD)=0.93 (1.39) vs. 1.7(1.82) Random effects regression F-test (p-value) 3-month group: 37.48 (NS) F-test (p-value) 3-month group x interaction: 1.78 (NS) Psychotropic use, 6 months postintervention Mean (SD)=1.30 (2.15) vs. 1.57 (1.71) F-test (p-value) 6-month group: 4.99 (NS) F-test (p-value) 6-month group x interaction: 1.61 (NS) | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Miscellaneous McCallion 1999^81^ K=1; n=95 | Patient Agitation/Aggression K=1; n=105 | CSDD behavioral disturbance, baseline Mean (SD)=2.00 (1.58) vs. 1.13 (1.06) CSDD behavioral disturbance, 3 months postintervention Mean (SD)=1.32 (1.40) vs. 0.98 (1.13) Random effects regression F-test (p-value) 3-month group: 49.20 (NS) Random effects regression F-test (p-value) 3-month group x interaction: 7.76 (<0.01) CSDD behavioral disturbance, 6 months postintervention Mean (SD)=1.26 (1.17) vs. 1.29 (1.29) F-test (p-value) 6-month group: 23.46 (NS) F-test (p-value) 6-month group x interaction: 18.64 (<0.001) CMAI aggressive behavior, Baseline Mean (SD)=15.16 (9.81) vs. 13.25(7.52) CMAI aggressive behavior, 3 months postintervention Mean (SD)=11.00 (5.35) vs. 12.46 (6.82) Random effects regression F-test (p-value) 3-month group: 0.23 (NS) Random effects regression F-test (p-value) 3-month group x interaction: 8.67 (NS) CMAI aggressive behavior, 6 months postintervention Mean (SD)=12.21 (8.31) vs. 12.02 (6.22) F-test (p-value) 6-month group: 6.02 (NS) F-test (p-value) 6-month group x interaction: 0.92 (NS) CMAI physically nonaggressive behavior, baseline Mean (SD)=12.49 (6.34) vs. 11.09 (5.47) CMAI physically nonaggressive behavior, 3 months postintervention Mean (SD)=10.36 (4.72) vs. 11.86 (6.54) Random effects regression F-test (p-value) 3-month group: 0.56 (NS) F-test (p-value) 3-month group x interaction: 17.59 (<0.001) CMAI physically nonaggressive behavior, 6 months postintervention Mean (SD)=11.38 (5.99) vs. 10.38 (6.32) F-test (p-value) 6-month group: 7.78 (NS) F-test (p-value) 6-month group x interaction: 0.26 (NS) CMAI verbally aggressive behavior, baseline Mean (SD)=16.22 (10.31) vs. 10.44 (6.21) CMAI verbally aggressive behavior, 3 months postintervention Mean (SD)=11.38 (7.13) vs. 11.52 (6.71) Random effects regression F-test (p-value) 3-month group: 38.65 (NS) F-test (p-value) 3-month group x interaction: 32.97 (<0.001) CMAI verbally aggressive behavior, 6 months postintervention Mean (SD)=12.88 (8.39) vs. 12.05 (6.86) F-test (p-value) 6-month group: 38.82 (NS) F-test (p-value) 6-month group x interaction: 14.23 (<0.001) | Moderate | Direct | Imprecise | Unknown | Undetected | Insufficient
Miscellaneous Teri 2005^86^ K=1; n=31 | Patient Agitation/Aggression K=1; n=31 | ABID AMC (SD)=-3.8 (4.0) vs. -0.5 (6.7) | Moderate | Direct | Precise | Unknown | Undetected | Insufficient
Miscellaneous Teri 2005^86^ K=1; n=31 | Patient General Behavior K=1; n=31 | NPI AMC (SD)= -3.5 (8.1) vs. 2.7 (10.0) RMBPC Total Score Frequency AMC (SD)= -1.1 (1.0) vs. 0.2 (0.8) RMBPC Disruption Frequency AMC (SD)= -0.2 (0.2) vs. 0.0 (0.3) | Moderate | Indirect | Precise | Unknown | Undetected | Insufficient
Miscellaneous Teri 2005^86^ K=1; n=31 | Staff Distress, Burden, QoL K=1; n=31 | NPI (staff impact) AMC (SD)= -1.2 (5.3) vs. 1.6 (4.2) RMBPC (reaction) AMC (SD)= -0.7 (1.0) vs. 0.2 (0.8) RMBPC-disruption (reaction) AMC (SD)= -0.1 (0.3) vs. 0.0 (0.0) Job Satisfaction AMC (SD)= 0.2 (0.4) vs. 0.00 (0.05) | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Miscellaneous Galik 2014^76^ K=1; n=103 | Patient Agitation/Aggression K=1; n=103 | CMAI baseline Control M (SE): 19.06 (1.05) Treatment M (SE): 16.57 (0.69) p-value difference between control and treatment: 0.08 CMAI 3-months Control M (SE): 3.18.95 (1.21) Treatment M (SE): 17.04 (0.69) p-value difference between control and treatment: 0.01 CMAI 6-months Control M (SE): 19.48 (1.46) Treatment M (SE): 17.83 (0.89) p-value difference between control and treatment: 0.36 | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Miscellaneous Galik 2014^76^ K=1; n=103 | Staff Distress, Burden, QoL K=1; n=103 | Staff QoL Job Satisfaction (Job Attitude Scale) baseline Control M (SE): 35.00 (1.02) Treatment M (SE): 39.37 (0.93) p-value difference between control and treatment: 0.002 Job Satisfaction (Job Attitude Scale) 3-months Control M (SE): 33.35 (1.19) Treatment M (SE): 37.85 (0.93) p-value difference between control and treatment: 0.003 Job Satisfaction (Job Attitude Scale) 6-months Control M (SE): 35.13 (1.24) Treatment M (SE): 36.89 (1.00) p-value difference between control and treatment: 0.280 | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Miscellaneous Galik 2014^76^ K=1; n=103 | Staff Behavior K=1; n=103 | The Restorative Care Behavior Checklist baseline Control M (SE): 0.55 (0.04) Treatment M (SE): 0.63 (0.04) p-value difference between control and treatment: 0.18 Function Focused Activities - The Restorative Care Behavior Checklist 3-months Control M (SE): 0.61 (0.04) Treatment M (SE): 0.71 (0.04) p-value difference between control and treatment: 0.12 Function Focused Activities - The Restorative Care Behavior Checklist 6-months Control M (SE): 0.40 (0.06) Treatment M (SE): 0.66 (0.05) p-value difference between control and treatment: 0.001 | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient
Miscellaneous Galik 2014^76^ K=1; n=103 | Harms K=1; n=103 | Falls 6-months Control N (%): 25 (50) Treatment N (%): 15 (28) p-value difference between control and treatment: 0.02 Emergency room visits for falls 6-months: Control N (%): 5 (10) Treatment N (%): 1 (2) p-value difference between control and treatment: 0.08 Injuries post falls 6-months Control N (%): 5 (10) Treatment N (%): 5 (9) p-value difference between control and treatment: 0.92 Deaths 6-months Control N (%): 3 (6) Treatment N (%): 5 (9) p-value difference between control and treatment: 0.45 | Moderate | Indirect | Imprecise | Unknown | Undetected | Insufficient

MD=mean difference; NA=not applicable; NR=not reported; RR=risk ratio