# Excluded Studies

(Reason for exclusion appears in italics following each reference)

1 Aguirre E, Spector A, Hoe J, et al. Maintenance Cognitive Stimulation Therapy (CST) for dementia: a single-blind, multi-centre, randomized controlled trial of Maintenance CST vs. CST for dementia. Trials. [Electronic Resource]. 2010;11:46. Intervention does not address agitation/aggression. [pmid: 20426866].
2 Akhondzadeh S, Noroozian M, Mohammadi M, et al. Melissa officinalis extract in the treatment of patients with mild to moderate Alzheimer's disease: A double blind, randomised, placebo controlled trial. Journal of Neurology, Neurosurgery & Psychiatry. Jul-Dec. 2003;74(7):863-6. Intervention does not address agitation/aggression.
3 Anderson K, Bird M, Macpherson S, et al. Findings from a pilot investigation of the effectiveness of a snoezelen room in residential care: should we be engaging with our residents more?. Geriatric Nursing. May-Jun. 2011;32(3):166-77. Not RCT. [pmid: 21306798].
4 Arango-Lasprilla JC, Panyavin I, Merchan EJH, et al. Evaluation of a group cognitive-behavioral dementia caregiver intervention in Latin America. American Journal of Alzheimer's Disease and Other Dementias. Sep. 2014;29(6):548-55. Intervention does not address agitation/aggression.
5 Ashida S. The effect of reminiscence music therapy sessions on changes in depressive symptoms in elderly persons with dementia. Journal of Music Therapy. Fal. 2000;37(3):170-82. Intervention does not address agitation/aggression. [pmid: 10990595].
6 Au A, Li S, Lee K, et al. The Coping With Caregiving group program for Chinese caregivers of patients with Alzheimer's disease in Hong Kong. Patient Education and Counseling. Feb. 2010;78(2):256-60. Intervention does not address agitation/aggression. [pmid: 19619974].
7 Au A, Wong MK, Leung LM, et al. Telephone-assisted pleasant-event scheduling to enhance well-being of caregivers of people with dementia: a randomised controlled trial. Hong Kong Medical Journal. Jun. 2014;20(3 Suppl 3):30-3. Intervention does not address agitation/aggression. [pmid: 25001033].
8 Avila R, Carvalho IA, Bottino CM, et al. Neuropsychological rehabilitation in mild and moderate Alzheimer's disease patients. Behavioural Neurology. 2007;18(4):225-33. Not nonpharm intervention(s). [pmid: 18430980].
9 Bach D, Bach M, Bohmer F, et al. Reactivating occupational therapy: a method to improve cognitive performance in geriatric patients. Age & Ageing. May. 1995;24(3):222-6. Trial does not report behavioral outcomes. [pmid: 7645443].
10 Baird A, Samson S. Music and dementia. Progress in Brain Research. 2015;217:207-35. Not RCT. [pmid: 25725917].
11 Ballard C, Brown R, Fossey J, et al. Brief psychosocial therapy for the treatment of agitation in Alzheimer disease (the CALM-AD trial). American Journal of Geriatric Psychiatry. Sep. 2009;17(9):726-33. Not RCT. [pmid: 19700946].
12 Ballard C, Gray A, Ayre G. Psychotic symptoms, aggression and restlessness in dementia. Revue Neurologique. 1999;155(Suppl 4):4S44-4S52. Not RCT.
13 Ballard C, Hanney ML, Theodoulou M, et al. The dementia antipsychotic withdrawal trial (DART-AD): Long-term follow-up of a randomised placebo-controlled trial. The Lancet Neurology. Feb. 2009;8(2):151-7. Trial does not report behavioral outcomes. [pmid: 19138567].
14 Barrick AL, Sloane PD, Williams CS, et al. Impact of ambient bright light on agitation in dementia. International Journal of Geriatric Psychiatry. Oct. 2010;25(10):1013-21. Not RCT. [pmid: 20104513].
15 Beauchamp N, Irvine A, Seeley J, et al. Worksite based internet multimedia program for family caregivers of persons with dementia. The Gerontologist. Dec. 2005;45(6):793-801. Intervention does not address agitation/aggression. [pmid: 16326661].
16 Berger G, Bernhardt T, Schramm U, et al. No effects of a combination of caregivers support group and memory training/music therapy in dementia patients from a memory clinic population. International Journal of Geriatric Psychiatry. Mar. 2004;19(3):223-31. Not RCT. [pmid: 15027037].
17 Bird M, Jones RH, Korten A, et al. A controlled trial of a predominantly psychosocial approach to BPSD: treating causality. International Psychogeriatrics. Oct. 2007;19(5):874-91. Not RCT. [pmid: 17234041].
18 Bourgeois MS, Burgio LD, Schulz R, et al. Modifying repetitive verbalizations of community-dwelling patients with AD. Gerontologist. Feb. 1997;37(1):30-9. PMID:. WOS:A1997WH81800005. Not RCT. [pmid: 9046703].
19 Brodaty H. Caregivers and behavioral disturbances: Effects and interventions. International Psychogeriatrics. 1996;8(Suppl 3):455-8. Not RCT. [pmid: 9154607].
20 Burgener SC, Yang Y, Gilbert R, et al. The effects of a multimodal intervention on outcomes of persons with early-stage dementia. American Journal of Alzheimer's Disease & Other Dementias. Aug-Sep. 2008;23(4):382-94. Intervention does not address agitation/aggression. [pmid: 18453642].
21 Burgio LD, Stevens A, Burgio KL, et al. Teaching and maintaining behavior management skills in the nursing home. Gerontologist. Aug. 2002;42(4):487-96. Not Dementia. [pmid: 12145376].
22 Burns R, Nichols LO, Martindale-Adams J, et al. Primary care interventions for dementia caregivers: 2-year outcomes from the REACH study. Gerontologist. Aug. 2003;43(4):547-55. PMID:. WOS:000184967700011. Not RCT. [pmid: 12937333].
23 Callahan CM, Boustani MA, Unverzagt FW, et al. Effectiveness of collaborative care for older adults with Alzheimer disease in primary care - A randomized controlled trial. Jama-Journal of the American Medical Association. May. 10. 2006;295(18):2148-57. PMID:. WOS:000237391300024. Not RCT.
24 Camic PM, Williams CM, Meeten F. Does a ‘Singing Together Group’ improve the quality of life of people with a dementia and their carers? A pilot evaluation study. Dementia. Mar. 2013;12(2):157-76. Not RCT. [pmid: 24336767].
25 Cerga-Pashoja A, Lowery D, Bhattacharya R, et al. Evaluation of exercise on individuals with dementia and their carers: a randomised controlled trial. Trials. [Electronic Resource]. 2010;11:53. Not RCT. [pmid: 20465799].
26 Chang FY, Huang HC, Lin KC, et al. The effect of a music programme during lunchtime on the problem behaviour of the older residents with dementia at an institution in Taiwan. Journal of Clinical Nursing. Apr. 2010;19(7-8):939-48. Not RCT. [pmid: 20492038].
27 Cheng ST, Lau RW, Mak EP, et al. A benefit-finding intervention for family caregivers of persons with Alzheimer disease: study protocol of a randomized controlled trial. Trials. [Electronic Resource]. 2012;13:98. Not RCT. [pmid: 22747914].
28 Chenoweth L, King MT, Jeon Y-H, et al. Caring for Aged Dementia Care Resident Study (CADRES) of person-centred care, dementia-care mapping, and usual care in dementia: A cluster-randomised trial. The Lancet Neurology. Apr. 2009;8(4):317-25. Duplicate reference. [pmid: 19282246].
29 Chiu YC, Lee YN, Wang PC, et al. Family caregivers' sleep disturbance and its associations with multilevel stressors when caring for patients with dementia. Aging & mental health. 2014;18(1):92-101. Not RCT. [pmid: 24053456].
30 Chodosh J, Colaiaco BA, Connor KI, et al. Dementia Care Management in an Underserved Community: The Comparative Effectiveness of Two Different Approaches. Journal of Aging & Health. Aug. 2015;27(5):864-93. Intervention does not address agitation/aggression. [pmid: 25656074].
31 Choi AN, Lee MS, Cheong KJ, et al. Effects of group music intervention on behavioral and psychological symptoms in patients with dementia: a pilot-controlled trial. International Journal of Neuroscience. 2009;119(4):471-81. Not RCT. [pmid: 19229716].
32 Choi A-N, Lee MS, Cheong K-J, et al. Effects of group music intervention on behavioral and psychological symptoms in patients with dementia: A pilot-controlled trial. International Journal of Neuroscience. Apr. 2009;119(4):471-81. Not RCT. [pmid: 19229716].
33 Chu H, Yang CY, Lin Y, et al. The impact of group music therapy on depression and cognition in elderly persons with dementia: a randomized controlled study. Biological Research for Nursing. Apr. 2014;16(2):209-17. Intervention does not address agitation/aggression. [pmid: 23639952].
34 Churchill M, Safaoui J, McCabe BW, et al. Using a therapy dog to alleviate the agitation and desocialization of people with Alzheimer's disease. Journal of psychosocial nursing and mental health services. 1999. Apr. 1999;37(4):16-22. Not RCT. [pmid: 10218187].
35 Clare L, Woods RT, Whitaker R, et al. Development of an awareness-based intervention to enhance quality of life in severe dementia: trial platform. Trials. [Electronic Resource]. 2010;11:73. Not RCT. [pmid: 20579370].
36 Clark PA, Bass DM, Looman WJ, et al. Outcomes for patients with dementia from the Cleveland Alzheimer's Managed Care Demonstration. Aging & Mental Health. Jan. 2004;8(1):40-51. Intervention does not address agitation/aggression. [pmid: 14690867].
37 Coen RF, Flynn B, Rigney E, et al. Efficacy of cognitive stimulation therapy programme for people with dementia. Irish Journal of Psychological Medicine. Sep. 2011;28(3):145-7. Intervention does not address agitation/aggression.
38 Cohen CI, Hyland K, Devlin M. An evaluation of the use of the natural helping network model to enhance the well-being of nursing home residents. The Gerontologist. Aug. 1999;39(4):426-33. Not RCT. [pmid: 10495580].
39 Cohen-Mansfield J, Dakheel-Ali M, Jensen B, et al. An analysis of the relationships among engagement, agitated behavior, and affect in nursing home residents with dementia. International Psychogeriatrics. May. 2012;24(5):742-52. Not RCT. [pmid: 22221823].
40 Cohen-Mansfield J, Marx MS, Thein K, et al. The impact of stimuli on affect in persons with dementia. Journal of Clinical Psychiatry. Apr. 2011;72(4):480-6. Not RCT. [pmid: 21527124].
41 Cohen-Mansfield J, Thein K, Marx MS, et al. The relationships of environment and personal characteristics to agitated behaviors in nursing home residents with dementia. Journal of Clinical Psychiatry. Mar. 2012;73(3):392-9. Not RCT. [pmid: 22152398].
42 Connell CM, Janevic MR. Effects of a telephone-based exercise intervention for dementia caregiving wives: A randomized controlled trial. Journal of Applied Gerontology. Apr. 2009;28(2):171-94. Intervention does not address agitation/aggression. [pmid: 21709757].
43 Cotelli M, Manenti R, Zanetti O. Reminiscence therapy in dementia: A review. Maturitas. Jul. 2012;72(3):203-5. Not RCT. [pmid: 22607813].
44 Crispim Nascimento CM, Ayan C, Cancela JM, et al. Effect of a multimodal exercise program on sleep disturbances and instrumental activities of daily living performance on Parkinson's and Alzheimer's disease patients. Geriatrics & Gerontology International. Apr. 2014;14(2):259-66. Intervention does not address agitation/aggression. [pmid: 23647635].
45 Cristancho-Lacroix V, Moulin F, Wrobel J, et al. A web-based program for informal caregivers of persons with Alzheimer's disease: an iterative user-centered design. JMIR Research Protocols. 2014;3(3):e46. Not RCT. [pmid: 25263541].
46 Cumbo E, Ligori LD. Differential effects of current specific treatments on behavioral and psychological symptoms in patients with Alzheimer's disease: a 12-month, randomized, open-label trial. Journal of Alzheimer's Disease. 2014;39(3):477-85. Not nonpharm intervention(s). [pmid: 24164733].
47 Cyarto EV, Cox KL, Almeida OP, et al. The fitness for the Ageing Brain Study II (FABS II): protocol for a randomized controlled clinical trial evaluating the effect of physical activity on cognitive function in patients with Alzheimer's disease. Trials. [Electronic Resource]. 2010;11:120. Not RCT. [pmid: 21143943].
48 Davison TE, Hudgson C, McCabe MP, et al. An individualized psychosocial approach for “treatment resistant” behavioral symptoms of dementia among aged care residents. International Psychogeriatrics. Oct. 2007;19(5):859-73. Not RCT. [pmid: 16973098].
49 Denney A. Quiet music. An intervention for mealtime agitation?. Journal of Gerontological Nursing. Jul. 1997;23(7):16-23. Not RCT. [pmid: 9287602].
50 Denormandie P, Dubost V, Marigot-Outtandy D, et al. Comparative study of two on aged care-based occupational (professional) training in medical home for aged and dependant patients with neuro-psychiatric behaviours. Geriatrie et Psychologie Neuropsychiatrie du Vieillissement. Jun. 2014;12(2):163-79. Not available in English. [pmid: 24939404].
51 Diamond K, Mowszowski L, Cockayne N, et al. Randomized controlled trial of a Healthy Brain Ageing Cognitive Training program: Effects on memory, mood, and sleep. Journal of Alzheimer's Disease. 2015;44(4):1181-91. Intervention does not address agitation/aggression.
52 Dias A, Dewey ME, D'souza J, et al. The effectiveness of a home care program for supporting caregivers of persons with dementia in developing countries: a randomised controlled trial from Goa, India. PLoS ONE. [Electronic Resource]. 2008;3(6):e2333. Not nonpharm intervention(s). [pmid: 18523642].
53 Done DJ, Thomas JA. Training in communication skills for informal carers of people suffering from dementia: a cluster randomized clinical trial comparing a therapist led workshop and a booklet. International Journal of Geriatric Psychiatry. Aug. 2001;16(8):816-21. Intervention does not address agitation/aggression. [pmid: 11536349].
54 Droes R, Meiland F, Schmitz M, et al. Effect of the meeting centres support program on informal carers of people with dementia: Results from a multi-centre study. Aging & Mental Health. Mar. 2006;10(2):112-24. Not RCT. [pmid: 16517486].
55 Droes R-M, Breebaart E, Ettema TP, et al. Effect of integrated family support versus day care only on behavior and mood of patients with dementia. International Psychogeriatrics. Mar. 2000;12(1):99-115. Not RCT. [pmid: 10798457].
56 Droes R-M, Meiland F, Schmitz M, et al. Effect of combined support for people with dementia and carers versus regular day care on behaviour and mood of persons with dementia: Results from a multi-centre implementation study. International Journal of Geriatric Psychiatry. Jul. 2004;19(7):673-84. Not RCT. [pmid: 15254924].
57 Duarte Vieira VL, Dozzi Brucki SM, Marques Martins ALC, et al. Neuropsychological rehabilitation program and behavioral disturbances in early-stage Alzheimer patients. Dementia & Neuropsychologia. Apr-Jun. 2008;2(2):146-50. Not nonpharm intervention(s).
58 Ducharme F, Lachance L, Levesque L, et al. Maintaining the potential of a psycho-educational program: Efficacy of a booster session after an intervention offered family caregivers at disclosure of a relative's dementia diagnosis. Aging & Mental Health. Mar. 2015;19(3):207-16. Intervention does not address agitation/aggression. [pmid: 24943996].
59 Dunn JC, Thiru-Chelvam B, Beck CH. Bathing. Pleasure or pain?. Journal of Gerontological Nursing. Nov. 2002;28(11):6-13. Not RCT. [pmid: 12465197].
60 Edberg A, Hallberg IR. Actions seen as demanding in patients with severe dementia during one year of intervention. Comparison with controls. International Journal of Nursing Studies. Jun. 2001;38(3):271-85. Not RCT. [pmid: 11245864].
61 Eggermont L, Swaab D, Hol E, et al. Walking the line: A randomised trial on the effects of a short term walking programme on cognition in dementia. Journal of Neurology, Neurosurgery & Psychiatry. Jul. 2009;80(7):802-4. Intervention does not address agitation/aggression.
62 Eichler T, Thyrian JR, Dreier A, et al. Dementia care management: going new ways in ambulant dementia care within a GP-based randomized controlled intervention trial. International Psychogeriatrics. Feb. 2014;26(2):247-56. Not RCT. [pmid: 24152974].
63 Eloniemi-Sulkava U, Saarenheimo M, Laakkonen M-L, et al. Family care as collaboration: Effectiveness of a multicomponent support program for elderly couples with dementia. Randomized controlled intervention study. Journal of the American Geriatrics Society. Dec. 2009;57(12):2200-8. Intervention does not address agitation/aggression. [pmid: 20121986].
64 Ennen J, Mueller B, Bibl M, et al. Impact of multimodal exercise on cognition and daily activity in patients suffering from early Alzheimer's dementia (SPORT&KOG). Zeitschrift fur Gerontopsychologie und -psychiatrie. Sep. 2008;21(3):163-9. Not available in English.
65 Fan JT, Chen KM. Using silver yoga exercises to promote physical and mental health of elders with dementia in long-term care facilities. International Psychogeriatrics. Oct. 2011;23(8):1222-30. Not RCT. [pmid: 21385519].
66 Farina E, Mantovani F, Fioravanti R, et al. Evaluating two group programmes of cognitive training in mild-to-moderate AD: is there any difference between a ‘global’ stimulation and a ‘cognitive-specific’ one?. Aging & Mental Health. May. 2006;10(3):211-8. Not RCT. [pmid: 16777648].
67 Farina E, Mantovani F, Fioravanti R, et al. Efficacy of recreational and occupational activities associated to psychologic support in mild to moderate Alzheimer disease: a multicenter controlled study. Alzheimer Disease & Associated Disorders. Oct-Dec. 2006;20(4):275-82. Not RCT. [pmid: 17132973].
68 Fernandez-Calvo B, Contador I, Ramos F, et al. Effect of unawareness on rehabilitation outcome in a randomised controlled trial of multicomponent intervention for patients with mild Alzheimer's disease. Neuropsychological Rehabilitation. 2015;25(3):448-77. Intervention does not address agitation/aggression. [pmid: 25121567].
69 Fernandez-Calvo B, Contador I, Serna A, et al. The effect of an individual or group intervention format in cognitive stimulation of patients with Alzheimer's disease. Revista de Psicopatologia y Psicologia Clinica. Aug. 2010;15(2):115-23. Not available in English.
70 Fleiner T, Zijlstra W, Dauth H, et al. Evaluation of a hospital-based day-structuring exercise programme on exacerbated behavioural and psychological symptoms in dementia - the exercise carrousel: study protocol for a randomised controlled trial. Trials. [Electronic Resource]. 2015;16:228. Not RCT. [pmid: 26006738].
71 Fossey J, Masson S, Stafford J, et al. The disconnect between evidence and practice: a systematic review of person-centred interventions and training manuals for care home staff working with people with dementia. International Journal of Geriatric Psychiatry. Aug. 2014;29(8):797-807. Not RCT. [pmid: 24535885].
72 Freund-Levi Y, Basun H, Cederholm T, et al. Omega-3 supplementation in mild to moderate Alzheimer's disease: Effects on neuropsychiatric symptoms. International Journal of Geriatric Psychiatry. Feb. 2008;23(2):161-9. Not nonpharm intervention(s). [pmid: 17582225].
73 Frisoni G, Gozzetti A, Bignamini V, et al. Special care units for dementia in nursing homes: A controlled study of affectiveness. Archives of Gerontology and Geriatrics. 1998;6:215-24. Not RCT.
74 Gallagher-Thompson D, Gray HL, Dupart T, et al. Effectiveness of cognitive/behavioral small group intervention for reduction of depression and stress in non-Hispanic White and Hispanic/Latino women dementia family caregivers: Outcomes and mediators of change. Journal of Rational-Emotive & Cognitive-Behavior Therapy. Dec. 2008;26(4):286-303. Intervention does not address agitation/aggression. [pmid: 25067886].
75 Gallagher-Thompson D, Tzuang M, Hinton L, et al. Effectiveness of a fotonovela for reducing depression and stress in Latino dementia family caregivers. Alzheimer Disease & Associated Disorders. Apr-Jun. 2015;29(2):146-53. Intervention does not address agitation/aggression. [pmid: 25590939].
76 Gaugler JE, Jarrott SE, Zarit SH, et al. Adult day service use and reductions in caregivings hours: Effects on stress and psychological well-being for dementia caregivers. International Journal of Geriatric Psychiatry. Jan. 2003;18(1):55-62. Intervention does not address agitation/aggression. [pmid: 12497556].
77 Gauthier S, Loft H, Cummings J. Improvement in behavioural symptoms in patients with moderate to severe Alzheimer's disease by memantine: A pooled data analysis. International Journal of Geriatric Psychiatry. May. 2008;23(5):537-45. Not nonpharm intervention(s). [pmid: 18058838].
78 George DR, Houser WS. “I'm a storyteller!”: Exploring the benefits of TimeSlips creative expression program at a nursing home. American Journal of Alzheimer's Disease and other. Dementias. 20. Dec. 2014;29(8):678-84. Trial does not report behavioral outcomes.
79 Gitlin LN. Use of the Tailored Activities Program to reduce neuropsychiatric behaviors in dementia: an Australian protocol for a randomized trial to evaluate its effectiveness. International psychogeriatrics / IPA. 01. May. 2014;26(5):857-69. Not RCT. [pmid: 24507481].
80 Gitlin LN, Mann WC, Vogel WB, et al. A non-pharmacologic approach to address challenging behaviors of Veterans with dementia: description of the tailored activity program-VA randomized trial. BMC Geriatrics. 2013;13:96. Not RCT. [pmid: 24060106].
81 Gitlin LN, Winter L, Dennis MP, et al. A non-pharmacological intervention to manage behavioral and psychological symptoms of dementia and reduce caregiver distress: design and methods of project ACT3. Clinical Interventions In Aging. 2007;2(4):695-703. Not RCT. [pmid: 18225471].
82 Gitlin LN, Winter L, Vause Earland T, et al. The tailored activity program to reduce behavioral symptoms in individuals with dementia: Feasibility, acceptability, and replication potential. The Gerontologist. Jun. 2009;49(3):428-39. Not RCT. [pmid: 19420314].
83 Gonzalez MT, Kirkevold M. Benefits of sensory garden and horticultural activities in dementia care: a modified scoping review. Journal of Clinical Nursing. Oct. 2014;23(19-20):2698-715. Not RCT. [pmid: 24128125].
84 Grasel E, Wiltfang J, Kornhuber J. Non-drug therapies for dementia: An overview of the current situation with regard to proof of effectiveness. Dementia and Geriatric Cognitive Disorders. 2003;15(3):115-25. Not RCT. [pmid: 12584426].
85 Gray SG, Clair AA. Influence of aromatherapy on medication administration to residential-care residents with dementia and behavioral challenges. American Journal of Alzheimer's Disease & Other Dementias. May-Jun. 2002;17(3):169-74. Not RCT. [pmid: 12083347].
86 Haffmans PM, Sival RC, Lucius SA, et al. Bright light therapy and melatonin in motor restless behaviour in dementia: a placebo-controlled study. International Journal of Geriatric Psychiatry. Jan. 2001;16(1):106-10. Intervention does not address agitation/aggression. [pmid: 11180494].
87 Haight BK, Bachman DL, Hendrix S, et al. Life Review: Treating the Dyadic family Unit with Dementia. Clinical Psychology & Psychotherapy. May-Jun. 2003;10(3):165-74. Not RCT.
88 Halek M, Dichter MN, Quasdorf T, et al. The effects of dementia care mapping on nursing home residents' quality of life and staff attitudes: design of the quasi-experimental study Leben-QD II. BMC Geriatrics. 2013;13:53. Not RCT. [pmid: 23725292].
89 Han P, Kwan M, Chen D, et al. A controlled naturalistic study on a weekly music therapy and activity program on disruptive and depressive behaviors in dementia. Dementia and Geriatric Cognitive Disorders. Jan. 2011;30(6):540-6. Not RCT. [pmid: 21252549].
90 Hart BD, Wells DL. The effects of language used by caregivers on agitation in residents with dementia. Clinical Nurse Specialist. Jan. 1997;11(1):20-3. Intervention does not address agitation/aggression. [pmid: 9233134].
91 Hasselbalch S, Madsen K, Svarer C, et al. Reduced 5-HT2A receptor binding in patients with mild cognitive impairment. Neurobiology of Aging. Dec. 2008;29(12):1830-8. Not nonpharm intervention(s). [pmid: 17544547].
92 Haupt M, Karger A, Janner M. Improvement of agitation and anxiety in demented patients after psychoeducative group intervention with their caregivers. International Journal of Geriatric Psychiatry. Dec. 2000;15(12):1125-9. Not RCT. [pmid: 11180469].
93 Hebert R, Levesque L, Vezina J, et al. Efficacy of a psychoeducative group program for caregivers of demented persons living at home: a randomized controlled trial. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. Jan. 2003;58(1):S58-67. Intervention does not address agitation/aggression. [pmid: 12496309].
94 Hebert R, Levesque L, Vezina J, et al. Efficacy of a Psychoeducative Group Program for Caregivers of Demented Persons Living at Home: A Randomized Controlled Trial. The Journals of Gerontology: Series B: Psychological Sciences and Social Sciences. Jan. 2003;58B(1):S58-S67. Duplicate reference.
95 Herrmann N, Cappell J, Eryavec GM, et al. Changes in nursing burden following memantine for agitation and aggression in long-term care residents with moderate to severe Alzheimer's disease: an open-label pilot study. CNS Drugs. May. 2011;25(5):425-33. Not nonpharm intervention(s). [pmid: 21476613].
96 Hilgeman MM, Allen RS, Snow AL, et al. Preserving Identity and Planning for Advance Care (PIPAC): preliminary outcomes from a patient-centered intervention for individuals with mild dementia. Aging & Mental Health. May. 2014;18(4):411-24. Intervention does not address agitation/aggression. [pmid: 24359036].
97 Ho SY, Lai HL, Jeng SY, et al. The effects of researcher-composed music at mealtime on agitation in nursing home residents with dementia. Archives of Psychiatric Nursing. Dec. 2011;25(6):e49-55. Not RCT. [pmid: 22114806].
98 Hoeffer B, Talerico KA, Rasin J, et al. Assisting cognitively impaired nursing home residents with bathing: effects of two bathing interventions on caregiving. Gerontologist. Aug. 2006;46(4):524-32. Trial does not report behavioral outcomes. [pmid: 16921006].
99 Holland JM, Thompson LW, Cucciare MA, et al. Cortisol outcomes among Caucasian and Latina/Hispanic women caring for a family member with dementia: A preliminary examination of psychosocial predictors and effects of a psychoeducational intervention. Stress and Health: Journal of the International Society for the Investigation of Stress. Oct. 2011;27(4):334-46. Trial does not report behavioral outcomes.
100 Holm A, Michel M, Stern GA, et al. The outcomes of an inpatient treatment program for geriatric patients with dementia and dysfunctional behaviors. Gerontologist. Dec. 1999;39(6):668-76. Not RCT. [pmid: 10650676].
101 Holmes C, Hopkins V, Hensford C, et al. Lavender oil as a treatment for agitated behaviour in severe dementia: a placebo controlled study. International Journal of Geriatric Psychiatry. Apr. 2002;17(4):305-8. Not RCT. [pmid: 11994882].
102 Horr T, Messinger-Rapport B, Pillai JA. Systematic review of strengths and limitations of randomized controlled trials for non-pharmacological interventions in mild cognitive impairment: focus on Alzheimer's disease. Journal of Nutrition, Health & Aging. Feb. 2015;19(2):141-53. Not RCT. [pmid: 25651439].
103 Huang HL, Shyu YIL, Chen MC, et al. A pilot study on a home-based caregiver training program for improving caregiver self-efficacy and decreasing the behavioral problems of elders with dementia in Taiwan. International Journal of Geriatric Psychiatry. Apr. 2003;18(4):337-45. PMID:. WOS:000182353600012. Not RCT. [pmid: 12673611].
104 Huang H-L, Shyu Y-IL, Chen M-C, et al. A pilot study on a home-based caregiver training program for improving caregiver self-efficacy and decreasing the behavioral problems of leaders with dementia in Taiwan. International Journal of Geriatric Psychiatry. Apr. 2003;18(4):337-45. Duplicate reference. [pmid: 12673611].
105 Huey ED, Garcia C, Wassermann EM, et al. Stimulant treatment of frontotemporal dementia in 8 patients. Journal of Clinical Psychiatry. Dec. 2008;69(12):1981-2. Intervention does not address agitation/aggression. [pmid: 19203481].
106 Husebo B, Ballard C, Aarsland D. Pain treatment of agitation in patients with dementia: A systematic review. International Journal of Geriatric Psychiatry. Oct. 2011;26(10):1012-8. Not nonpharm intervention(s). [pmid: 21308784].
107 Husebo B, Ballard C, Fritze F, et al. Efficacy of pain treatment on mood syndrome in patients with dementia: A randomized clinical trial. International Journal of Geriatric Psychiatry. Aug. 2014;29(8):828-36. Not nonpharm intervention(s). [pmid: 24806873].
108 Ismail Z, Emeremni CA, Houck PR, et al. A comparison of the E-BEHAVE-AD, NBRS, and NPI in quantifying clinical improvement in the treatment of agitation and psychosis associated with dementia. American Journal of Geriatric Psychiatry. Jan. 2013;21(1):78-87. Not nonpharm intervention(s). [pmid: 23290205].
109 Ismail Z, Herrmann N, Francis P, et al. A SPECT study of sleep disturbances and Alzheimer's disease. Dementia and Geriatric Cognitive Disorders. Feb. 2009;27(3):254-9. Trial does not report behavioral outcomes. [pmid: 19246910].
110 Jablonski RA, Kolanowski A, Therrien B, et al. Reducing care-resistant behaviors during oral hygiene in persons with dementia. BMC Oral Health. 2011;11:30. Not RCT. [pmid: 22100010].
111 Jimenez-Palomares M, Rodriguez-Mansilla J, Gonzalez-Lopez-Arza MV, et al. Benefits of music therapy as therapy no pharmacology and rehabilitation moderate dementia. Revista Espanola de Geriatria y Gerontologia. Sep-Oct. 2013;48(5):238-42. Not available in English. [pmid: 24053988].
112 Judge KS, Yarry SJ, Orsulic-Jeras S, et al. Acceptability and feasibility results of a strength-based skills training program for dementia caregiving dyads. The Gerontologist. Jun. 2010;50(3):408-17. Trial does not report behavioral outcomes. [pmid: 19808841].
113 Kanamori M, Suzuki M, Yamamoto K, et al. A day care program and evaluation of animal-assisted therapy (AAT) for the elderly with senile dementia. American Journal of Alzheimer's Disease. Jul-Aug. 2001;16(4):234-9. Not RCT.
114 Kanne S, Balota DA, Storandt M, et al. Relating anatomy to function in Alzheimer's disease: Neuropsychological profiles predict regional neuropathology 5 years later. Neurology. Apr. 1998;50(4):979-85. Not RCT. [pmid: 9566382].
115 Kiosses DN, Ravdin LD, Gross JJ, et al. Problem adaptation therapy for older adults with major depression and cognitive impairment: A randomized clinical trial. JAMA Psychiatry. 01. Jan. 2015;72(1):22-30. Intervention does not address agitation/aggression. [pmid: 25372657].
116 Koivisto M, Portin R, Seinela A, et al. Automatic influences of memory in Alzheimer's disease. Cortex: A Journal Devoted to the Study of the Nervous System and Behavior. Apr. 1998;34(2):209-2109. Not RCT. [pmid: 9606586].
117 Kolanowski AM, Fick DM, Clare L, et al. Pilot study of a nonpharmacological intervention for delirium superimposed on dementia. Research in Gerontological Nursing. Jul. 2011;4(3):161-7. Trial does not report behavioral outcomes. [pmid: 21053841].
118 Konno R, Kang HS, Makimoto K. A best-evidence review of intervention studies for minimizing resistance-to-care behaviours for older adults with dementia in nursing homes. Journal of Advanced Nursing. Oct. 2014;70(10):2167-80. Not RCT. [pmid: 24738712].
119 Kovach CR, Schlidt AM. The agitation-activity interface of people with dementia in long-term care. American Journal of Alzheimer's Disease. Jul-Aug. 2001;16(4):240-6. Not RCT.
120 Kuo LM, Huang HL, Hsu WC, et al. Health-related quality of life and self-efficacy of managing behavior problems for family caregivers of vascular dementia and alzheimer's disease patients. Dementia and Geriatric Cognitive Disorders. 16. Apr. 2014;38(5-6):310-20. Intervention does not address agitation/aggression. [pmid: 25011490].
121 Kuo L-M, Huang H-L, Huang H-L, et al. A home-based training program improves Taiwanese family caregivers' quality of life and decreases their risk for depression: A randomized controlled trial. International Journal of Geriatric Psychiatry. May. 2013;28(5):504-13. Intervention does not address agitation/aggression. [pmid: 22778053].
122 Kuzis G, Sabe L, Tiberti C, et al. Neuropsychological correlates of apathy and depression in patients with dementia. Neurology. Apr. 1999;52(7):1403-7. Not RCT. [pmid: 10227625].
123 Kwan RYC, Leung MCP, Lai CKY. Acupressure for agitation in nursing home residents with dementia: Study protocol for a randomized controlled trial. Trials. October. 27. 2014;15(1). Not RCT.
124 Kwok T, Au A, Wong B, et al. Effectiveness of online cognitive behavioral therapy on family caregivers of people with dementia. Clinical Interventions In Aging. 2014;9:631-6. Not RCT. [pmid: 24748781].
125 La Garce M. Daylight interventions and Alzheimer's behaviors: A twelve-month study. Journal of Architectural and Planning Research. Fal. 2004;21(3):257-69. Not RCT.
126 Lam JH. Can leisure activities slow dementia progression in nursing home residents? A cluster-randomized controlled trial. International psychogeriatrics / IPA. 01. Apr. 2014;26(4):637-43. Intervention does not address agitation/aggression. [pmid: 24411480].
127 Lam LC, Lui VW, Luk DN, et al. Effectiveness of an individualized functional training program on affective disturbances and functional skills in mild and moderate dementia-A randomized control trial. International Journal of Geriatric Psychiatry. Feb. 2010;25(2):133-41. Intervention does not address agitation/aggression. [pmid: 19582757].
128 Lamar M, Price CC, Giovannetti T, et al. The dysexecutive syndrome associated with ischaemic vascular disease and related subcortical neuropathology: A Boston Process Approach. Behavioural Neurology. 2009;22(1-2):53-62. Not RCT. [pmid: 20543459].
129 Law LL, Barnett F, Yau MK, et al. Effects of functional tasks exercise on older adults with cognitive impairment at risk of Alzheimer's disease: a randomised controlled trial. Age & Ageing. Nov. 2014;43(6):813-20. Intervention does not address agitation/aggression. [pmid: 24850540].
130 Lawton M, Van Haitsma K, Klapper J, et al. A stimulation-retreat special care unit for elders with dementing illness. International Psychogeriatrics. Dec. 1998;10(4):379-95. Duplicate reference. [pmid: 9924833].
131 Leach MJ, Francis A, Ziaian T. Transcendental Meditation for the improvement of health and wellbeing in community-dwelling dementia caregivers [TRANSCENDENT]: A randomised wait-list controlled trial. BMC Complementary and Alternative Medicine. May. 08. 2015;15(1). Intervention does not address agitation/aggression.
132 LeBars PL, Katz MM, Berman N, et al. A placebo-controlled, double-blind, randomized trial of an extract of Ginkgo biloba for dementia. JAMA: Journal of the American Medical Association. Oct. 1997;278(16):1327-32. Not nonpharm intervention(s). [pmid: 9343463].
133 Leone E, Deudon A, Bauchet M, et al. Management of apathy in nursing homes using a teaching program for care staff: the STIM-EHPAD study. International Journal of Geriatric Psychiatry. Apr. 2013;28(4):383-92. Intervention does not address agitation/aggression. [pmid: 22700526].
134 Li C-H, Liu C-K, Yang Y-H, et al. Adjunct effect of music therapy on cognition in Alzheimer's disease in Taiwan: A pilot study. Neuropsychiatric Disease and Treatment. Feb. 2015;11:291-6. Not RCT. [pmid: 25678794].
135 Libin A, Cohen-Mansfield J. Therapeutic robocat for nursing home residents with dementia: preliminary inquiry. American Journal of Alzheimer's Disease & Other Dementias. Mar-Apr. 2004;19(2):111-6. Not RCT. [pmid: 15106392].
136 Liddle J, Smith-Conway ER, Baker R, et al. Memory and communication support strategies in dementia: effect of a training program for informal caregivers. International Psychogeriatrics. Dec. 2012;24(12):1927-42. Intervention does not address agitation/aggression. [pmid: 23092595].
137 Lieberman MA, Fisher L. The impact of a parent's dementia on adult offspring and their spouses: the contribution of family characteristics. Journal of Mental Health and Aging. Fal. 1999;5(3):207-22. Intervention does not address agitation/aggression.
138 Lin L-C, Yang M-H, Kao C-C, et al. Using acupressure and Montessori-based activities to decrease agitation for residents with dementia: A cross-over trial. Journal of the American Geriatrics Society. Jun. 2009;57(6):1022-9. Duplicate reference. [pmid: 19507295].
139 Lin PW-k, Chan W-c, Ng BF-l, et al. Efficacy of aromatherapy (Lavandula angustifolia) as an intervention for agitated behaviours in Chinese older persons with dementia: A cross-over randomized trial. International Journal of Geriatric Psychiatry. May. 2007;22(5):405-10. Duplicate reference. [pmid: 17342790].
140 Lin Y, Chu H, Yang C-Y, et al. Effectiveness of group music intervention against agitated behavior in elderly persons with dementia. International Journal of Geriatric Psychiatry. Jul. 2011;26(7):670-8. Duplicate reference. [pmid: 20672256].
141 Liu W, Cheon J, Thomas SA. Interventions on mealtime difficulties in older adults with dementia: A systematic review. International Journal of Nursing Studies. Jan. 2014;51(1):14-27. Not RCT. [pmid: 23340328].
142 Livingston G, Barber J, Rapaport P, et al. Long-term clinical and cost-effectiveness of psychological intervention for family carers of people with dementia: A single-blind, randomised, controlled trial. The Lancet Psychiatry. 01. Dec. 2014;1(7):539-48. Intervention does not address agitation/aggression. [pmid: 26361313].
143 Livingston G, Barber J, Rapaport P, et al. START (STrAtegies for RelaTives) study: a pragmatic randomised controlled trial to determine the clinical effectiveness and cost-effectiveness of a manual-based coping strategy programme in promoting the mental health of carers of people with dementia. Health Technology Assessment (Winchester, England). Oct. 2014;18(61):1-242. Intervention does not address agitation/aggression. [pmid: 25300037].
144 Livingston G, Kelly L, Lewis-Holmes E, et al. Non-pharmacological interventions for agitation in dementia: systematic review of randomised controlled trials. British Journal of Psychiatry. Dec. 2014;205(6):436-42. Not RCT. [pmid: 25452601].
145 Logsdon RG, McCurry SM, Teri L. A home health care approach to exercise for persons with Alzheimer's disease. Care Management Journals. 2005;6(2):90-7. Not RCT. [pmid: 16544870].
146 Logsdon RG, McCurry SM, Teri L. Evidence-based psychological treatments for disruptive behaviors in individuals with dementia. Psychology and Aging. Mar. 2007;22(1):28-36. Not RCT. [pmid: 17385980].
147 Logsdon RG, Teri L, Weiner MF, et al. Assessment of agitation in Alzheimer's disease: the agitated behavior in dementia scale. Alzheimer's Disease Cooperative Study. Journal of the American Geriatrics Society. Nov. 1999;47(11):1354-8. Not RCT. [pmid: 10573447].
148 lto T, Meguro K, Akanuma K, et al. A randomized controlled trial of the group reminiscence approach in patients with vascular dementia. Dementia and Geriatric Cognitive Disorders. Jun. 2007;24(1):48-54. Duplicate reference. [pmid: 17565213].
149 Luk KY, Lai KY, Li CC, et al. The effect of horticultural activities on agitation in nursing home residents with dementia. International Journal of Geriatric Psychiatry. Apr. 2011;26(4):435-6. Not RCT. [pmid: 21412848].
150 Lyne KJ, Moxon S, Sinclair I, et al. Analysis of a care planning intervention for reducing depression in older people in residential care. Aging & Mental Health. Jul. 2006;10(4):394-403. PMID:. WOS:000238562200009. Not Dementia. [pmid: 16798632].
151 Mahoney DM, Tarlow B, Jones RN, et al. Factors affecting the use of a telephone-based intervention for caregivers of people with Alzheimer's disease. Journal of Telemedicine & Telecare. 2001;7(3):139-48. Not RCT. [pmid: 11346473].
152 Marques A, Cruz J, Barbosa A, et al. Motor and multisensory care-based approach in dementia: long-term effects of a pilot study. American Journal of Alzheimer's Disease & Other Dementias. Feb. 2013;28(1):24-34. Not RCT. [pmid: 23221028].
153 Martin-Carrasco M, Dominguez-Panchon AI, Gonzalez-Fraile E, et al. Effectiveness of a psychoeducational intervention group program in the reduction of the burden experienced by caregivers of patients with dementia: the EDUCA-II randomized trial. Alzheimer Disease & Associated Disorders. Jan-Mar. 2014;28(1):79-87. Trial does not report behavioral outcomes. [pmid: 24113563].
154 Martindale-Adams J, Nichols LO, Burns R, et al. A trial of dementia caregiver telephone support. Canadian Journal of Nursing Research. Dec. 2013;45(4):30-48. Intervention does not address agitation/aggression. [pmid: 24617278].
155 Masters JL. The benefits of consumer-directed services for caregivers of persons with Alzheimer's disease. Families in Society. Oct-Dec. 2006;87(4):583-9. Intervention does not address agitation/aggression.
156 Matteson MA, Linton AD, Cleary BL, et al. Management of problematic behavioral symptoms associated with dementia: a cognitive developmental approach. Aging-Clinical & Experimental Research. Oct. 1997;9(5):342-55. Not Dementia. [pmid: 9458995].
157 Matthews EA, Farrell GA, Blackmore AM. Effects of an environmental manipulation emphasizing client-centred care on agitation and sleep in dementia sufferers in a nursing home. Journal of Advanced Nursing. Sep. 1996;24(3):439-47. Not RCT. [pmid: 8876402].
158 McCabe M, Davison T, George K. Effectiveness of staff training programs for behavioral problems among older people with dementia. Aging & Mental Health. Sep. 2007;11(5):505-19. Not RCT. [pmid: 17882588].
159 McCabe MP, Mellor D, Davison TE, et al. A study protocol to investigate the management of depression and challenging behaviors associated with dementia in aged care settings. BMC Geriatrics. 2013;13:95. Not RCT. [pmid: 24047236].
160 McCurry SM, Logsdon RG, Vitiello MV, et al. Successful behavioral treatment for reported sleep problems in elderly caregivers of dementia patients: a controlled study. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. Mar. 1998;53(2):P122-9. Intervention does not address agitation/aggression. [pmid: 9520929].
161 McGilton K, Rivera T, Dawson P. Can we help persons with dementia find their way in a new environment?. Aging & Mental Health. Sep. 2003;7(5):363-71. Duplicate reference. [pmid: 12959805].
162 McGinnis KA, Schulz R, Stone RA, et al. Concordance of Race or Ethnicity of Interventionists and Caregivers of Dementia Patients: Relationship to Attrition and Treatment Outcomes in the REACH Study. The Gerontologist. Aug. 2006;46(4):449-55. Intervention does not address agitation/aggression. [pmid: 16920998].
163 McNeil J. Neuropsychological characteristics of the dementia syndrome of depression: Onset, resolution, and three-year follow-up. Clinical Neuropsychologist. May. 1999;13(2):136-46. Not RCT. [pmid: 10949155].
164 Mercado C, Mercado E. A Program Using Environmental Manipulation, Music Therapy Activities, and the Somatron© Vibroacoustic Chair To Reduce Agitation Behaviors of Nursing Home Residents with Psychiatric Disorders. Music Therapy Perspectives. 2006;24(1):30-8. Not RCT.
165 Miller S, Vermeersch PE, Bohan K, et al. Audio presence intervention for decreasing agitation in people with dementia. Geriatric Nursing. Mar-Apr. 2001;22(2):66-70. Not RCT. [pmid: 11326212].
166 Mishima K, Okawa M, Hishikawa Y, et al. Morning bright light therapy for sleep and behavior disorders in elderly patients with dementia. Acta Psychiatrica Scandinavica. Jan. 1994;89(1):1-7. Not Dementia. [pmid: 8140901].
167 Mitchell AM, Chiappetta L, Boucek L, et al. Nonpharmacological therapeutic techniques to decrease agitation in geriatric psychiatric patients with dementia. Journal of Gerontological Nursing. Feb. 2015;41(2):53-9. Not RCT. [pmid: 25347866].
168 Moniz-Cook E, Agar S, Silver M, et al. Can staff training reduce behavioural problems in residential care for the elderly mentally ill?. International Journal of Geriatric Psychiatry. Mar. 1998;13(3):149-58. Not RCT. [pmid: 9565836].
169 Mork Rokstad AM, Rosvik J, Kirkevold O, et al. The effect of person-centred dementia care to prevent agitation and other neuropsychiatric symptoms and enhance quality of life in nursing home patients: A 10-month randomized controlled trial. Dementia and Geriatric Cognitive Disorders. Dec. 2013;36(5-6):340-53. Duplicate reference. [pmid: 24022375].
170 Moser B, Deisenhammer E, Marksteiner J, et al. Serial position effects in patients with mild cognitive impairment and early and moderate Alzheimer's disease compared with healthy comparison subjects. Dementia and Geriatric Cognitive Disorders. Feb. 2014;37(1-2):19-26. Not RCT. [pmid: 24107650].
171 Mossello E, Ridolfi A, Mello AM, et al. Animal-assisted activity and emotional status of patients with Alzheimer's disease in day care. International Psychogeriatrics. Aug. 2011;23(6):899-905. Not RCT. [pmid: 21356158].
172 Mowrey C, Parikh PJ, Bharwani G, et al. Application of behavior-based ergonomics therapies to improve quality of life and reduce medication usage for Alzheimer's/dementia residents. American Journal of Alzheimer's Disease & Other Dementias. Feb. 2013;28(1):35-41. Not RCT. [pmid: 23196404].
173 Moyle W, Cooke ML, Beattie E, et al. Foot massage and physiological stress in people with dementia: a randomized controlled trial. Journal of Alternative & Complementary Medicine. Apr. 2014;20(4):305-11. Intervention does not address agitation/aggression. [pmid: 24047244].
174 Nair B, Heim C, Krishnan C, et al. The effect of Baroque music on behavioural disturbances in patients with dementia. Australasian Journal on Ageing. Mar. 2011;30(1):11-5. Duplicate reference. [pmid: 21395934].
175 Nair BK, Heim C, Krishnan C, et al. The effect of Baroque music on behavioural disturbances in patients with dementia. Australasian Journal on Ageing. Mar. 2011;30(1):11-5. Not RCT. [pmid: 21395934].
176 Namazi KH, Haynes SR. Sensory stimuli reminiscence for patients with Alzheimer's disease: Relevance and implications. Clinical Gerontologist: The Journal of Aging and Mental Health. 1994;14(4):29-46. Not RCT.
177 Neville C, Henwood T, Beattie E, et al. Exploring the effect of aquatic exercise on behaviour and psychological well-being in people with moderate to severe dementia: a pilot study of the Watermemories Swimming Club. Australasian Journal on Ageing. Jun. 2014;33(2):124-7. Not RCT. [pmid: 24521103].
178 Nichols LO, Martindale-Adams J, Burns R, et al. Translation of a dementia caregiver support program in a health care system--REACH VA. Archives of Internal Medicine. Feb. 28. 2011;171(4):353-9. Not RCT. [pmid: 21357811].
179 Niu Y-X, Tan J-P, Guan J-Q, et al. Cognitive stimulation therapy in the treatment of neuropsychiatric symptoms in Alzheimer's disease: A randomized controlled trial. Clinical Rehabilitation. Dec. 2010;24(12):1102-11. Intervention does not address agitation/aggression. [pmid: 20713437].
180 Nocon M, Roll S, Schwarzbach C, et al. Nursing concepts for patients with dementia. A systematic review. Zeitschrift fur Gerontologie und Geriatrie. Jun. 2010;43(3):183-9. Not RCT. [pmid: 20449596].
181 Nolan BA, Mathews RM. Facilitating resident information seeking regarding meals in a special care unit: an environmental design intervention. Journal of Gerontological Nursing. Oct. 2004;30(10):12-6. quiz 55-6. Not RCT. [pmid: 15515440].
182 Nutter-Upham KE, Saykin AJ, Rabin LA, et al. Verbal fluency performance in amnestic MCI and older adults with cognitive complaints. Archives of Clinical Neuropsychology. May. 2008;23(3):229-41. Intervention does not address agitation/aggression. [pmid: 18339515].
183 O'Connor CM, Clemson L, Brodaty H, et al. Use of the Tailored Activities Program to reduce neuropsychiatric behaviors in dementia: an Australian protocol for a randomized trial to evaluate its effectiveness. International Psychogeriatrics. May. 2014;26(5):857-69. Not RCT. [pmid: 24507481].
184 O'Connor DW, Ames D, Gardner B, et al. Psychosocial treatments of behavior symptoms in dementia: A systematic review of reports meeting quality standards. International Psychogeriatrics. Apr. 2009;21(2):225-40. Not RCT. [pmid: 18814806].
185 Oh H, Hur MH, Eom M. Development and analysis of the effects of caregiver training program on aggressive behavior in elders with cognitive impairment. Daehan Ganho Haghoeji. Jun. 2005;35(4):745-53. Not RCT. [pmid: 16037730].
186 Orrell M, Hancock G, Hoe J, et al. A cluster randomised controlled trial to reduce the unmet needs of people with dementia living in residential care. International Journal of Geriatric Psychiatry. Nov. 2007;22(11):1127-34. Intervention does not address agitation/aggression. [pmid: 17394129].
187 O'shea E, Devane D, Murphy K, et al. Effectiveness of a structured education reminiscence-based programme for staff on the quality of life of residents with dementia in long-stay units: a study protocol for a cluster randomised trial. Trials. [Electronic Resource]. 2011;12(1):41. Not RCT. [pmid: 21320303].
188 Pasquier F, Lebert F, Lavenu I, et al. Clinical diagnosis of frontotemporal dementia. Revue Neurologique. Apr. 1998;154(3):217-23. Not RCT. [pmid: 9773045].
189 Passini R, Rainville C, Marchand N, et al. Wayfinding and dementia: Some research findings and a new look at design. Journal of Architectural and Planning Research. Sum. 1998;15(2):133-51. Not RCT.
190 Passini R, Rainville C, Marchand N, et al. Spatio-cognitive operation deficits in dementia of the Alzheimer type. Revue de Neuropsychologie. Sep. 1997;7(3):247-79. Not RCT.
191 Passoni S, Moroni L, Toraldo A, et al. Cognitive behavioral group intervention for Alzheimer caregivers. Alzheimer Disease & Associated Disorders. Jul-Sep. 2014;28(3):275-82. Intervention does not address agitation/aggression. [pmid: 24614271].
192 Perilli V, Lancioni GE, Hoogeveen F, et al. Video prompting versus other instruction strategies for persons with Alzheimer's disease. American Journal of Alzheimer's Disease & Other Dementias. Jun. 2013;28(4):393-402. Trial does not report behavioral outcomes. [pmid: 23687181].
193 Pettersen JA, Sathiyamoorthy G, Gao F-Q, et al. Microbleed topography, leukoaraiosis, and cognition in probable Alzheimer disease from the Sunnybrook Dementia Study. Archives of Neurology. Jun. 2008;65(6):790-5. Not RCT. [pmid: 18541799].
194 Pezzati R, Molteni V, Bani M, et al. Can Doll therapy preserve or promote attachment in people with cognitive, behavioral, and emotional problems? A pilot study in institutionalized patients with dementia. Frontiers in Psychology. Apr. 2014;5:342. Not RCT. [pmid: 24795682].
195 Pieper MJ, Achterberg WP, Francke AL, et al. The implementation of the serial trial intervention for pain and challenging behaviour in advanced dementia patients (STA OP!): a clustered randomized controlled trial. BMC Geriatrics. 2011;11:12. Not RCT. [pmid: 21435251].
196 Prick AE, de Lange J, van 't Leven N, et al. Process evaluation of a multicomponent dyadic intervention study with exercise and support for people with dementia and their family caregivers. Trials. [Electronic Resource]. 2014;15:401. Intervention does not address agitation/aggression. [pmid: 25336121].
197 Quinn C, Anderson D, Toms G, et al. Self-management in early-stage dementia: a pilot randomised controlled trial of the efficacy and cost-effectiveness of a self-management group intervention (the SMART study). Trials. [Electronic Resource]. 2014;15:74. Not RCT. [pmid: 24606601].
198 Raggi A, Iannaccone S, Marcone A, et al. The effects of a comprehensive rehabilitation program of Alzheimer's Disease in a hospital setting. Behavioural Neurology. 2007;18(1):1-6. Not RCT. [pmid: 17297213].
199 Raglio A, Bellandi D, Baiardi P, et al. Listening to music and active music therapy in behavioral disturbances in dementia: a crossover study. Journal of the American Geriatrics Society. Apr. 2013;61(4):645-7. Not RCT. [pmid: 23581919].
200 Raglio A, Bellelli G, Traficante D, et al. Efficacy of music therapy treatment based on cycles of sessions: A randomised controlled trial. Aging & Mental Health. Nov. 2010;14(8):900-4. Duplicate reference. [pmid: 21069596].
201 Raglio A, Bellelli G, Traficante D, et al. Efficacy of music therapy in the treatment of behavioral and psychiatric symptoms of dementia. Alzheimer Disease & Associated Disorders. Apr-Jun. 2008;22(2):158-62. Not RCT. [pmid: 18525288].
202 Ragneskog H, Asplund K, Kihlgren M, et al. Individualized music played for agitated patients with dementia: analysis of video-recorded sessions. International Journal of Nursing Practice. Jun. 2001;7(3):146-55. Not RCT. [pmid: 11811810].
203 Ragneskog H, Gerdner LA, Josefsson K, et al. Probable reasons for expressed agitation in persons with dementia. Clinical Nursing Research. May. 1998;7(2):189-206. Not RCT. [pmid: 9633339].
204 Ragneskog H, Kihlgren M, Karlsson I, et al. Dinner music for demented patients: analysis of video-recorded observations. Clinical Nursing Research. Aug. 1996;5(3):262-77. discussion 78-82. Not RCT. [pmid: 8850771].
205 Rapoport M, Wolf U, Herrmann N, et al. Traumatic brain injury, apolipoprotein E-epsilon4, and cognition in older adults: A two-year longitudinal study. The Journal of Neuropsychiatry and Clinical Neurosciences. Win. 2008;20(1):68-73. Not Dementia. [pmid: 18305286].
206 Rapp MA, Decker A, Klein U, et al. Behavioral symptoms of dementia in nursing home residents: Evaluation of a combined nursing and physician guideline implementation (VIDEANT). Zeitschrift fur Gerontopsychologie und -psychiatrie. Sep. 2008;21(3):205-14. Duplicate reference.
207 Remington R, Bechtel C, Larsen D, et al. A Phase II Randomized Clinical Trial of a Nutritional Formulation for Cognition and Mood in Alzheimer's Disease. Journal of Alzheimer's Disease. 2015;45(2):395-405. Not nonpharm intervention(s). [pmid: 25589719].
208 Reuther S, Holle D, Buscher I, et al. Effect evaluation of two types of dementia-specific case conferences in German nursing homes (FallDem) using a stepped-wedge design: study protocol for a randomized controlled trial. Trials. [Electronic Resource]. 2014;15:319. Not RCT. [pmid: 25118091].
209 Robinson KM, Yates K. Effects of two caregiver-training programs on burden and attitude toward help. Archives of Psychiatric Nursing. Oct. 1994;8(5):312-9. Trial does not report behavioral outcomes. [pmid: 7993133].
210 Rodriguez-Sanchez E, Criado-Gutierrez JM, Mora-Simon S, et al. Physical activity program for patients with dementia and their relative caregivers: Randomized clinical trial in Primary Health Care (AFISDEMyF study). BMC Neurology. Apr. 2014;14:63. Not RCT. [pmid: 24684948].
211 Rogers JC, Holm MB, Burgio LD, et al. Improving morning care routines of nursing home residents with dementia. Journal of the American Geriatrics Society. Sep. 1999;47(9):1049-57. Not RCT. [pmid: 10484245].
212 Rovner BW, Steele CD, Shmuely Y, et al. A randomized trial of dementia care in nursing homes. Journal of the American Geriatrics Society. Jan. 1996;44(1):7-13. Intervention does not address agitation/aggression. [pmid: 8537594].
213 Rusted J, Sheppard L, Waller D. A Multi-centre Randomized Control Group Trial on the Use of Art Therapy for Older People with Dementia. Group Analysis. Dec. 2006;39(4):517-36. Intervention does not address agitation/aggression.
214 Salzman C, Jeste DV, Meyer RE, et al. Elderly patients with dementia-related symptoms of severe agitation and aggression: Consensus statement on treatment options, clinical trials methodology, and policy. Journal of Clinical Psychiatry. Jun. 2008;69(6):889-98. Not RCT. [pmid: 18494535].
215 Samus QM, Johnston D, Black BS, et al. A multidimensional home-based care coordination intervention for elders with memory disorders: The Maximizing Independence at Home (MIND) pilot randomized trial. The American Journal of Geriatric Psychiatry. Apr. 2014;22(4):398-414. Intervention does not address agitation/aggression. [pmid: 24502822].
216 Sandvik RK, Selbaek G, Seifert R, et al. Impact of a stepwise protocol for treating pain on pain intensity in nursing home patients with dementia: a cluster randomized trial. European Journal of Pain. Nov. 2014;18(10):1490-500. Not nonpharm intervention(s). [pmid: 24819710].
217 Sarkamo T, Tervaniemi M, Laitinen S, et al. Cognitive, emotional, and social benefits of regular musical activities in early dementia: randomized controlled study. Gerontologist. Aug. 2014;54(4):634-50. Intervention does not address agitation/aggression. [pmid: 24009169].
218 Schacke C. The benefits of adult day care use for family caregivers assisting a relative with dementia: An evaluation. Verhaltenstherapie & Verhaltensmedizin. 2002;23(2):227-43. Not available in English.
219 Scherder EJ, Bouma A, Steen LM. Effects of “isolated” transcutaneous electrical nerve stimulation on memory and affective behavior in patients with probable Alzheimer's disease. Biological Psychiatry. Mar. 15. 1998;43(6):417-24. Intervention does not address agitation/aggression. [pmid: 9532346].
220 Schreiber M, Schweizer A, Lutz K, et al. Potential of an interactive computer-based training in the rehabilitation of dementia: An initial study. Neuropsychological Rehabilitation. Apr. 1999;9(2):155-67. Not RCT.
221 Schrijnemaekers V, van Rossum E, Candel M, et al. Effects of emotion-oriented care on elderly people with cognitive impairment and behavioural problems. International Journal of Geriatric Psychiatry. Oct. 2002;17(10):926-37. Duplicate reference. [pmid: 12325052].
222 Schwarz B, Chaudhury H, Tofle RB. Effect of design interventions on a dementia care setting. American Journal of Alzheimer's Disease & Other Dementias. May-Jun. 2004;19(3):172-6. Not RCT. [pmid: 15214204].
223 Senanarong V, Jamjumras P, Harmphadungkit K, et al. A counseling intervention for caregivers: Effect on neuropsychiatric symptoms. International Journal of Geriatric Psychiatry. Aug. 2004;19(8):781-8. Not RCT. [pmid: 15290702].
224 Shinagawa S, Nakajima S, Plitman E, et al. Non-pharmacological management for patients with frontotemporal dementia: a systematic review. Journal of Alzheimer's Disease. 2015;45(1):283-93. Not RCT. [pmid: 25737152].
225 Skjerve A, Holsten F, Aarsland D, et al. Improvement in behavioral symptoms and advance of activity acrophase after short-term bright light treatment in severe dementia. Psychiatry & Clinical Neurosciences. Aug. 2004;58(4):343-7. Not RCT. [pmid: 15298644].
226 Sloane PD, Hoeffer B, Mitchell C, et al. Effect of Person-Centered Showering and the Towel Bath on Bathing-Associated Aggression, Agitation, and Discomfort in Nursing Home Residents with Dementia: A Randomized, Controlled Trial. Journal of the American Geriatrics Society. Nov. 2004;52(11):1795-804. Duplicate reference. [pmid: 15507054].
227 Snow LA, Hovanec L, Brandt J. A controlled trial of aromatherapy for agitation in nursing home patients with dementia. Journal of Alternative & Complementary Medicine. Jun. 2004;10(3):431-7. Not RCT. [pmid: 15253846].
228 Snyder M, Egan EC, Burns KR. Interventions for decreasing agitation behaviors in persons with dementia. Journal of Gerontological Nursing. Jul. 1995;21(7):34-40. Not RCT. [pmid: 7615916].
229 Snyder M, Tseng Y, Brandt C, et al. A glider swing intervention for people with dementia. Geriatric Nursing. Mar-Apr. 2001;22(2):86-90. Not RCT. [pmid: 11326215].
230 Soril LJ, Leggett LE, Lorenzetti DL, et al. Effective use of the built environment to manage behavioural and psychological symptoms of dementia: a systematic review. PLoS ONE. [Electronic Resource]. 2014;9(12):e115425. Not RCT. [pmid: 25517508].
231 Spector A, Charlesworth G, King M, et al. Cognitive-behavioural therapy for anxiety in dementia: pilot randomised controlled trial. British Journal of Psychiatry. Jun. 2015;206(6):509-16. Intervention does not address agitation/aggression. [pmid: 25698766].
232 Spector A, Orrell M, Lattimer M, et al. Cognitive behavioural therapy (CBT) for anxiety in people with dementia: study protocol for a randomised controlled trial. Trials. [Electronic Resource]. 2012;13:197. Not RCT. [pmid: 23092336].
233 Spijker A, Wollersheim H, Teerenstra S, et al. Systematic care for caregivers of patients with dementia: a multicenter, cluster-randomized, controlled trial. American Journal of Geriatric Psychiatry. Jun. 2011;19(6):521-31. Intervention does not address agitation/aggression. [pmid: 21358385].
234 Spira AP, Edelstein BA. Behavioral interventions for agitation in older adults with dementia: An evaluative review. International Psychogeriatrics. Jun. 2006;18(2):195-225. Not RCT. [pmid: 16472409].
235 Steffen AM. Anger management for dementia caregivers: A preliminary study using video and telephone interventions. Behavior Therapy. Spr. 2000;31(2):281-99. Intervention does not address agitation/aggression.
236 Stella F, Canonici AP, Gobbi S, et al. Attenuation of neuropsychiatric symptoms and caregiver burden in Alzheimer's disease by motor intervention: a controlled trial. Clinics (Sao Paulo, Brazil). 2011;66(8):1353-60. Not RCT. [pmid: 21915483].
237 Suemoto CK, Apolinario D, Nakamura-Palacios EM, et al. Effects of a non-focal plasticity protocol on apathy in moderate Alzheimer's disease: a randomized, double-blind, sham-controlled trial. Brain Stimulation. Mar-Apr. 2014;7(2):308-13. Intervention does not address agitation/aggression. [pmid: 24262299].
238 Sung H-c, Lee W-l, Li T-l, et al. A group music intervention using percussion instruments with familiar music to reduce anxiety and agitation of institutionalized older adults with dementia. International Journal of Geriatric Psychiatry. Jun. 2012;27(6):621-7. Duplicate reference. [pmid: 21823174].
239 Suzuki M, Kanamori M, Nagasawa S, et al. Music therapy-induced changes in behavioral evaluations, and saliva chromogranin A and immunoglobulin A concentrations in elderly patients with senile dementia. Geriatrics & Gerontology International. Mar. 2007;7(1):61-71. Not RCT.
240 Suzuki M, Kanamori M, Watanabe M, et al. Behavioral and endocrinological evaluation of music therapy for elderly patients with dementia. Nursing & Health Sciences. Mar. 2004;6(1):11-8. Not RCT. [pmid: 14764189].
241 Suzuki M, Tatsumi A, Otsuka T, et al. Physical and psychological effects of 6-week tactile massage on elderly patients with severe dementia. American Journal of Alzheimer's Disease & Other Dementias. Dec. 2010;25(8):680-6. Not RCT. [pmid: 21131675].
242 Tanner JA, Black BS, Johnston D, et al. A randomized controlled trial of a community-based dementia care coordination intervention: Effects of MIND at home on caregiver outcomes. The American Journal of Geriatric Psychiatry. Apr. 2015;23(4):391-402. Intervention does not address agitation/aggression. [pmid: 25260557].
243 Teri L. Results from the multisite implementation of STAR-VA: a multicomponent psychosocial intervention for managing challenging dementia-related behaviors of veterans. Psychological services. 01. May. 2014;11(2):200-8. Not RCT. [pmid: 23937081].
244 Teri L, Gibbons LE, McCurry SM, et al. Exercise plus behavioral management in patients with Alzheimer disease: a randomized controlled trial. JAMA. Oct. 15. 2003;290(15):2015-22. Intervention does not address agitation/aggression. [pmid: 14559955].
245 Teri L, McCurry SM, Logsdon R, et al. Training community consultants to help family members improve dementia care: A randomized controlled trial. Gerontologist. Dec. 2005;45(6):802-11. PMID:. WOS:000233699500010. Trial does not report behavioral outcomes. [pmid: 16326662].
246 Testad I, Aasland A, Aarsland D. The effect of staff training on the use of restraint in dementia: A single-blind randomised controlled trial. International Journal of Geriatric Psychiatry. Jun. 2005;20(6):587-90. Duplicate reference. [pmid: 15920716].
247 Testad I, Corbett A, Aarsland D, et al. The value of personalized psychosocial interventions to address behavioral and psychological symptoms in people with dementia living in care home settings: A systematic review. International Psychogeriatrics. Jul. 2014;26(7):1083-98. Not RCT. [pmid: 24565226].
248 Testad I, Corbett A, Aarsland D, et al. The value of personalized psychosocial interventions to address behavioral and psychological symptoms in people with dementia living in care home settings: a systematic review. [Erratum appears in Int Psychogeriatr. 2014 Jul;26(7):1099]. International Psychogeriatrics. Jul. 2014;26(7):1083-98. Not RCT. [pmid: 24565226].
249 Testad I, Mikkelsen A, Ballard C, et al. Health and well-being in care staff and their relations to organizational and psychosocial factors, care staff and resident factors in nursing homes. International Journal of Geriatric Psychiatry. Aug. 2010;25(8):789-97. PMID:. WOS:000280538300004. Not RCT. [pmid: 19862696].
250 Thompson Coon J, Abbott R, Rogers M, et al. Interventions to reduce inappropriate prescribing of antipsychotic medications in people with dementia resident in care homes: a systematic review. Journal of the American Medical Directors Association. Oct. 2014;15(10):706-18. Not RCT. [pmid: 25112229].
251 Thyrian JR, Fis T, Dreier A, et al. Life- and person-centred help in Mecklenburg-Western Pomerania, Germany (DelpHi): study protocol for a randomised controlled trial. Trials. [Electronic Resource]. 2012;13:56. Not RCT. [pmid: 22575023].
252 Toba K, Nakamura Y, Endo H, et al. Intensive rehabilitation for dementia improved cognitive function and reduced behavioral disturbance in geriatric health service facilities in Japan. Geriatrics & Gerontology International. Jan. 2014;14(1):206-11. Not RCT. [pmid: 23647510].
253 Tremont G, Davis JD, Bishop DS, et al. Telephone-delivered psychosocial intervention reduces burden in dementia caregivers. Dementia: The International Journal of Social Research and Practice. Nov. 2008;7(4):503-20. Trial does not report behavioral outcomes.
254 Tremont G, Davis JD, Papandonatos GD, et al. Psychosocial telephone intervention for dementia caregivers: A randomized, controlled trial. Alzheimer's & Dementia. May. 2015;11(5):541-8. Intervention does not address agitation/aggression. [pmid: 25074341].
255 Treusch Y, Majic T, Page J, et al. Apathy in nursing home residents with dementia: results from a cluster-randomized controlled trial. European Psychiatry: the Journal of the Association of European Psychiatrists. Feb. 2015;30(2):251-7. Intervention does not address agitation/aggression. [pmid: 24630745].
256 Tuet R, Lam L. A preliminary study of the effects of music therapy on agitation in Chinese patients with dementia. Hong Kong Journal of Psychiatry. Sep. 2006;16(3):87-91. Not RCT.
257 Turner S. Behavioural symptoms of dementia in residential settings: A selective review of non-pharmacological interventions. Aging & Mental Health. Mar. 2005;9(2):93-104. Not RCT. [pmid: 15804626].
258 Ulstein ID, Sandvik L, Wyller TB, et al. A one-year randomized controlled psychosocial intervention study among family carers of dementia patients-effects on patients and carers. Dementia and Geriatric Cognitive Disorders. Nov. 2007;24(6):469-75. Duplicate reference. [pmid: 17986818].
259 Van Bogaert P, Van Grinsven R, Tolson D, et al. Effects of SolCos model-based individual reminiscence on older adults with mild to moderate dementia due to Alzheimer disease: a pilot study. Journal of the American Medical Directors Association. Jul. 2013;14(7):528.e9-13. Not RCT. [pmid: 23583001].
260 van der Ploeg ES, Camp CJ, Eppingstall B, et al. The study protocol of a cluster-randomised controlled trial of family-mediated personalised activities for nursing home residents with dementia. BMC Geriatrics. 2012;12:2. Not RCT. [pmid: 22236064].
261 van der Ploeg ES, O'Connor DW. Evaluation of personalised, one-to-one interaction using Montessori-type activities as a treatment of challenging behaviours in people with dementia: the study protocol of a crossover trial. BMC Geriatrics. 2010;10:3. Not RCT. [pmid: 20096137].
262 van der Roest HG, Meiland FJ, Jonker C, et al. User evaluation of the DEMentia-specific Digital Interactive Socal Chart (DEM-DISC). A Pilot study among informal carers on its impact, user friendliness and, usefulness. Aging & Mental Health. May. 2010;14(4):461-70. Not RCT. [pmid: 20455122].
263 van Dijk A, van Weert J, Droes R. Theatre as communication method in psychogeriatric care: Effects on behaviour, mood and quality of life of people with dementia. Tijdschrift voor Gerontologie en Geriatrie. Dec. 2012;43(6):283-95. Not available in English. [pmid: 23371871].
264 van Dijk AM, van Weert JC, Droes RM. Does theatre improve the quality of life of people with dementia?. International Psychogeriatrics. Mar. 2012;24(3):367-81. Not RCT. [pmid: 22040605].
265 van Weert JC, van Dulmen AM, Spreeuwenberg PM, et al. Behavioral and mood effects of snoezelen integrated into 24-hour dementia care. Journal of the American Geriatrics Society. Jan. 2005;53(1):24-33. Not RCT. [pmid: 15667372].
266 Venturelli M, Magalini A, Scarsini R, et al. From Alzheimer's disease retrogenesis: a new care strategy for patients with advanced dementia. American Journal of Alzheimer's Disease & Other Dementias. Nov. 2012;27(7):483-9. Not RCT. [pmid: 22984089].
267 Villar F, Vila-Miravent J, Celdran M, et al. The participation of patients with dementia in Individualised Intervention Plan meetings: The impact on their well-being and the quality of life. Revista Espanola de Geriatria y Gerontologia. Nov-Dec. 2013;48(6):259-64. Not available in English. [pmid: 23725734].
268 Visser S, McCabe M, Hudgson C, et al. Managing behavioural symptoms of dementia: Effectiveness of staff education and peer support. Aging & Mental Health. Jan. 2008;12(1):47-55. Duplicate reference. [pmid: 18297478].
269 Wang JJ, Yen M, OuYang WC. Group reminiscence intervention in Taiwanese elders with dementia. Archives of Gerontology & Geriatrics. Sep-Oct. 2009;49(2):227-32. Not RCT. [pmid: 18930560].
270 Wang J-J, Yen M, OuYang WC. Group reminiscence intervention in Taiwanese elders with dementia. Archives of Gerontology and Geriatrics. Sep-Oct. 2009;49(2):227-32. Duplicate reference. [pmid: 18930560].
271 Wang KL, Hermann C. Pilot study to test the effectiveness of Healing Touch on agitation in people with dementia. Geriatric Nursing. Jan-Feb. 2006;27(1):34-40. Not RCT. [pmid: 16483898].
272 Ward-Smith P, Llanque SM, Curran D. The effect of multisensory stimulation on persons residing in an extended care facility. American Journal of Alzheimer's Disease & Other Dementias. 2009 Dec-2010 Jan. 24(6):450-5. Not RCT. [pmid: 19846683].
273 Williams K, Arthur A, Niedens M, et al. In-home monitoring support for dementia caregivers: A feasibility study. Clinical Nursing Research. May. 2013;22(2):139-50. Not RCT. [pmid: 22997349].
274 Williams VP, Bishop-Fitzpatrick L, Lane JD, et al. Video-based coping skills to reduce health risk and improve psychological and physical well-being in Alzheimer's disease family caregivers. Psychosomatic Medicine. Nov-Dec. 2010;72(9):897-904. Intervention does not address agitation/aggression. [pmid: 20978227].
275 Wilz G, Kalytta T. Evaluation of a cognitive-behavioral group intervention for family caregivers of persons with dementia. PPmP: Psychotherapie Psychosomatik Medizinische Psychologie. Sep. 2012;62(9-10):359-66. Not available in English.
276 Wolfs CA, Kessels A, Dirksen CD, et al. Integrated multidisciplinary diagnostic approach for dementia care: Randomised controlled trial. The British Journal of Psychiatry. Apr. 2008;192(4):300-5. Intervention does not address agitation/aggression. [pmid: 18378994].
277 Woods DL, Dimond M. The effect of therapeutic touch on agitated behavior and cortisol in persons with Alzheimer's disease. Biological Research for Nursing. Oct. 2002;4(2):104-14. Not RCT. [pmid: 12408216].
278 Wouters H, Quik EH, Boersma F, et al. Discontinuing inappropriate medication in nursing home residents (DIM-NHR Study): protocol of a cluster randomised controlled trial. BMJ Open. 2014;4(10):e006082. Not RCT. [pmid: 25296655].
279 Wu HS, Lin LC. Comparing cognition, mealtime performance, and nutritional status in people with dementia with or without ideational apraxia. Biological Research for Nursing. Mar. 2015;17(2):199-206. Not RCT. [pmid: 24924352].
280 Yang MH, Wu SC, Lin JG, et al. The efficacy of acupressure for decreasing agitated behaviour in dementia: a pilot study. Journal of Clinical Nursing. Feb. 2007;16(2):308-15. Not RCT. [pmid: 17239066].
281 Yu F, Thomas W, Nelson NW, et al. Impact of 6-month aerobic exercise on Alzheimer's symptoms. Journal of Applied Gerontology. Jun. 2015;34(4):484-500. Not RCT. [pmid: 24652914].
282 Zanetti O, Frisoni GB, De Leo D, et al. Reality orientation therapy in Alzheimer disease: Useful or not? A controlled study. Alzheimer Disease and Associated Disorders. 1995;9(3):132-8. Trial does not report behavioral outcomes. [pmid: 8534411].
283 Zare M, Ebrahimi AA, Birashk B. The effect of music therapy on reducing agitation in patients with Alzheimer's disease in Shahryar city nursing home. Advances in Cognitive Science. 2009;11(2; 42):55-62. Not available in English.
284 Zhu XC, Yu Y, Wang HF, et al. Physiotherapy intervention in Alzheimer's disease: systematic review and meta-analysis. Journal of Alzheimer's Disease. 2015;44(1):163-74. Not RCT. [pmid: 25201787].