# Search Strategy

Database: Ovid MEDLINE(R) <1946 to November Week 1 2014>

Search Strategy:

--------------------------------------------------------------------------------

1. exp *Dementia/
2. dementi*.ti.
3. alzheimer*.ti.
4. 1 or 2 or 3
5. neuropsych*.mp.
6. behav*.mp.
7. agitat*.mp.
8. aggress*.mp.
9. exp Behavioral Symptoms/
10. exp Psychomotor Agitation/
11. 5 or 6 or 7 or 8 or 9 or 10
12. 4 and 11
13. limit 12 to “therapy (maximizes sensitivity)”
14. limit 13 to (clinical trial, phase i or clinical trial, phase ii or clinical trial, phase iii or clinical trial phase iv or clinical trial or controlled clinical trial or randomized controlled trial)
15. limit 14 to yr=“1994-Current”

***************************

Embase Search Strategy:

--------------------------------------------------------------------------------

1. dementia/
2. Alzheimer*.ti.
3. dementia.ti.
4. 1 or 2 or 3
5. agitation/
6. neuropsych*.mp.
7. agitat*.mp.
8. behav*.mp.
9. exp behavior/
10. aggres*.mp.
11. 5 or 6 or 7 or 8 or 9 or 10
12. 4 and 11
13. limit 12 to “therapy (maximizes sensitivity)”
14. limit 13 to (article or journal)
15. limit 14 to (randomized controlled trial or multicenter study)
16. limit 15 to yr=“1994-Current”