# Abbreviations

ABID: Agitated Behavior in Dementia Scale
ABRS: Agitated Behavior Rating Scale
ACT: Advancing Caregiver Training
ADCS-CGIC: Alzheimer's Disease Cooperative Study-Clinical Global Impression of Change
AHRQ: Agency for Healthcare Research and Quality
AICT: Advance Illness Care Teams
ARD: Absolute risk difference
BEHAVE-AD: Behavioral Pathology in Alzheimer's disease
BLT: Bright light therapy
BMD: Behaviour and Mood Disturbance
BPSD: Behavioral and Social Symptoms of Dementia
BRS: Behavioral Rating Scale
BRSD: Behavior Rating Scale for Dementia
CENTRAL: Cochrane-Central Register of Controlled Trials
CFI: Camberwell Family Interview
CI: Confidence interval
CMAI: Cohen-Mansfield Agitation Inventory
COPE: Care of Persons with Dementia in their Environments
DBRS: Disruptive Behavior Rating Scales
DCM: Dementia care mapping
DSM-5: Diagnostic and Statistical Manual of Mental Disorders, Fifth Edition
ESP: Environmental Skill-Building Program
MID: Minimal important difference
MOSES: Multi-dimensional Observation Scale for Elderly Patients
NCD: Neurocognitive disorders
NPI: Neuropsychiatric Inventory
NPI-C: Neuropsychiatric Inventory Clinician
PAS: Pittsburgh Agitation Scale
PCC: Person-centered care
PICOTS: Population, Interventions, Comparators, Outcomes, Timing, Setting
QoL: Quality of life
RCT: Randomized controlled trial
REACH: Resources for Enhancing Alzheimer's Caregiver Health
REHAB: Rehabilitation Evaluation Hall and Baker
RMBPC: Revised Memory and Behavior Problem Checklist
RR: Risk ratio
RSS: Relative Stress Scale
SCB: Screen for Caregiver Burden
SMD: Standardized mean difference
TAP: Tailored Activity Program
TREA: Treatment Route for Exploring Agitation
WMD: Weighted mean difference
ZBI: Zarit Burden Index