# Results

## Introduction

This chapter first describes the results of the literature searches and then provides the results for each KQ, including key points, an overview of the studies identified for that question, and a detailed synthesis of the studies.

## Results of Literature Searches

Our searches identified 6,269 titles/abstracts. Reference mining the previous systematic reviews (SRs) and guidelines identified in our searches resulted in an additional 233 titles. Our search of clinicaltrials.gov identified 270 entries for gout. Of these, 19 were potentially relevant, 10 were either included already in our report or identified in our searches and excluded as ineligible, 1 was withdrawn, and 8 were recorded as being completed but no results were posted in clinicaltrials.gov, and we could find no published journal articles. Two manufacturers of drugs (Novartis and Regeneron) responded to requests by the AHRQ Scientific Resource Center for Scientific Information Packets on gout treatments. None of the trials described in these information packets was included in this report, as the drugs are currently not FDA approved. Of a total of 6,772 titles/abstracts screened for inclusion. 6,087 titles/abstracts were excluded for the following reasons: not human (295), not gout or hyperuricemia associated with gout (1,630), not gout diagnosis or management or did not address a KQ (2,716), study of risk factor(s) for gout that doesn't test possible treatment (89), no original data or non-systematic reviews (508), case reports (287), population not of interest (75), titles with no abstracts (full-text articles or reports were obtained for a random sample of 10 percent of these titles and all were rejected as letters, commentaries, or non-systematic reviews with no original data, so on this basis, we decided not to consider the remainder) (199), gout diagnosis only (104),biologics not within scope of review (133), or duplicate data (51) (see Figure 2). We further reviewed 685 full text articles, of which 542 were excluded for the following reasons: not human (2), not gout or hyperuricemia associated with gout (26), not gout diagnosis or management or did not address a KQ (154), study of risk factor(s) for gout that doesn't test possible treatment (18), no original data or non-systematic reviews (97), study design (66), case reports (51), population not of interest (8), gout diagnosis only (6), biologics not within scope of review (64), no outcomes of interest (11), no interventions of interest (2), duplicate data (33), or article not found (4).

Figure 2 Literature flow diagram

AE(s) = adverse event(s); KQ = Key Question; MA = meta-analysis; RCT(s) = randomized controlled trial(s); SR(s) = systematic review(s)

This figure is the flow chart that summarizes the study retrieval and selection process for articles. The information displayed in the figure is described in the section entitled Results of Literature Searches.

We considered 143 articles for data synthesis, which included 115 studies and 28 SRs.

For KQ 1, we identified 45 studies. Thirty studies were included in prior SRs. We included 10 systematic reviews (SRs), 3 randomized controlled trials (RCTs) not included in prior SRs, and 2 studies that reported only on adverse events (AEs).

For KQ2, we identified 22 studies. Six studies were included in prior SRs. We include 5 SRs; 6 RCTs not included in prior SRs that examined dietary, lifestyle, and Traditional Chinese Medicine (TCM) treatments; and 3 observational studies (reported in six publications) on dietary risk factors.

For KQ3, we identified 55 studies. Ten studies were identified in previous SRs. We include 11 SRs and one meta-analysis, 7 RCTs not included in prior SRs and 1 abstract that has not been published, 5 new analyses of studies included in existing SRs, and 20 studies on AEs.

For KQ4, we include 2 SRs and 24 original studies. For KQ5, we include 3 original studies.

Figure 2 presents the literature flow diagram. Appendix B includes the reasons for exclusion of studies at the data abstraction phase.

## Key Questions 1a–c Acute Gout Treatment

a. In patients with acute gout, what are the benefits and harms of different pharmacological therapies?
b. Does effectiveness (benefits and harms) differ according to patient baseline demographic characteristics and co-morbid conditions (including renal function)?
c. Does effectiveness (benefits and harms) differ according to disease severity, including initial clinical presentation (e.g., extent of joint involvement and time since start of flare) and laboratory values (serum and/or urine UA levels)?

### Key Points

- High-strength evidence supports the efficacy of colchicine to reduce pain in acute gout.
- Moderate-strength evidence supports the finding that low-dose colchicine is as effective as higher dose for reducing pain, with fewer side effects.
- High-strength evidence supports the efficacy of NSAIDs to reduce pain in acute gout.
- Moderate-strength evidence supports a lack of difference among NSAIDs in effectiveness.
- High-strength evidence supports the efficacy of systemic corticosteroids to reduce pain in acute gout.
- Moderate-strength evidence supports animal-derived ACTH formulation to reduce pain in acute gout.
- SoE is insufficient regarding the effect of therapies on other outcomes: joint swelling, tenderness, activities of daily living, patient global assessment.
- SoE is insufficient regarding differences in efficacy stratified by patient demographic, comorbid conditions, disease severity, clinical presentation, or lab values.
- The most common adverse effects associated with colchicine are gastrointestinal symptoms, reported in 23 to 77 percent of users. NSAIDs also have gastrointestinal side effects, with dyspepsia or abdominal pain occurring in 10 percent or more of patients and more serious GI perforations, ulcers, and bleeds occurring in fewer than one percent of users, although the risk is greater in patients older than 65 years of age. Both colchicine and NSAIDs require dose reduction in renal impairment. The adverse effects of corticosteroids and animal-derived ACTH formulation are mostly related to long term use, although dysphoria, elevation in blood glucose, immune suppression, and fluid retention may all occur, even with short term use, and cumulative doses from repeated short term courses may also cause harms similar to long term use.

### Description of Included Studies

We identified 10 existing SRs on the following therapies for acute gout: colchicine, NSAIDs, corticosteroids, and animal-derived ACTH formulation (see Table 2).43-52 Five systematic reviews received an AMSTAR rating of either 7/7, 9/9, 10/10 (see Table 3).43-45, 50, 52 Two systematic reviews received an AMSTAR rating of 6/9^47^ and 7/9.^51^ Three reviews received an AMSTAR rating of 1/9 or 2/9.^46, 48, 49^

Table 2 Randomized controlled trials included in systematic reviews

| Systematic Reviews
RCTs | Moi et al., 2013^44^ | Janssens et al., 2008^45^ | Richette and Bardin, 2010^48^ | van Echteld et al., 2014^50^ | Terkeltaub, 2008^49^ | Daoussis et al., 2014^46^ | van Durme et al., 2014^52^ | Khanna et al., 2014^47^ | Wechalekar et al., 2014^51^ | Wechalekar et al., 2013^43^ (Zero included studies)
Ahern 1987^59^ | | | × | × | × | | | ×
Alloway 1993^60^ | | × | | | | | | × | ×
Altman 1988^61^ | | | | | | | × | ×
Axelrod 1988^62^ | | | | | | × | × | ×
Borstad 2004^63^ | | | × | | × | | | | ×
Butler 1985^64^ | | | | | | | × | ×
Cheng 2004^65^ | | | | | | | × | × | ×
Chou 1995^66^ | | | | | | | | × | ×
Douglas 1970^67^ | | | | | | | × | ×
Eberl1983^68^ | | | | | | | × | × | ×
Janssens 2008^69^ | | | | | | | × | × | ×
Lederman 1990^70^ | | | | | | | × | ×
Lomen 1986^71^ | | | | | | | ×
Maccagno 991^72^ | | | | | | | × | ×
Man 2007^73^ | | × | | | | | × | ×
Paulus 1974^74^ | | | ×
Rubin 2004^75^ | | | | | | | × | × | ×
Ruotsi 1978^76^ | | | | | | | | ×
Schlesinger 2002^77^ | × | | | | | | | ×
Schumacher 2002^78^ | | | | | | | × | | ×
Schumacher 2012^79^ | | | | | | | × | ×
Shi 2008^80^ | | | | | | | | × | ×
Shrestha 1995^81^ | | | | | | | × | × | ×
Siegel 1994^82^ | | × | | | | × | | × | ×
Siegmeth 1976^83^ | | | | | | | ×
Terkeltaub 2010^84^ | | | | × | | | | ×
Tumrasvin 1985^85^ | | | | | | | | | ×
Valdes 1987^86^ | | | | | | | | × | ×
Weiner 1979^87^ | | | | | | | | ×
Zhou 2012^88^ | | | | | | | ×

Table 3 Systematic reviews of pharmacologic therapy for acute gout treatment

Author/Year/Funding | End Date of Search | # of Included Studies | # of Included Patients/Patient Characteristics Included | Setting(s) | Outcomes | Doses | Results | AMSTAR
Richette and Bardin, 2010^48^; Colchicine/Funding: T Bardin received honorarium from sanofi-aventis and Mayoly-Spindler. | Aug-10 | 3 RCTs | Not reported | Not reported | Proportion of patients with at least 50% reduction in pain within 24 hrs; Number of acute gout attacks | AGREE Trial: Placebo vs1.8mg colchicine vs. 4.8mg colchicine. RCT2: 500mg probenecid tid + 1.5mg colchicine vs. 500mg probenecid tid + placebo. RCT3: 0.6mg colchicine twice daily vs. placebo | Low-dose colchicine when given early as is effective as high-dose colchicine, in reducing pain and the number of acute gout attacks. | 2/9
Janssens et. al., 2008^45^; Systemic corticosteroids/Funding: Radboud University Nijmegen Medical Centre, Netherlands | Apr-07 | 3 head-to-head trials | 148 patients; Patients of any age with acute gouty arthritis identified after MSU crystal identification or ACR criteria or clinical grounds | Hospital in-patient and out-patient | Patient assessment of pain and disability; investigator assessment of clinical symptoms; AE's | 1. 60mg triamcinolone acetonide vs. 50mg indomethacin; 2. 30mg oral prednisolone vs. 50mg indomethacin TID for 2 days, followed by 25mg TID for 3 days.; 3. 60mg triamcinolone acetonide vs. 40 IU ACTH. | Inconclusive evidence for the efficacy and effectiveness of systemic corticosteroids compared with indomethacin in the treatment of acute gout. No AE's reported in the short-term. | 9/9
Van Durme et. al, 2014^52^; NSAIDs, COX-2, ACTH, Oral glucocorticoids/Funding: In-kind support by: Masstricht University Medical Center, Flinders University, UMNDJ, Cabrini Hopsital, Monash University, Leiding University Medical Center, Atrium Medical Centre, University of Amsterstam | 10/7/2013 | 23 RCTs | N = 2200 / adults 18+ with a diagnosis of acute gout | Outpatients | Proportion of participants with >= 50% pain improvement; Proportion of participants with >=50% inflammation or joint swelling improvement; Functioning of target joining; HRQoL; Participant withdrawal due to AE's. Total number of AE's. | NSAID (40mg) vs. placebo (N=1) NSAID vs. NSAID (N=13) NSAID (50mg indomethacin ×3) vs COX2 (etoricoxib 120mg ×1 or celecoxib 50mg, 200mg or 400mg ×2 or lumiracoxib 400mg ×1) (N=4); NSAID (naproxen 500mg ×1 or indomethacin 50mg ×3) vs. oral glucocorticoids (prednisolone 30mg or 35mg ×1) (N =2) NSAID (indomethacin 50mg ×4) vs. ACTH (40 IU ×1) (N = 1) NSAID (indomethacin 50mg ×3 then 25mg ×3) vs. rilonacept (320mg) (N=1) NSAID (indomethacin 25mg ×3) vs. Acupuncture + IR | NSAID vs. placebo: More participants reported >50% pain relief after 24 hrs with NSAID; No difference in proportion with >50% improvement in joint swelling; No AE's with NSAIDs, but some with placebo. NSAID vs. COXIB: similar pain, swelling and global improvement but fewer AE's with COXIB; fewer withdrawals due to AE's in COXIB. Lower total AE's with COXIB. NSAID vs. glucocorticoids: No difference in pain reduction, function, or AE's. | 10/10
Khanna, et. al, 2014^47^; NSAIDs, COX-2 inhibitors, ACTH, IL-1, Simiao Pill, topical ice./Funding: ACR Gout Guidelines Grant | 5/5/2013 | 30 RCTs (28 active comparator studies; 2 with a placebo-controlled group) | Number of patients not reported; pooled mean age 54.14 (SD = 11.94); 89.7% male | NR | Pain (multiple measures) | NR | Oral colchicine is effective for acute gout. Corticosteroids and possibly ACTH potentially good alternative in subjects with contraindications to NSAIDs or colchicine therapy. IL-1B promising for acute gout that is refractory or has contraindications to conventional therapy. | 6/9
Echteld et al., 2014^50^/Colchicine/Funding = Cochrane Musculoskeletal Group, Australia | 4/30/2014 | 2 RCTs | N = 124/Age 18+ with diagnosis of acute gout (i.e. author defined or MSU crystals in joint aspirate or ACR criteria or Rome criteria or New York criteria) | Hospital and Outpatient | Proportion of participants with >50% decrease in pain; Withdrawal due to AE's; Reduction of inflammation; Function of target joint; Patient global assessment of treatment success; HRQoL; Total AE's, serious AE's, and type of AE's. | 0.5mg colchicine every two hours; 4.8mg colchicine over 6 hours | Low-quality evidence that high dose colchicine relieves pain greater than 50%; Total AE's higher in high-dose colchicine vs. placebo; Low-quality evidence that high-dose colchicine provides 50% or greater decrease in joint inflammation score. Low-quality evidence that low-dose colchicine is more efficacious than placebo with respect to greater than 50% decrease in pain; there are no additional AE's for colchicine vs placebo. High-dose and low-dose colchicine approximately equal in providing greater than 50% pain relief; More AE's with high-dose colchicine vs. low-dose colchicine. | 10/10
Terkeltaub, 2008^49^; Colchicine/VA Research Service, NIH, AR Scientific, Regeneron, ARDEA, Novartis, Pfizer, TAP, Savient, BioCryst | Jul-08 | 2 RCTs | 86/characteristics not reported | Not reported | Frequency and severity of gouty arthritis flares; Proportion of participants reporting >50% reduction in pain; | 0.6mg twice daily vs. placebo (N=1) 1mg, then 0.5mg every 2 hours until a complete response or toxicity developed vs. placebo (N=1) | Addition of colchicine as a prophylactic in allopurinol treatment for urate lowering therapy, reduced the frequency and severity of gouty arthritis flares. Colchicine also effective in reducing the pain associated with gout flares. | 1/9
Daoussis et. al., 2014^46^/Funding: Not reported | Not reported | 5 (2 RCTs, 3 retrospective chart reviews) | n=266/characteristics not reported | Not reported | Time to complete resolution; time to pain relief | 40 IU ACTH single dose (N=2) 100 IU ACTH single dose (N=1) 40 or 80 IU ACTH tid, gradual tapering (N=2) | ACTH is effective in treating acute gout and can be used in patients with multiple comorbidities due to its excellent safety profile. | 2/9
Wechalekar,2014^51^ Intraarticular Glucocorticoids, Colchicine, NSAIDs, IL-1 | 9/30/2011 | 26 RCTs | N = NR/Adults 18+ with acute gout defined by study authors, presence of MSU crystals, or fulfilling the ACR, Rome, or New York criteria | NR | Pain; withdrawal due to AE's or SAE's; inflammation, patient global assessment, function of target joint, HRQoL, number of participants with AE's. | See Table 1 in study | Systemic GC as effective as NSAID but safer (moderate-quality, N=3); High and Low-dose colchicine more effective than placebo; Low-dose colchicine no safer than placebo but safer than high-dose colchicine (low-quality; N=1); No difference between NSAID and placebo in terms of pain (low-quality; N=1) | 7/9
Wechalekar 2013^43^ Intra-articular glucocorticoids/Funding: No sources supplied | 10/16/2012 | 0 | N/A | N/A | Pain; proportion of participant withdrawals due to AE's; inflammation; function; patient global assessment of treatment success; quality of life; proportion of participants with serious AE's | N/A | No trials were identified that evaluated the efficacy and safety of intra-articular glucocorticoids for acute gout. | 7/7

We also identified three new randomized-controlled trials, not included in existing SRs, that reported on the efficacy of agents to treat acute gout. These studies collectively involved 538 patients (range: 51 to 190 patients), with study time periods ranging from 5 days to 2 years. The primary outcomes of interest varied across studies, as shown in Table 4.^53-55^ Two additional studies reported on AEs.56, 57

Table 4 Randomized controlled trials of pharmacologic therapies for acute gout not included in existing systematic reviews

Author/Year | Objective | Population, Sample size | Diagnosis of gout | Intervention | Comparison | Outcomes | Timing | Results | Cochrane ROB
Karimzadeh 2006^55^ | Efficacy of colchicine prophylaxis in prevention of acute gout attacks for patients undergoing urate lowering therapy | N = 190, patients with gouty arthritis, at least one year after diagnosis, and on long-term ULT presenting to hospital rheumatology department | Unclear | Allopurinol + Colchicine for: 3-6 months (Group 1) vs. 7-9 months (Group 2) vs. 10-12 months (Group 3) | Allopurinol + Colchicine over time | Probability of recurrence of gout attacks; sUA levels | 6 months, 12 months | Probability of recurrence at 6 months: 46% (3-6mos), 11%(7-9 mos), 6% (10-12 mos). Probability of recurrence at 12 months: 54% (3-6 mos), 27.5% (7-9 mos), 23% (10-12 mos). No difference in sUA levels. | 1. Sequence: Low 2. Allocation concealment: High 3a. Blinding participants: High 3b. Blinding care providers: High 3c. Blinding outcome assessors: High 4a. Follow-up less than 20%: Low 4b. Loss to follow-up missing data explained: High 4c. Only those who completed the treatment program 5. Outcome reporting: Low 6. Findings reported as % who responded: High
Zhang 2014^54^ | Comparing NSAIDs vs. IM GC in acute gout treatment | N = 60, patients with an acute gout attack within 24 hrs. | ACR guidelines | Betamethasone (glucocorticoid) 7mg IM once vs. Diclofenac Sodium 75mg b.i.d. for 7 days | Glucocorticoid vs. NSAID | Pain intensity, tenderness, swelling, and global assessment of response to therapy, sUA levels | 7 days | In terms of change in pain intensity from baseline, betamethasone preferred on Day 3 and comparable to diclofenac sodium on Day 7. (See Table 1) Fewer AE's for betamethasone (see Table 3) No significant differences in sUA levels. | 1. Sequence: Low 2. Allocation concealment: High 3a. Blinding participants: Low 3b. Blinding care providers: High 3c. Blinding outcome assessors: High 4a. Follow-up less than 20%: Low 4b. Loss to follow-up missing data explained: Low 4c. All participants randomized to particular groups 5. Outcome reporting: Low 6. Findings reported as % who responded: Low
Li 2013^53^ | COX-2 vs. NSAIDs in treating acute gout | N=178, with an acute gouty attack (<48 hours) | ACR guidelines | Etoricoxib (120mg/day) vs. Indomethacin (75mg/day × 2) | COX-2 vs. NSAID | Self-assessed pain in affected joint, tenderness and swelling, global assessment of response to therapy, patients discontinuing treatment, AE | 5 days | No difference between etoricoxib and indomethacin in terms of pain in affected joint. Mean change difference from baseline to days 2- 5 was 0.03 (95% CI – 0.19 to 0.25; P=0.6364). No significant difference in adverse events. Absolute number of AE's: Etoricoxib (n=31) vs. Indomethacin (n=34). | 1. Sequence: Low 2. Allocation concealment: Unclear 3a. Blinding participants: Low 3b. Blinding care providers: Low 3c. Blinding outcome assessors: Low 4a. Follow-up less than 20%: Low 4b. Loss to follow-up missing data explained: Low 4c. All participants randomized to particular groups 5. Outcome reporting: Low 6. Findings reported as % who responded: High

NSAID versus Intramuscular Glucocorticoid. One trial, involving 60 patients,54 monitored self-reported pain intensity in the affected joint, patient's global assessment of response to therapy, physician assessment of joint swelling, serum urate levels, and adverse events.

NSAID versus Selective COX-2 Inhibitors. One trial, involving 178 patients,53 monitored self-assessed pain, swelling and tenderness in affected joint, physician and patient assessment of global response to therapy, and number of withdrawals due to adverse events.

Colchicine + Allopurinol, over time. One trial, involving 190 patients,55 monitored the probability of recurrence of gout attack, and the average time to recurrence. The patients were stratified by age, gender, and mean uric acid levels at baseline and follow-up.

Allopurinol versus Placebo (Colchicine as a prophylactic). One trial, involving 57 patients,58 assessed pain on a visual analog scale (VAS) in the primary joint during days 1 – 10, the number of self-reported attacks (flares) in any joint through day 30, serum urate levels, sedimentation rates, and C-reactive protein levels.

### Detailed Synthesis

#### Existing Systematic Reviews

##### Colchicine

Colchicine has been used as a treatment for gout since ancient times.1 Six prior systematic reviews44, 47-51 collectively identified 5 RCTs investigating the efficacy (pain reduction on VAS, number of acute gout attacks, and severity of attacks in terms of pain) and safety (total number of adverse events) of colchicine. Two of these studies were placebo-controlled trials of treatment for acute gout,59, 84 two were placebo-controlled studies of prophylaxis against gout flare when initiating urate lowering therapy,63, 74 and one study compared the addition of ice to colchicine and prednisone.77 All reviews found that the proportion of colchicine-treated patients who reported a greater than 50 percent pain reduction was greater than that for placebo, especially if the treatment was administered within the first 12 hours of an acute attack.44, 47-51 Low-dose colchicine (1.2mg initially followed by 0.6mg one hour later) was found to be as effective as high-dose colchicine (1.2mg initially followed by 0.6mg each hour for the next six hours) in terms of pain relief, but had a better tolerability profile in terms of gastrointestinal adverse events: 77 percent of participants who received high-dose colchicine developed diarrhea versus 23 percent in the low-dose group versus 14 percent in the placebo group.84

##### Systemic Corticosteroids

Identified systematic reviews did not find any placebo-controlled trials of systemic corticosteroids. Active-controlled trials of corticosteroids identified in the SRs are discussed in the section on comparative effectiveness.

##### NSAIDS

Two prior systematic reviews51, 52 found one low-quality trial that compared the NSAID tenoxicam (40mg once a day) against placebo in 30 patients with gout. This study reported a significant between-group difference in the fraction of patients reporting greater than 50 percent pain relief at 24 hours, no between-group differences in joint swelling at 24 hours (11/15 in the tenoxicam group vs. 4/15 in the placebo group), and no overall between-group differences at day 4.^89^ No difference in adverse events was reported among patients taking NSAIDs versus those taking the placebo.

##### Intra-articular Glucocorticoids

One prior systematic review43 on intra-articular glucocorticoids identified no randomized trials for inclusion.

#### Comparative Effectiveness

##### Systemic Corticosteroids Versus ACTH

Three prior systematic reviews45, 47, 51 identified one RCT comparing systemic corticosteroids against adrenocorticotropic hormone (ACTH).82 In this trial 31 male patients with acute gout were randomized to receive either 40 IU of ACTH or 60mg triamcinolone intramuscularly. The study is not described as double-blinded. The duration of the acute attack and the number of joints involved were not significantly different between the two groups, although the number of reinjections for continued symptoms were fewer in the triamcinolone group (14 vs. 6 p=0.075). No mention was made of side effects. We judged this trial as being at high risk of bias.

##### Systemic Corticosteroids Versus NSAIDs

Four prior systematic reviews45, 47, 51, 52 identified three trials that compared the effectiveness of systemic corticosteroids against that of NSAIDs. None of the reviews found differences in terms of time-to-resolution of symptoms, clinical joint status at follow-up, reduction of pain at rest per hour during the first two hours and at rest per day after two weeks, and reduction of pain with activity per day after two weeks. Gastrointestinal, non-gastrointestinal, and severe adverse events were more common in the NSAID than in the systemic glucocorticoid group.51

##### NSAIDs Versus Selective COX-2 Inhibitors (COX-2)

Three prior systematic reviews47, 51, 52 identified four controlled trials that compared NSAIDs against COX-2 inhibitors. COX-2 inhibitors were as effective as NSAIDs in terms of pain, joint swelling, global improvement, and health-related quality of life, but fewer withdrawals due to adverse events were observed among those treated with selective COX-2 selective inhibitors (3 percent) versus NSAIDs (8 percent) and fewer total adverse events were observed among the recipients of selective COX-2 inhibitors (38 percent) versus recipients of NSAIDs (60 percent). Low doses of selective COX-2 inhibitors were less effective in reducing pain than high doses, and NSAIDs were as effective as high-dose COX-2 inhibitors.47

##### NSAIDs Versus ACTH

Three prior systematic reviews46, 47, 52 identified one trial comparing the efficacy of NSAIDs to ACTH for the treatment of acute gout.62 In this randomized comparison of 40 IU intramuscular ACTH to 50 mg of indomethacin four times a day, among 76 (out of an initial sample of 100) men who completed 1 year of followup, the time to pain relief during an episode of acute gout was a mean of 3 hours in the ACTH-treated patients versus 24 hours in the NSAID-treated patients. No side effects were reported in the ACTH group, whereas 55 percent of patients in the NSAID group reported abdominal discomfort or dyspepsia, and 38 percent reported headaches. We judged this trial as being at high risk of bias.

##### NSAIDs Versus NSAIDs

We identified 16 RCTs that compared the efficacy of one NSAID versus another NSAID in patients with acute gout.53, 61, 64, 65, 67, 68, 70-72, 75, 76, 78, 79, 81, 83, 87 Fifteen of these 16 studies were included in prior SRs. One new trial is described below.53 Most of the studies were small and therefore underpowered to detect differences. Half of the studies enrolled fewer than 30 participants; only two studies enrolled more than 100 participants. Many of the NSAIDs studied are either no longer on the market or are not FDA-approved. Ibuprofen, which is one of the most-used NSAIDs in the US, was not assessed in any study. Most of the studies reported no statistically or clinically important differences between NSAIDs in effectiveness outcomes. These data do not support a hypothesis of clinically important differences between equipotent doses of NSAIDs in terms of relief of symptoms from acute gout, a conclusion that is compatible with how NSAIDs are viewed for most other conditions, i.e., that their effectiveness is a class effect (see Table 5).

Table 5 Randomized controlled trials of NSAID versus NSAID for treatment of acute gout

Author, Year | Sample Size | NSAID 1 | Dose 1 | NSAID 2 | Dose 2 | Statistically or Clinically Important Differences in Effectiveness
Douglas et al., 1970^67^ | 25 | Flufenamic acid | 800mg/d × 4 d, then 400mg/d | Phenylbutazone | 800mg/d × 4 d, then 400mg/d | No
Siegmeth et al., 1976^83^ | 46 | Ketoprofen | 50mg/BID | Phenylbutazone | 300mg/BID | No
Ruotsi et al., 1978^76^ | 18 | Proquazone | 300mg/TID, then 300mg/QD | Indomethacin | 50mg/TID, then 50mg/QD | No
Weiner et al., 1979^87^ | 30 | Fenoprofen | 3.6g day1, then 3.0g day 2-4 | Phenylbutazone | 700mg day1, then 400mg day 2-4 | No
Eberl et al., 1983^68^ | 20 | Meclofenamate | 800mg/day, then 100mg/TID | Indomethacin | 200mg/day, then 50mg/TID | No
Butler et al., 1985^64^ | 33 | Flurbiprofen | 400mg/d × 2d, 200mg/d | Phenylbutazone | 800mg/d × 2d, 400mg/day | No
Lomen et al., 1986^71^ | 29 | Flurbiprofen | 400mg/d × 1 day, then 200mg/d | Indomethacin | 200mg/day × 1 day, then 100mg/day | No
Altman et al., 1988^61^ | 59 | Ketoprofen | 100mg/TID | Indomethacin | 50mg/TID | No
Lederman et al., 1990^70^ | 60 | Etodolac | 300mg/BID | Naproxen | 500mg/TID | No
Maccagno et al., 1991^72^ | 61 | Etodolac | 300mg/BID | Naproxen | 500mg/BID | No
Shrestha et al., 1995^81^ | 20 | Ketorolac | 60mg/once | Indomethacin | 50mg/once | No
Schumacher et al., 2002^78^ | 150 | Etoricoxib | 120mg/QD × 8d | Indomethacin | 50mg/TID × 8d | No
Cheng et al., 2004^65^ | 62 | Rofecoxib | 50mg | Diclofenac | 150mg | Rofecoxib equivalent to diclofenac Rofecoxib superior to meloxicam Meloxicam equivalent to diclofenac
Cheng et al., 2004^65^ | 62 | Rofecoxib | 50mg | NSAID 3: Meloxicam | 15mg | Rofecoxib equivalent to diclofenac Rofecoxib superior to meloxicam Meloxicam equivalent to diclofenac
Rubin et al., 2004^75^ | 189 | Etoricoxib | 120mg/QD | Indomethacin | 50mg/TID | No
Schumacher et al., 2012^79^ | 400 | Celecoxib | 50mg/BID, 200mg/BID, 400mg/BID | Indomethacin | 50mg/TID | High dose celecoxib equivalent to indomethacin Low dose celecoxib inferior to indomethacin
Li et al., 2013^53^ | 78 | Etoricoxib | 120mg/d | Indomethacin | 75mg/BID | No

#### Evidence From New Eligible Studies

We identified three RCTs that were not included in any of the existing reviews (see Table 4).53-55, 58

Karimzadeh (2006)55 assessed the optimal duration of prophylactic use of colchicine when initiating ULT. This study is discussed in detail in the description of the results for KQ 3.

Zhang (2014)54 compared the efficacy of corticosteroids against that of NSAIDs in acute gout treatment, irrespective of gastrointestinal or cardiovascular risk factors. Sixty patients were randomized to receive either 7mg betamethasone intra-muscularly once during 7 days or 75mg diclofenac sodium twice a day for 7 days. The outcomes of treatment were pain intensity, tenderness, swelling and global assessment. Betamethasone had greater efficacy than that of diclofenac (measured as change from baseline percentage of patients reporting severe or extreme pain) on Day 3 and equivalent efficacy on Day 7. Fewer total adverse events were reported in the betamethasone group (4/30) than in the NSAID group (8/30), but statistical testing for difference was not performed. We judged this trial as being at low risk of bias.

Taylor 2012^58^ investigated whether early initiation of allopurinol influenced the duration of acute gout attacks and pain associated with them. However we have not included this study in our response to this KQ as allopurinol was not included in the scope as a treatment in acute gout.

Li 2013^53^ randomized a sample of 178 patients to either etoricoxib (120mg/day for 5 days), or indomethacin (75mg twice daily) for 5 days. No differences were seen between the two groups in self-assessed pain in the affected joint or in the total number of adverse events. We judged this study as being at low risk of bias.

The evidence from four new eligible studies is consistent with the conclusions of the systematic reviews.

#### Evidence About Subgroups

With one exception, we found no included studies that reported effectiveness stratified by any of the pre-specified subgroups of interest.

- Gender: No studies assessed the potential role of gender in response to treatment.
- Acute Episode: No studies assessed the potential effect of the duration of the acute episode on response to treatment.
- History of gout: No studies assessed the potential effect of the history of gout on response to treatment.
- Serum Urate: Karimzadeh (2006)55 found no association between serum urate level and the probability of recurrence of gout attack when using colchicine prophylactically during ULT.
- HLA-B5801 status: No studies presented data stratified by HLA-B5801 status.
- Age: Karimzadeh 2006^55^ also found no association of age with the probability of recurrence of gout attack when using colchicine prophylactically during urate lowering therapy.
- Tophi: No studies assessed the effect of the presence of tophi on response to treatment.
- Comorbidities: No studies presented data by comorbidities.

#### Harms

Fewer than 300 total gout patients were enrolled in the clinical trials that addressed this KQ. Yet these drugs have been in widespread clinical use for more than 30 years, not only for gout, but for numerous other conditions as well. A large body of evidence has been amassed on their harms, which has been summarized in various forms, including text books, systematic reviews, and online data sources. To ignore these data on the harms of these agents when used in other conditions would give readers an incomplete view of the body of evidence about harms. We therefore provide here brief summaries of the important harms of the major drugs for acute gout. Unless otherwise referenced, the data are compiled from Lexicomp, Medline Plus (www.nlm.nih.gov/medlineplus), and/or the FDA (http://www.fda.gov/Drugs/DrugSafety/default.htm).

##### Colchicine

The most common adverse effects associated with colchicine use, by far, are gastrointestinal side effects, in particular diarrhea, with reported rates of 23 percent to 77 percent. In the one placebo-controlled study of colchicine treatment for acute gout included in this review, the authors note that all patients had gastrointestinal side effects before they had relief of gout pain. Gastrointestinal side effects are dose dependent, which contributes to the popularity of “low dose” colchicine regimens.84 Other gastrointestinal symptoms are also common, such as nausea, vomiting, cramps, and pain.50 Fatigue and headache are reported in a small percent (1 percent-4 percent) of patients taking colchicine. Aplastic anemia has also been associated with colchicine. One analysis of VA databases calculated an adjusted hazard ratio of 3.32 (95% CI 2.32, 4.76) for aplastic anemia with colchicine use, and an incidence rate of 0.5/1000.^57^ Another analyses of the FDA Adverse Event Reporting System found pancytopenia, renal failure, vomiting, and diarrhea as the most common reported adverse events, although without a denominator, no rate can be calculated.56 According to the manufacturer, colchicine-induced neuromuscular toxicity and rhabdomyolysis have been reported with chronic treatment in therapeutic doses. Patients with renal dysfunction and elderly patients, even those with normal renal and hepatic function, are at increased risk. Dosage must be reduced in severe renal or hepatic impairment and with concomitant use of CYP3A4 inhibitors such as erythromycin and fluconazole and P-gp inhibitors like cyclosporine, and alternative therapies considered.

##### NSAIDs

Nonsteroidal anti-inflammatory drugs (NSAIDs) are among the most commonly used drugs in the world, and their safety profile allows for over-the-counter availability in low doses. The main harms attributed to NSAIDs are gastrointestinal side effects, both “minor” (dyspepsia) and more serious (“perforations, ulcers, and bleeds” [PUBs],” the former occurring in 10 percent or more of patients and the latter in up to 1 percent.90, 91 PUBs are more common in older patients.92 Another common adverse event associated with NSAIDs is reduced kidney function, occurring in 1 percent to 5 percent of patients, which can be acute kidney injury, worsening of hypertension, or electrolyte abnormalities. Mild-to-moderate renal impairment is a relative contraindication for NSAIDs use. NSAIDs are also reversible platelet inhibitors. Numerous other, rare, side effects have been reported, including bone marrow suppression, aseptic meningitis, and various dermatologic adverse events. NSAIDs have been associated with an increased risk of cardiac events including myocardial infarction, stroke, heart failure, and atrial fibrillation and are the subject of FDA warning labels; however, in patients without known cardiovascular disease, the increase in risk is very small.

##### Corticosteroids

Long term use of glucocorticoids is associated with a host of adverse reactions, affecting almost every organ system of the body. However, most of these harms are dose and duration-dependent. The effects of short courses of glucocorticoids are not as well understood but include dysphoria and mood disorders, elevation of blood glucose levels, immune suppression, and fluid retention. All of these effects are reversible on discontinuation of the glucocorticoids, but low doses have cumulative effects over time: The cumulative effects of repeated short term exposures are similar to those seen with long term use.

##### ACTH

Although less used and well-studied than corticosteroids the mechanism of ACTH is in part via the stimulation of cortisol production by the body, Thus although ACTH is used and studies less than are corticosteroids, the expected harms are probably very similar to those for corticosteroids. In one trial of ACTH included here, no side effects were reported among 36 treated patients. The report of the other trial stated that the 14 patients who were treated with ACTH “tolerated [it] well.”

#### Strength of Evidence

##### Colchicine

We judged the strength of evidence that colchicine improves the symptom of pain in acute gout as high, because two placebo-controlled trials showed large (∼50 percent reduction) effects.

##### NSAIDs

Only one placebo-controlled trial of an NSAID for treating acute gout was identified. However, we nevertheless judged the strength of evidence as high that NSAIDs improve the symptom of pain. We base this assessment on the biology of gout (it is an inflammatory reaction to uric acid crystals) and the mechanism of action of NSAIDs as an anti-inflammatory. Furthermore, NSAIDs are FDA approved for the temporary relief of pain, based on dozens of placebo-controlled trials for other painful conditions. Lastly, in patients starting on ULT, which is a risk factor for acute gout attacks, the strength of evidence is high (based on observational studies) that prophylaxis with NSAIDs greatly reduces this risk of an acute attack. Therefore, the evidence from the one available placebo-controlled trial is strengthened by the biological evidence and proven benefit in other painful conditions, and the large effect on prophylaxis against acute gout attacks with ULT. For comparisons of NSAID versus NSAID, while the available studies suffer from methodologic limitations, we found no signal of a differential effectiveness between NSAIDs, and this finding is compatible with the conclusions from other painful conditions that NSAIDs do not differ in effectiveness at equipotent doses. Thus we judged the SoE for this conclusion as moderate.

##### Systemic Corticosteroids

While we identified no placebo-controlled RCTs of systemic corticosteroids, we judged the strength of evidence that they reduce the symptom of pain in acute gout as high. This assessment is based on the anti-inflammatory action of steroids and the equivalence in RCTs comparing systemic steroids to NSAIDs, which we judged as high strength of evidence in relieving pain.

##### ACTH

Although we identified no placebo-controlled RCTs of ACTH in acute gout, we judged the strength of evidence as high that it reduces the symptoms of pain in acute gout. Because a primary mechanism of action for ACTH is by increasing the body's release of corticosteroids, the reasons are the same as for corticosteroids. However, we downgraded the SoE to moderate as the only two equivalence trials were both judged as high risk of bias. In contrast, three low risk-of-bias equivalence trials assessed the efficacy of systemic corticosteroids.

## Key Question 2 Dietary and Lifestyle Management of Gout

a. In adults with gout, what are the benefits and harms of different dietary therapies and life style measures on intermediate (serum and/or urine UA levels) and final health outcomes (including recurrence of gout episodes and progression [e.g., development of tophi])?
b. Does effectiveness and comparative effectiveness of dietary modification differ according to disease severity (including presence of tophi and baseline serum UA), underlying mechanisms of hyperuricemia, or baseline demographic and co-morbid characteristics?

### Key Points

- The SoE from RCTs that assess symptomatic outcomes is insufficient to support a role for specific dietary changes (including reducing intakes of dietary purines, protein, or alcohol; increasing intakes of cherries, modified milk products, or supplemental vitamin C; or achieving weight loss) in gout management.
- The SoE is insufficient to support a role for gout-specific dietary advice (counseling about reducing red meat intake; avoiding offal, shellfish, and yeast-rich foods and beverages; and including low fat dairy products, vegetables, and cherries) compared with nonspecific dietary advice (counseling about the importance of weight loss and reduced alcohol intake) for reducing serum urate levels in patients with gout.
- The SoE is insufficient to support or refute the effectiveness of Traditional Chinese Medicine (TCM; including herbs and acupuncture) on symptomatic outcomes.

### Description of Included Studies

For this KQ, we include five SRs,47, 93-96 that report findings for Traditional Chinese Medicine practices. The studies included in these SRs are shown in Table 6, and the SRs are further described in Table 9.

Table 6 Randomized controlled trials included in systematic reviews of Traditional Chinese Medicine Interventions

| Systematic Reviews
RCTs | Li et al., 2013^95^ | Zhou et al. 2013^96^ | Lee et al. 2013^94^ | Khanna et al. 2014^47^ | Choi et al. 2011^93^
Zhou 2012^88^ | | | ×
Chou 1995^66^ | | | | ×
Shi 2008^80^ | × | | | ×
Schlesinger 2002^77^ | | | | ×
Feng, 2003^108^ | | | | | ×

Table 9 Systematic reviews of Traditional Chinese Medicine interventions for acute gout treatment

Author/Year/Funding | Search End date | # of included studies | # of included patients/Patient characteristics | Setting(s) | Outcomes | Doses | Results | AMSTAR
Li et al, 2013^95^; Traditional Chinese Medicine/Funding: Program for Innovative Research Team of Beijing University of Chinese Medicine (2011-CXTD-09) and the Project for Standard Operation Procedure of Clinical Appraisal in the Program for Significant New Drugs Development | Dec. 2012 | 12 RCTs | 885 male and female adult patients (18 years and older) with a diagnosis of gout | Inpatient and/or Outpatient or NR | Pain relief | Traditional Chinese Medicine compared with colchicine (8 trials), allopurinol (4 trials), colchicine and allopurinol (3 trials), NSAID (12 trials), colchicine and NSAID (6 trials), allopurinol and NSAID (4 trials), uricosuric agents (1 trial), uricosuric and colchicines (1 trial), uricosuric and NSAID (2 trials). | There is not enough evidence showing that TCM was statistically more effective than conventional medications in pain relief [mean difference (MD), −0.03; 95 % confidence interval (CI), −0.06, 0.00],but TCM combined with conventional medicines may have better effectiveness (MD, −0.33; 95 %CI, −0.59, −0.07). | 10/11
| Dec. 2012 | 2 RCTs | 159 patients | Inpatient and/or Outpatient or NR | Recurrence (calculated as the number of patients with at least one flare during the follow-up). | | There was no evidence showing that TCM prevents gout recurrence better. | 10/11
| Dec. 2012 | 40 RCTs | 2975 gout patients | Inpatient and/or Outpatient or NR | Serum urate level reduction | | The mean serum urate level after treatment in the intervention groups was 50.1 lower (54.37 to 45.83 lower) than the mean serum urate level after treatment in the control groups (MD −50.10 [−54.37, −45.83]). | 10/11
| Dec. 2012 | 10 RCTs | 685 gout patients | Inpatient and/or Outpatient or NR | Inflammation of joint swellings after treatment | | The mean inflammation of joint swelling after treatment in the intervention groups was 0.14 lower (0.25 to 0.03 lower) compared with the mean inflammation of joint swelling after treatment in the control groups. MD −0.07 [−0.11,−0.02] | 10/11
| Dec. 2012 | 37 RCTs | NR | Inpatient and/or Outpatient or NR | Adverse reactions | | The current data show that TCM leads to fewer side reactions compared with conventional therapies [risk ratio (RR), 0.11; 95 % CI, 0.08 to 0.15]. | 10/11
Zhou et al, 2013^96^; Traditional Chinese Medicine/Funding: Natural Science Foundation of China | June 2012 | 17 RCTs | 1042 patients diagnosed with primary gout in the phase of acute arthritis. | NR | clinical efficacy: Serum urate level reduction etc. | Chinese herbal decoctions (6-45g) vs traditional Western medicine[colchicine(0.5g/4-8g);Allopurinol (0.1 g*3); Ibuprofen (0.1 g*3);Diclofenac Sodium (25mg*3); Meloxicam (7.5mg); Indomethacin (25mg) etc] | The results of the meta-analysis showed that when gout had progressed to the stage of acute arthritis, there was no significant difference in clinical efficacy between Chinese herbal decoctions and traditional Western medicine, as indicated based on the following parameters: serum urate (standardized mean difference (SMD):0.35, 95% confidence interval (CI): 0.03 to 0.67), C reactive protein (SMD: 0.25, 95% CI: 20.18 to 0.69), erythrocyte sedimentation rate (SMD: 0.21, 95% CI: -0.02 to 0.45) and overall clinical response (relative risk (RR): 1.05, 95% CI: 1.01 to 1.10). | 8/11
Zhou et al, 2013^96^; Traditional Chinese Medicine/Funding: Natural Science Foundation of China | June 2012 | 7 RCTs | 507 patients diagnosed with primary gout in the phase of acute arthritis | NR | adverse reactions | | The Chinese herbal decoction was significantly better than traditional Western medicine in controlling adverse drug reactions (RR: 0.06, 95% CI: 0.03 to 0.13). | 8/11
Lee et al, 2013^94^; Acupuncture/Funding: National Research Foundation of Korea | August 2012 | 8 RCTs | 632 patients with gouty arthritis | NR | Uric acid level reduction | Acupuncture [electro-acupuncture treatment (EAT) & acupuncture treatment (AT) 5-15days] in treatment group vs Western therapy [Allopurinol 350mg/day; Indomethacin 25mg; Probenecid 0.5 g/day; benzbromarone qd X6 days] in control group | The pooled analysis showed that acupuncture therapy alone decreased uric acid more than western therapy (MD = 30.37; 95% CI 4.28, 56.47; P<0.00001). Two out of the 8 trials (120 patients) reported a worse effect than the control group on uric acid. | 9/11
Lee et al, 2013^94^; Acupuncture/Funding: National Research Foundation of Korea | August 2012 | 4 RCTs | 380 patients with gouty arthritis | NR | Visual Analogue Scale | | The pooled analysis showed that acupuncture therapy alone improved the VAS more than western therapy (MD=2.23; 95% CI 1.39 - 3.08; P<0.0001). | 9/11
Khanna, et. al. 2014^47^; Traditional Chinese Medicine/Funding: ACR Gout Guidelines Grant | May 2013 | 30 RCTs (Only 2 relevant to Traditional Chinese Medicine) | Number of patients not reported; pooled mean age 54.14 (SD = 11.94); 89.7% male | NR | Joint swelling, Pain, serum urate | Danggui-Nian-Tong_Tang (DNTT) (6 tablets/day) vs Indomethacin (125mg/day) and Allopurinol (200mg/day); Simiao Pill vs Indomethacin (50mg per time, 3 times a day) | No significant improvement in reducing the number of painful and swollen joint (p<0.05) and pain score (p<0.01) by treatment with DGNTT compared with indomethacin. Also no significant reduction in serum urate level in DGNTT group (p>0.05) compared with allopurinol group (p<0.001); Simiao pill more efficacious than Indomethacin at Day 7 in reducing joint swelling and tenderness (p<0.05). | 6/9
Choi et al., 2011^93^ | May 2010 | 14 [2 on gouty arthritis] | NR | | Gout specific response rate | NR | Ginger moxibustion plus leflunomide is more effective than leflunomide only. The response rates were significantly higher in the moxibustion plus drug group. | 9/11

We identified six RCTs and three prospective observational studies (described in six publications) that met our inclusion criteria and that examined dietary, lifestyle, and TCM interventions in gout management.23, 97-107 These studies are described in Tables 7 and 8.

Table 7 Studies assessing dietary factors and treatment of gout

Author, year, Location, Design | Participants, N, Inclusion/Exclusion Criteria | Interventions/exposures/ Controls | Outcomes | Findings | RoB
Holland, 2014^106^ Australia RCT | 29 adults with hx of gout (age range 38-80; median 61) with stable gout on ULT, serum urate<0.36 mmol/L | Baseline knowledge testing questionnaires Intervention: British Society for Rheumatology advice on dietary gout management: (reducing red meat; avoiding offal, shellfish, yeast extract; adding low fat dairy foods, coffee, vegetables, and cherries at baseline and 3 months Control: baseline advice on weight loss, exercise, drug therapy compliance, reducing alcohol intake, and target serum urate | Serum urate at 3 and 6 months, knowledge, dietary modifications | At 6 months, intervention group had significantly improved knowledge and self-reported dietary modification compared with baseline and controls but no difference in serum urate | 1. Sequence: Low 2. Allocation concealment: High 3a. Blinding participants: Low 3b. Blinding care providers: High 3c. Blinding outcome assessors: Unclear 4a. Follow-up less than 20%: Low 4b. Loss to follow-up missing data explained: Low 4c. Unclear if all participants randomized to particular groups 5. Outcome reporting: Low 6. Findings reported as % who responded: High
Zeng, 2012^103^ China RCT | 61 overweight patients with gout (mean age 61.46±14.52 for intervention group) Inclusion: at least 1 gout attack in prior 6 months | Intervention: High protein diet 40% complex CHO, 30% protein, 30% unsaturated fat Control: Low purine diet contained 60% CHO, 10% protein, 30% fat (purine <150mg/d) Both diets were isocaloric (1500 kcal/d) | Weight, uric acid, serum lipids, # gout attacks at 6 months | High protein group lost significantly more weight than the low purine group (p=0.043); and had significantly lower serum UA (420±37 vs. 467±42 umol/L, p=0.000) and fewer gout attacks (48.48% decrease vs. 22.22% decrease, p=0.000); triglycerides decreased and HDL increased in the high protein group. | 1. Sequence: Low 2. Allocation concealment: High 3a. Blinding participants: Unclear 3b. Blinding care providers: Unclear 3c. Blinding outcome assessors: Unclear 4a. Follow-up less than 20%: Low 4b. Loss to follow-up missing data explained: Low 4c. Only those who completed the treatment regimen 5. Outcome reporting: Low 6. Findings reported as % who responded: High
Stamp, 2013^104^ New Zealand RCT | 40 patients (90% male; mean age Vitamin C: 61.2 , no Vitamin C: 55.0; mean BMI 31) with ACR-dx gout (and SU>0.36 mmol/L), 20 taking allopurinol and 20 not taking allopurinol; use of OTC vitamins excluded | Intervention: patients already taking allopurinol were randomized to receive an increased dose or to begin taking Vitamin C (500 mg/d) Patients not taking allopurinol randomized to receive allopurinol (up to 100mg/d to a target sUA <0.36) or vitamin C; open label, 8 weeks | Baseline, 4-week, and 8-week serum urate, ascorbate, and oxypurinol | Vitamin C resulted in a significant increase in serum ascorbate but a significantly smaller decrease in serum urate (0.014 mmol/L) than did allopurinol (either initiating tx or increasing dose)(0.118, p<0.001) | 1. Sequence: Low 2. Allocation concealment: High 3a. Blinding participants: High 3b. Blinding care providers: High 3c. Blinding outcome assessors: Low 4a. Follow-up less than 20%: Low 4b. Loss to follow-up missing data explained: Low 4c. All participants randomized to particular groups 5. Outcome reporting: Low 6. Findings reported as % who responded: High
Dalbeth, 2012^102^ New Zealand RCT | 120 patients (91% male; mean age 56) with recurrent gout flares (mean self-reported flares in preceding 4 months: 3.9±2.7-5.1±9.6) | Active intervention 1: Skim milk powder (SMP) Active intervention 2: SMP enriched with glycomacropeptide and G600 milk fat (SMP/GMP/G600) Control: Lactose | Recurrence of gout attacks, as defined by pain at rest of >3 on a 10-point scale and patient self-reported flare over 3 months; urinary uric acid | Gout flare frequency decrease in all 3 groups at 3 months; Decrease was significantly greater in the (SMP/GMP/G600) group, along with fractional excretion of uric acid, pain, and a trend to greater improvement in tender joint count. | 1. Sequence: Low 2. Allocation concealment: Low 3a. Blinding participants: Low 3b. Blinding care providers: Low 3c. Blinding outcome assessors: Low 4a. Follow-up less than 20%: Low 4b. Loss to follow-up missing data explained: Low 4c. All participants randomized to particular groups 5. Outcome reporting: Low 6. Findings reported as % who responded: High
Zhang, 2006^101^ US BU Online Gout Study Case-crossover | 179 patients (80% male; median age 52) with gout according to ACR criteria (median duration of disease 8 years; median duration of current flare 2 days). Patients completed 48-hour diet and lifestyle recall questionnaires during gout attacks | Exposure: alcoholic drinks | Risk for recurrent gout attacks | Compared with no alcohol consumption, odds ratios for recurrent gout attacks were 1.1, 0.9, 2.0, and 2.5 for 1 to 2, 3 to 4, 5 to 6, and 7 or more drinks consumed over the 2-day period, respectively (P<.005) | Not rated
Zhang, 2012^100^ US BU Online Gout Study Case-crossover | 663 U.S. patients with MD-diagnosed gout (confirmed in medical records by two rheumatologists via ACR criteria),18 years and older (mean age 54, 78% male), having had a gout attack within the past 12 months, who completed 48-hour diet and lifestyle recall questionnaires during gout attacks and control periods free of gout symptoms | Exposure: Cherries and cherry juice, ascertained through 48-hour dietary recall | Risk for recurrent gout attacks | Cherry intake over a 2-day period was associated with a 35% lower risk of gout attacks compared with no intake (multivariate OR 0.65, 95% CI 0.50, 0.85). Cherry extract showed similar association (multivariate OR 0.55, 95% CI 0.30, 0.98). Association was unaffected by sex, obesity status, purine intake, alcohol use, diuretic use, and use of anti-gout medications; Allopurinol use magnified the association. | Not rated
Zhang, 2012^99^ US BU Online Gout Study Case crossover | See Zhang 2012 above; 663 patients, of whom 554 had crystal-proven gout | Exposure to purine-rich foods | Risk for recurrent attacks | 1,247 gout attacks verified. Compared with the lowest quintile of total purine intake over a 2-day period, OR of recurrent gout attacks were 1.17, 1.38, 2.21 and 4.76, respectively, with each increasing quintile (p for trend <0.001). The corresponding OR were 1.42, 1.34, 1.77 and 2.41 for increasing quintiles of purine intake from animal sources (p for trend <0.001), and 1.12, 0.99, 1.32 and 1.39 from plant sources (p=0.04), respectively. The effect of purine intake persisted across subgroups by sex, use of alcohol, diuretics, allopurinol, NSAIDs and colchicine | Not rated
Neogi, 2014^98^ BU Online Gout Study Case-crossover | 724 participants with gout (78% male, mean age 54 years) who reported at least 1 gout attack during a 1-year follow-up | Exposure: alcohol quantity and type during 24 hours prior to a gout attack | Risk for recurrent gout attacks | Amount of alcohol consumed was significantly associated with risk for recurrent gout attacks (p<0.001 for trend; >1-2 drinks: RR 1.36 (95% CI 1, 1.88); >2-4 drinks: RR 1.51, (1.09, 2.09) compared with no alcohol. Type of alcohol was not a factor. | Not rated
Zhu, 2010^23^ US MRFIT Post hoc analysis of RCT | 12,379 males (35-57 years of age at baseline) at increased CVD risk (number of participants with gout not specified) enrolled in minimum 1-year dietary trial to reduce risk factors | Intervention: diet to achieve weight loss | Odds for achievement of target serum uric acid levels | A 1-kg weight loss was associated with 11% increased odds of achieving the therapeutic Goal, independent of any other factors. For men with gout, weight losses of >10 kg, 5-9.9kg, and 1-4.9kg were associated with OR of 3.19 (1.99, 5.09), 2.33 (1.75, 3.11), and 1.53 (1.24, 1.89) of achieving the target urate compared with men who did not lose weight. | Not rated
Dalbeth, 2014^97^ Australia Prospective weight loss study | 60 obese individuals with Type II diabetes (12 with gout, mean age 49(8) 42% female) | One year of non-surgical weight loss and bariatric surgery | Likelihood of achieving target serum urate at one-year post bariatric surgery | In participants with gout, mean (SD) weight reduced from 134.3 (24.3) kg at baseline visit to 100.3 (16.3) kg at the final study visit (p<0.0001). SU above therapeutic target levels (≥0.36 mmol/L) were present in 10/12 (83%) at baseline and 4/12 (33%) 1 year after surgery (p=0.031). | Not rated

Table 8 Randomized controlled trials of Traditional Chinese Medicine therapies for acute gout not included in existing systematic reviews

Author/Year | Population, Sample Size | Intervention | Outcomes | Timing | Results | Cochrane ROB
Zhang, 2010^105^ | 67 cases of acute gouty arthritis; male; aged 32-71 with an average of 48. | blood-letting cupping plus TCM (treatment group) vs. Diclofenac Sodium Enteric-coated Tablets(control group) (3 times daily for 3–7 days) | “Cure rate” (resolved joint swelling, reduced pain, and normal or decreased blood uric acid) | 1 week | “Cure rate” (resolved joint swelling, reduced pain, and normal or decreased blood uric acid) was 61% in treatment group compared with 58% in the control group. However the difference was not significant at the 5% level. | 1. Sequence: Low 2. Allocation concealment: High 3a. Blinding participants: High 3b. Blinding care providers: High 3c. Blinding outcome assessors: High 4a. Follow-up less than 20%: Low 4b. Loss to follow-up missing data explained: Low 4c. All participants randomized to particular groups 5. Outcome reporting: Low 6. Findings reported as % who responded: Low
Wang et al 2014^107^ | 176 outpatient individuals (aged > 18 years; 166 men) with newly diagnosed acute gouty arthritis | Patients were randomized to either Chuanhu anti-gout mixture 250 ml orally daily (n=88) or Colchicine mimetic agent) (n=88). | Recurrence rates; changes in white blood cells and C-reactive protein; adverse events | 12 weeks | The overall recurrence rates in the Chuanhu anti-gout mixture group (CH group) and the Colchicine group (Col group) were 12.50% vs 14.77% (difference -2.22%, 95% CI:10.78%-6.23%) respectively, suggesting that Chuanhu anti-gout mixture is not inferior to colchicine. There were less adverse events in the CH group compared with the Col group (2.27% vs 28.41%, 95% CI: 0.01-0.26). Changes in blood uric acid in the CH group were significantly larger compared with those in the Col group (P<0.05). | 1. Sequence: Low 2. Allocation concealment: Unclear 3a. Blinding participants: Low 3b. Blinding care providers: Low 3c. Blinding outcome assessors: Unclear 4a. Follow-up less than 20%: Low 4b. Loss to follow-up missing data explained: Low 4c. All participants randomized to particular groups 5. Outcome reporting: Low 6. Findings reported as % who responded: Low

One RCT assessed the effects of supplementing the diet with three different enriched skim milk products on frequency of gout flares among 120 individuals who were experiencing frequent gout flares.102 Another RCT assessed the efficacy of vitamin C supplementation in lowering serum urate in 40 patients with established gout.104 Two RCTs103, 106 assessed the effects of dietary advice on gout management. These studies, published in 2010 and 2014, enrolled adult male patients with history of gouty arthritis. The 2010 study,103 which was in Chinese, enrolled sixty-seven male patients with gout, average age of 61 years, history of overweight and at least one gouty attack during the six months before enrollment. The 2014 study106 enrolled 30 adult patients with a history of gout, receiving an appropriate and stable dose of urate lowering therapy (ULT).

Three SRs examined the efficacy of Traditional Chinese Medicine (TCM) in the management of gout while one examined the efficacy of acupuncture and one examined the efficacy of moxibustion for rheumatic conditions. The AMSTAR ratings of these 5 SRs ranged from moderate to good quality. A single RCT105 evaluated the efficacy of TCM in gout management. The study was conducted in 2010 and enrolled male patients with acute gouty arthritis and an average age of 48.^105^

### Detailed Synthesis

#### Interventions Involving Dietary Factors

##### Original Randomized Controlled Trials of Dietary Interventions

A trial102 by Dalbeth and colleagues with low to moderate risk of bias assessed whether skim milk powder (SMP) enriched with glycomacropeptide (GMP) and G600 milk fat extract, non-enriched SMP, or lactose powder significantly reduced the frequency of gout attacks (flares) over a three-month study period. The frequency of gout attacks (flares) decreased from baseline in all three groups, however there was no significant difference among the three arms in terms of the change in the number of gout attacks (flares) or in adverse events.

An RCT of 40 adult gout patients by Stamp and colleagues104 with moderate to high risk of bias compared the effects of vitamin C supplementation to that of allopurinol.104 The study found that the reduction in serum urate level over 8 weeks was significantly less in those patients receiving vitamin C than in those who started or increased their dose of allopurinol (mean reduction 0.014 mmoles/liter [0.23mg/dl] versus 0.118 mmoles /liter [1.9mg/dl]; P < 0.001). They concluded that when administered as monotherapy or in combination with allopurinol, the uric acid lowering effect of a modest dose of vitamin C seems to be small in patients with gout.104

We also identified two RCTs103, 106 that assessed the effects of dietary advice or a specific diet on gout (Table 7).

A 2014 RCT by Holland and McGill 106 compared the effects of comprehensive gout-specific dietary advice with basic advice on serum urate in gout patients. The study divided 30 gout patients (on ULT, not further specified) into an intervention group (n=14) that received comprehensive dietary advice focused on gout management, based on the British Society of Rheumatology Guidelines and a control group (N=15) that received basic advice regarding the importance of compliance with therapy and the benefit of weight loss. Two educational sessions were provided: once at baseline and once at 3 months. The study found a significant increase in knowledge and an increase in self-reported dietary modification among the group that received gout-specific advice but no differences in serum urate between the two groups at the end of 6 months (p>0.05).106 The study did not implement a clinical measure of dietary compliance (including weight loss), and self-reported compliance was extremely low. The study had a high risk of bias.

A 2012 RCT103 investigated the effects of adjusted proportional macronutrient intake on serum urate and gout attacks in overweight patients with gout. Sixty one gout patients were randomized to one of two isocaloric (1500 cal/d) diets: high protein (40% complex CHO, 30% protein, 30% unsaturated fat), or the control low purine diet (60% CHO, 10% protein, 30% fat; purine <150mg/d). The study found that frequency of gouty attacks (17 vs 28, P=0.000) and serum urate levels(420.25±36.78 vs 466.81±41.97 μmol/L, P=0.000] were significantly reduced in the high protein group compared with the low purine group.103 This study also had a high risk of bias.

#### Original Prospective Observational Studies of Dietary Factors and Risk for Gout Flare

The Boston University (BU) Online Gout Study is an internet-based prospective observational (case-crossover) study aimed at assessing the role of dietary factors in the risk for gout flare. Over 600 patients with physician-diagnosed gout (verified by two rheumatologists using ACR criteria) and at least one gout flare in the preceding year enrolled online. Over a one-year period, patients were instructed to complete 48-hour dietary recall surveys prior to gout flares and during several two-day periods of no gout activity. Use of pharmacological treatments, including gout medications, was also noted.

Zhang and colleagues reported that compared with the lowest quintile of total purine intake over a 2-day period, the OR for recurrent gout attacks were 1.17, 1.38, 2.21 and 4.76, respectively, by increasing quintile (p for trend <0.001).99 For purines from animal sources, the corresponding OR were 1.42, 1.34, 1.77 and 2.41 for increasing quintiles (p for trend <0.001), and for purines from plant sources, the OR was 1.12, 0.99, 1.32 and 1.39 (p=0.04), respectively. Subgroup analysis showed no effect of sex, use of alcohol, diuretics, allopurinol, NSAIDs and colchicine.

In a subsequent publication, the researchers also reported that cherry intake over a 2-day period was associated with a 35% lower risk of gout attacks compared with no cherry intake (multivariate OR 0.65 [95% CI 0.50–0.85]).100 Cherry extract intake showed a similar inverse association (multivariate OR 0.55 [95% CI 0.30–0.98]). Subgroup analysis showed that these findings were not affected by differences in sex, age, weight status, purine intake, alcohol use, diuretic use or use of gout medications. However, when the effect of cherry intake was considered in combination with allopurinol use, the risk of gout attacks was 75% lower than during periods without either cherry juice or allopurinol (OR 0.25, 95% CI 0.15, 0.42).

Early in the study, the researchers analyzed the association between alcohol intake and risk for gout flare among an initial group of 179 patients.101 Compared with no alcohol consumption, the OR for recurrent gout attacks were 1.1, 0.9, 2.0, and 2.5 for 1 to 2, 3 to 4, 5 to 6, and 7 or more drinks consumed over the 2-day period, respectively (P=.005). A dose-response relationship of risk of gout attacks was more evident for alcohol consumed during the prior 24 hours. An increased risk of recurrent gout attacks was found for each type of alcoholic beverage consumed, although the sample size precluded assessing the statistical significance of this observation. A follow-up study with a larger patient population also found a significant dose response relationship between the amount of alcohol consumed and the risk for recurrent flare (p<0.001 for trend).98 The risk for recurrent gout attack was 1.36 (95% CI 1.00, 1.88) for >1-2 drinks per day and 1.51 (95% CI 1.09, 2.09) for >2-4 drinks in the prior 24 hours, compared with no alcohol. This study found no difference in the risk by the type of alcohol consumed (beer, wine, or hard liquor).

Two studies have assessed the association between weight loss and serum urate levels in men with gout. Zhu and colleagues assessed the association between weight loss and serum urate levels among the men enrolled in the Multiple Risk Factor Intervention Trial (MRFIT).23 Compared with men who did not lose weight, those with weight loss in the three higher quartiles showed a significant increase in the OR of achieving the target serum urate level of ≤60μmol/L (p<0.001). The increase in the odds of achieving the target serum urate did not differ between men with gout and those without gout (the serum urate level changes for the second, third, and fourth quartiles were 7, 19 and 37 mmol/L). Dalbeth and colleagues assessed the association between bariatric surgery-induced weight loss and serum urate levels among obese individuals with Type II diabetes and gout. At the beginning of the study, 83 percent of participants had serum urate levels above the therapeutic target (≥.36mmol/L); one year after surgery, 33 percent had urate levels above the target (p=0.031).97

#### Traditional Chinese Medicine (TCM)

TCM encompasses herbal medicine, acupuncture, massage, exercise, and dietary therapies. For this review, we limited the modalities we considered to acupuncture (moxibustion) and herbal therapies. We identified five SRs that evaluated the efficacy of TCM practices in gout management: three compared multiple TCM modalities to conventional medicine (Table 9), one evaluated the efficacy of acupuncture compared with conventional medicine in gout management, and one evaluated moxibustion for the treatment of rheumatic conditions.95 47, 93, 94, 96 The TCM evaluated included a wide range of delivery methods (including decoction, granule, capsule, and pill) and multiple mixtures of herbs (up to 23 in one SR), whose extracts have been found in some cases to contain active ingredients such as colchicine.95 In aggregate, the SRs of TCM included evidence from 86 RCTs. 47, 94-96 Of these RCTs, 58 assessed the efficacy of TCM as ULT compared with conventional therapies, two assessed the recurrence of attacks (flares), 13 assessed pain reduction, 12 assessed reduction in inflammation/joint swelling, and 44 assessed adverse reactions associated with TCM.

Two SRs95, 96 that reported pooled estimates found conflicting evidence on the efficacy of TCM in reducing serum urate level in gout management. Li (2013)95 concluded that the mean serum urate level in the TCM intervention groups was 50.1 micromol/L lower than the mean serum urate level after treatment in the control groups, which had conventional medicine (MD −50.10 [−54.37, −45.83]). The SR was of good quality while the quality of evidence of pooled estimates was judged to be moderate.95 However, results from a meta-analysis by Zhou et al 2013^96^ found no significant difference in clinical efficacy between Chinese herbal decoctions and traditional Western medicine as measured by serum urate (standardized mean difference (SMD):0.35, 95% CI): 0.03 -0.67) and overall clinical response (relative risk (RR): 1.05, 95% CI: 1.01-1.10) among patients experiencing acute gout flares. The SR was moderate in quality. In addition, the SR of Khanna (2014)47 describes an RCT66 of 40 adult gout patients that found no significant reduction in serum urate level in a group given a Chinese herbal formulation compared with a group given indomethacin and allopurinol.

Two SRs addressed the efficacy of TCM for pain relief for gout management.47, 95 A trial66 described by Khanna et al (2014)47 found no significant improvement in pain score for treatment with DDNT compared with indomethacin. Li et al 2013^95^ also concluded from the results of their meta-analysis of 12 studies that the evidence was insufficient to show a statistically significant effect of TCM compared with conventional medications for pain relief (mean difference [MD], −0.03; 95 % confidence interval [CI],-0.06, 0.00), but TCM combined with conventional medicines may have better effectiveness (MD, −0.33; 95 %CI, −0.59, −0.07) than conventional medications alone.

Evidence on the efficacy of TCM in reducing inflammation and joint swelling is also conflicting. Li et al 2013^95^ conclude from their pooled analysis of 10 RCTs that the mean difference in inflammation from joint swelling after treatment in the intervention groups (TCM) was 0.14 lower (0.03 to 0.25 lower) than the mean inflammation from joint swelling after treatment in the control (conventional medicine) groups (MD −0.07 [−0.11,−0.02]). The quality of evidence (GRADE) from the pooled analysis was judged to be moderate. In addition, Khanna et al (2014)47 describe a study by Shi et al (2008)80 that finds Simiao pill more efficacious than Indomethacin at Day 7 in reducing joint swelling and tenderness. However another study66 described by them found no significant improvement in the number of painful and swollen joints with an herbal formulation (DGNT) when compared with indomethacin. Li (2013)95 also found no evidence showing that TCM prevents recurrence of gout attacks (flares).

Li et al (2013)95 found evidence suggesting that TCM is associated with fewer adverse effects than are conventional therapies [risk ratio (RR), 0.11; 95% CI, 0.08 to 0.15]. Zhou et al (2013)96 also described evidence suggesting that a Chinese herbal decoction was associated with significantly fewer adverse drug reactions than was traditional Western medicine (RR: 0.06, 95% CI: 0.03 to 0.13). We identified one systematic review that evaluated the efficacy of acupuncture in comparison with conventional therapy for gout management.94 Results from pooled analysis suggest that acupuncture therapy is more effective in reducing serum urate level (MD = 30.37; 95% CI 4.28, 56.47; P<0.00001) and pain (MD 2.23; 95% CI 1.39 - 3.08; P<0.0001) than is conventional therapy. However, two out of the eight trials (120 patients) reported a worse effect of acupuncture than the control treatment on uric acid.94 The quality of the systematic review was moderate.

We identified one SR that evaluated the efficacy of moxibustion in comparison with conventional therapies for the treatment of pain and inflammation associated with rheumatic conditions.93 Two of the included studies enrolled gout patients; however only one compared moxibustion with a medication approved for use in the US, allopurinol. Patients treated with ginger moxibustion showed an increased response rate compared with patients treated with allopurinol (100 percent response rate vs. 75 percent response rate, respectively).108

We identified two new RCTs that evaluated the efficacy of TCM in gout management (see Table 8). Zhang (2010),105in a study that we judged had high risk of bias, investigated the “cure rate” in a group that received blood-letting cupping plus TCM compared with a control group that received Diclofenac Sodium Enteric-coated Tablets. They found that the “cure rate” (measured by resolved joint swelling, reduced pain, and normal or decreased blood uric acid) was higher in the treatment group (61 percent) than in the control group (58 percent), however the difference was not significant at the 5 percent level.

Wang et al (2014),107 in a study of 176 outpatients with newly diagnosed acute gouty arthritis, compared recurrence rate and adverse events between the treatment group, which received Chuanhu anti-gout mixture and the control group, which received colchicine. The treatment group had a significantly lower overall recurrence rate, fewer adverse events, and greater changes in serum uric acid compared with the control group. The authors conclude that their findings suggest that Chuanhu anti-gout mixture is non-inferior to colchicine and can be considered an alternative choice for the treatment of acute gouty arthritis.

#### Evidence About Subgroups

No studies were identified that presented data stratified by gender, baseline or achieved serum urate, HLA-B5801 status, age, tophi, or comorbidities on the effectiveness of dietary advice for gout, specific dietary therapies, or TCM in management of gout.

#### Strength of Evidence

##### Gout-Specific Diets and Dietary Advice

We judged the strength of evidence for gout specific diets and dietary advice is insufficient to reach conclusions, as we identified only four small RCTs with three studies that had a high risk of bias.

##### TCM Including Herbs and Acupuncture

Although numerous RCTs of various herbal therapies or acupuncture were identified, the results of these studies are inconsistent, and the interventions all differ from study to study, making it impossible for us to draw any conclusions.

## Key Question 3 Pharmacologic Management of Hyperuricemia in Gout Patients

a. In adults with gout, what are the benefits and harms of different pharmacological therapies on intermediate (serum and/or urine UA levels) and long-term clinical health outcomes (including recurrence of gout episodes and progression)?
b. Does effectiveness and comparative effectiveness of urate lowering therapy differ according to disease severity (including presence of tophi and baseline serum UA), underlying mechanisms of hyperuricemia, or baseline demographic and co-morbid characteristics?
c. What is the effect of dietary modification in combination with pharmacologic therapy?

### Key Points

- High-strength evidence supports the finding that urate lowering therapy does not reduce the risk of acute gout attacks in the first 6 months.
- Moderate-strength evidence supports a reduction in the risk of acute gout attacks after about 1 year of urate lowering therapy.
- High-strength evidence supports the efficacy of urate lowering therapy in reducing serum urate.
- High-strength evidence supports the finding of no difference between 40mg febuxostat and 300mg allopurinol in serum urate lowering.
- Evidence is insufficient about the potential effect of the presence of tophi on the effectiveness and comparative effectiveness of allopurinol and febuxostat.
- High-strength evidence suggests that prophylactic therapy with low dose colchicine or low dose NSAIDs when beginning urate lowering therapy reduces the risk of acute gout attacks.
- Moderate-strength evidence supports the finding that longer courses of prophylaxis with colchicine or NSAIDs (> 8 weeks) are more effective than courses of shorter duration to prevent acute gout attacks when initiating urate lowering therapy.
- The SoE is insufficient that gout-specific dietary advice adds to the effectiveness of urate lowering therapy in reducing serum urate.
- The most common adverse event associated with allopurinol is a skin rash, occurring in up to 5 percent of patients. While most of these are mild and reversible, serious skin reactions including Topic Epidermal Necrolysis and Stevens Johnson Syndrome have been reported. Allopurinol has been proposed as a cause of the DRESS syndrome (Drug Rash with Eosinophilia and Systemic Symptoms. These serious side effects are sufficiently rare that clinical trials lack power to detect them. The risk of DRESS is greatly increased in patients with the HLA-B*5801 allele. Some evidence indicates that allopurinol reactions are more likely to occur in the first six months of treatment.
- Clinical expertise with febuxostat is less than with allopurinol. The most commonly reported adverse events in trials of febuxostat were abdominal pain, diarrhea, and musculoskeletal pain (5 percent-20 percent for each), but these rates were not statistically significantly different from those in placebo-treated patients. Rare skin reactions also occur with febuxostat.
- High-strength evidence supports a lack of difference in overall adverse events between allopurinol 300mg and febuxostat 40mg. A systematic review that identified four RCTs comparing the safety of urate lowering therapies found no statistically significant differences in overall adverse events between allopurinol and febuxostat.

### Description of Included Studies

Placebo-controlled trials. Our literature search identified one SR109 that included data from two placebo-controlled trials of allopurinol and two SRs27, 110 that included data from two placebo-controlled trials of febuxostat. In addition, we identified one abstract of a febuxostat placebo-controlled trial111, and one secondary analysis of a febuxostat placebo-controlled trial112 already included in the systematic reviews. Finally, we identified one meta-analysis that compared the efficacy of febuxostat or allopurinol to that of placebo for female patients.113

Febuxostat versus Allopurinol. Our literature search identified six narrative SRs and one meta-analysis.27, 109, 110, 113-116. Four of the reviews were high quality (AMSTAR > 8),27, 109, 110, 114 and two were low quality.115, 117 The four high quality reviews included eight trials. The results of these studies were dominated by the FACT,118 APEX,119 CONFIRMS,120 and EXCEL121 trials. Our review identified one new randomized controlled trial that was not included in any of the prior systematic reviews.122 We also identified a meta-analysis of the FACT, APEX, and CONFIRMS studies that assessed the comparative effectiveness of allopurinol and febuxostat in women with gout.113

Adverse events. We identified two SRs123, 116 and 20 studies that reported on adverse events.124-143

Colchicine versus Allopurinol. Our literature search identified one new trial comparing colchicine with allopurinol.63

Allopurinol versus Probenecid. We identified one systematic review144 that included one trial comparing probenecid with allopurinol.145 We did not identify any new trials not covered in any of the existing systematic reviews.

Prophylaxis against acute gout attacks when starting urate lowering therapy. We identified two SRs 146, 147 and three original studies that addressed this issue.55, 63, 148

Dietary modification in addition to pharmacologic therapy. We identified one trial that addressed this kind of intervention.106

### Detailed Synthesis

#### Placebo-Controlled Trials

##### Allopurinol Versus Placebo

Our literature search identified one SR109 that included data from two placebo-controlled trials of allopurinol58, 119 (see Table 11 for a description of the systematic reviews and Table 12 for descriptions of the two trials).

Table 11 Systematic reviews of febuxostat or allopurinol versus placebo for the management of chronic gout

Author/Year/Funding | End Date of Search | # of Included Studies [indicate study design] | # of Included Patients/Patient Characteristics Included | Setting(s) | Outcomes | Doses | Results | AMSTAR
Seth et al., 2014^109^; No external funding | January 2014 | 2 placebo-controlled trials of allopurinol | 1072 (Schumacher 2008) + 57 (Taylor 2012); patients with chronic gout per ARA criteria | NR | Acute gout attacks, serum urate level, AEs | Allopurinol: 100/300mg Febuxostat: 80/120/240mg | Compared with placebo, allopurinol (100 to 300mg daily) is not associated with a significant reduction in acute gout attacks, but increases the proportion of participants achieving sUA < 6.0mg/dl, without increasing withdrawals due to AEs or serious adverse event rates | 11/11
Tayar et al., 2012^27^; No external funding | July 2011 | 4 placebo-controlled trials of febuxostat, 2 open- label extension trials of febuxostat | 3978 chronic gout patients (Becker 2005a, 2005b, 2009, 2010; Schumacher 2008, 2009) - 2619 randomized to febuxostat, 172 to placebo and 1187 to allopurinol | NR | Frequency of gout flares, serum urate level, AEs | Febuxostat: 40/80/120/240mg | Compared with placebo, patients treated with all doses of febuxostat were more likely to achieve sUA < 6.0mg/dl; gout flares were more frequent among patients treated with febuxostat 120/240mg than those with placebo but there were no differences observed for 40/80mg; no statistically significant difference in AEs between any doses of febuxostat and placebo. | 11/11
Ye et al., 2013^110^; National Natural Science Foundation of China | February 2012 | 4 placebo-controlled RCTs of febuxostat | 1225 (Becker 2005, Schumacher 2008, Kamatani 2011-phase II, 2011-phase III); hyperuricemic (sUA >= 7mg/dl) adults with/without gout, mean age 47.5-52; 989 in febuxostat group and 236 in Placebo group | NR | Serum urate | Febuxostat: 20-240mg | All of the Febuxostat doses were associated with a significantly higher percent of patients achieving target serum urate levels. | 10/11

Table 12 Randomized controlled trials of allopurinol versus placebo in the management of chronic gout

Author/Year | Population, Sample Size | Intervention | Outcomes | Timing | Results | Cochrane ROB
Schumacher et al., 2008^119^ | Adults with hyperuricemia (serum urate level >8.0mg/dl) and gout (defined by the ACR criteria) with normal or impaired (serum creatinine level >1.5 to <2.0mg/dl) renal function. N = 1,072 (134 placebo, 268 allopurinol 300mg, ) (For febuxostat vs. placebo results, see Table 13) 167 participating sites in the US; the majority of investigators were primary care physicians. | Allopurinol: 300mg Naproxen or colchicine was provided during the first 8 weeks | Proportion of participants with last 3 monthly serum urate levels < 6.0mg/dl; Proportion of subjects with serum urate level < 6.0mg/dl at week 28 or final visit; Percent reduction in serum urate level; Proportion of participants requiring treatment for gout flare; Total number and size of tophi; Adverse events | 28 weeks | 22% of individuals receiving allopurinol and 0% of those receiving placebo achieved last 3 monthly serum urate level < 6.0mg/dl (P < 0.001). 41% of those treated with allopurinol and 1% of those treated with placebo achieved serum urate level < 6.0mg/dl at the week 28 (P < 0.05). Allopurinol produced 34% reduction in serum urate level from baseline, compared with 4% reduction for those treated with placebo. During the first 8 weeks of the study, when gout flare prophylaxis was provided, 23% of those treated with allopurinol and 20% of those with placebo required treatment for gout flares. Between weeks 8 and 28, there were no statistically significant differences in the proportion of subjects requiring treatment for gout flares observed between the treatment groups. No significant difference between allopurinol and placebo in the number of tophi observed or the reduction in median tophus size. AEs occurred with similar frequency across treatment groups and were mild or moderate in severity. | 1. Sequence: Low 2. Allocation concealment: High 3a. Blinding participants: Low 3b. Blinding care providers: Low 3c. Blinding outcome assessors: Low 4a. Follow-up less than 20%: High 4b. Loss to follow-up missing data explained: Low 4c. All participants randomized 5. Outcome reporting: Low 6. Findings reported as % who responded: Low
Taylor et al., 2012^58^ | Adult male with crystal-proven gout based on ACR criteria and the presence of MSU crystals on arthrocentesis of the primary joint. N = 57 (31 allopurinol, 26 placebo) Veteran's Affairs Medical Center in White River Junction, Vermont. | Allopurinol: 300mg | Pain score measured by visual analogue scale for the primary affected joint on day 1 to 10; Self-reported gout flares in any joint during day 1 to 30; Adverse events | 10 days (double blind, placebo-controlled); Day 11 - 30 (open label allopurinol 300mg) | Initial mean VAS pain scores for the allopurinol and placebo groups were 6.72 versus 6.28 (P = 0.37) decreasing to 0.18 versus 0.27 (P = 0.54) at day 10. Mean VAS pain scores did not statistically significantly differ between study groups at any point between days 1 and 10. Subgroup analysis comparing participants having a first gout attack versus those having had prior attacks revealed insignificant differences. No differences in the rate of new or recurrent gout flares between days 1 and 30 was observed - rates were 2 of 26 (7.7%) in the allopurinol group and 3 of 25 (12.0%) in the placebo group (P = 0.61). Elevation of serum creatinine > 1.5mg/dL occurred in 1 subject from each study arm. Colchicine reductions due to gastrointestinal symptoms occurred in 8 participants (31%) in the allopurinol group and 12 subjects (48%) in the placebo group. There was one death in the allopurinol group. | 1. Sequence: Low 2. Allocation concealment: Low 3a. Blinding participants: Low 3b. Blinding care providers: Low 3c. Blinding outcome assessors: Low 4a. Follow-up less than 20%: Low 4b. Loss to follow-up missing data explained: Low 4c. Only those who completed the treatment program 5. Outcome reporting: Low 6. Findings reported as % who responded: Unclear

Table 13 Randomized controlled trials of febuxostat versus placebo in the management of chronic gout

Author/Year | Population, Sample Size | Intervention | Outcomes | Timing | Results | Cochrane ROB
Becker et al., 2005^149^ | Adult patients with gout and hyperuricemia (sUA > 8.0mg/dl). All patients met the ACR criteria for the classification of the acute arthritis of primary gout. N = 153 (38 placebo, 37 febuxostat 40mg, 40 febuxostat 80mg, 38 febuxostat 120mg) Setting unclear. | Febuxostat: 40/80/120mg Colchicine prophylaxis, 0.6mg twice daily, was provided during the 2-week washout period and the first 2 weeks of double-blind treatment | Proportion of participants with serum urate levels < 6.0mg/dl; Percent reduction in serum urate level; Incidence of gout flares | 28 days | 56%, 76% and 94% of individuals treated with febuxostat 40, 80 and 120mg, respectively, achieved serum urate acid < 6.0mg/dl on day 28, compared with none in the placebo group (p < 0.001). Compared with either 80 or 120mg, patients with the highest baseline sUA levels were less likely to reach a sUA level < 6.0mg/dl when treated with 40mg/day of febuxostat on day 28. The mean percentage reductions in sUA from baseline levels were significantly greater in each febuxostat group than in the placebo group, regardless of baseline urinary uric acid production. The greatest reductions in the febuxostat group receiving 120mg/day (range of mean change 53–59% at each visit). The overall incidence of gout flares were similar in the placebo group (37%) and 40mg febuxostat group (35%) but higher in the 80mg febuxostat (43%) and the 120mg febuxostat group (55%). The incidence of gout flares was lower (i.e., 8-13%) when treatment was administered with colchicine and higher when administered alone. When administered alone, higher doses of febuxostat were associated with higher incidence of gout flares (34%, 30%, 40%, 42% for placebo, febuxostat 40, 80 and 120mg, respectively). No significant differences between the febuxostat and placebo groups in the overall incidence of treatment-related adverse events, with the majority of events being mild or moderate in severity. | 1. Sequence: Low 2. Allocation concealment: High 3a. Blinding participants: Low 3b. Blinding care providers: Unclear 3c. Blinding outcome assessors: Low 4a. Follow-up less than 20%: Low 4b. Loss to follow-up missing data explained: Low 4c. All participants randomized to particular groups 5. Outcome reporting: Low 6. Findings reported as % who responded: Low
Goldfarb et al., 2011^112^ Subgroup analysis of Becker, 2005b. | Adult patients with gout and hyperuricemia (sUA 8.0mg/dl). All patients met the ACR preliminary criteria for the classification of the acute arthritis of primary gout. N = 153 (38 placebo, 37 febuxostat 40mg, 40 febuxostat 80mg, 38 febuxostat 120mg) Setting unclear. | Febuxostat: 40/80/120mg Colchicine prophylaxis, 0.6mg twice daily, was provided during the washout period and the first 2 weeks of double-blind treatment | Proportion of subjects with serum urate levels < 6.0mg/dl at day 28; Percentage change in serum urate from baseline to day 28 | 28 days | Treatment with any dose of febuxostat led to the majority of participants achieving sUA < 6.0mg/dl on day 28 in both overproducers and underexcretors; febuxostat 40mg appeared to be more efficacious in overproducers (sample size too small to perform statistical test). The percentage change in serum urate from baseline to day 28 was similar between overproducers and underexcretors among all treatment groups. | 1. Sequence: Low 2. Allocation concealment: High 3a. Blinding participants: Low 3b. Blinding care providers: Low 3c. Blinding outcome assessors: Low 4a. Follow-up less than 20%: Low 4b. Loss to follow-up missing data explained: Low 4c. Only those who had baseline sUA 5. Outcome reporting: Low 6. Findings reported as % who responded: Low
Schumacher et al., 2008^119^ | Adults with hyperuricemia (serum urate level >8.0mg/dl) and gout (defined by the ACR criteria) with normal or impaired (serum creatinine level >1.5 to <2.0mg/dl) renal function. N = 1,072 (134 placebo, 267 febuxostat 80mg, 269 febuxostat 120mg, 134 febuxostat 240mg) (For allopurinol vs. placebo results, see Table 12) 167 participating sites in the US; the majority of investigators were primary care physicians. | Febuxostat: 80/120/240mg Placebo Naproxen or colchicine was provided during the first 8 weeks. | Proportion of participants with last 3 monthly serum urate levels < 6.0mg/dl; Proportion of participants with serum urate level < 6.0mg/dl at week 28 or final visit; Percent reduction in serum urate level; Proportion of participants requiring treatment for gout flare; Total number and size of tophi; Adverse events | 28 weeks | 48%, 65% and 69% of individuals treated with febuxostat 80, 120 and 240mg, respectively, achieved last 3 monthly serum urate levels < 6.0mg/dl; none of those with placebo did (p < 0.001). The proportions of participants with impaired renal function attaining last 3 monthly serum urate levels < 6.0mg/dl were 44% (4 out of 9 patients with impaired renal function) in the febuxostat 80mg group, 46% (5 out of 11) in the 120mg group, and 60% (3 out of 5) in the 240mg group. At week 28, 76%, 87% and 94% of participants treated with febuxostat 80, 120 and 240mg, respectively, achieved serum urate levels < 6.0mg/dl, whereas 1% of those treated with placebo achieved the same goal (p < 0.05). No statistically significant differences in the proportion of participants requiring treatment for gout flares observed between treatment groups between weeks 8 and 28. During the first 8 weeks, when gout flare prophylaxis was provided, greater proportions (p < 0.05) of participants receiving febuxostat 120mg (36%) and 240mg (46%) required treatment for gout flares, compared with those receiving febuxostat 80mg (28%) or placebo (20%). No significant difference between febuxostat and placebo in the number of tophi observed or the reduction in median tophus size, except for a significant mean percent decrease in the number of tophi observed with febuxostat 120mg (-1.2) versus placebo (-0.3) at week 28 (P < 0.05). AEs occurred with similar frequency across treatment groups and were mild or moderate in severity. | 1. Sequence: Low 2. Allocation concealment: High 3a. Blinding participants: Low 3b. Blinding care providers: Unclear 3c. Blinding outcome assessors: Low 4a. Follow-up less than 20%: High 4b. Loss to follow-up missing data explained: Low 4c. All participants randomized 5. Outcome reporting: Low 6. Findings reported as % who responded: Low

The first study, by Schumacher (2008),119 was a 28-week double-blind RCT (the APEX trial) that compared allopurinol, febuxostat, and placebo. Participants were adults with hyperuricemia and gout with normal or impaired renal function. One hundred thirty-four patients were assigned to the placebo group and 268 patients were in the allopurinol 300mg group (patients with renal impairment received 100 mg allopurinol daily). The study found that the proportion of patients who achieved serum urate < 6.0mg/dl was significantly higher for than the allopurinol treated group than for the placebo group, and allopurinol resulted in greater reduction in serum urate level from baseline than did placebo. No significant difference was seen in gout attacks (flares), number of tophi, reduction in median tophus size, or incidence of adverse events between the two groups. Among the small sample of patients with renal impairment (who received allopurinol 100mg) and those in the placebo group, none achieved “last 3 monthly” serum urate levels < 6.0mg/dl, or attained serum urate < 6.0mg/dl at either the week-28 or final visits.

The second study, by Taylor et al. (2012),58 was a 10-day double-blind RCT followed by an open label study from day 11 to day 30. Participants were adult males with crystal-proven gout who were experiencing an acute gout attack. Thirty-one patients were assigned to the allopurinol 300mg group and 26 were assigned to the placebo group. No differences in VAS pain scores or the incidence of recurrent gout attacks (flares) were found between the treatment and the placebo groups during the 10-day RCT period. Subgroup analysis comparing participants having a first gout attack with those having had prior attacks also revealed insignificant differences in pain scores. During the placebo-controlled period of the study, serum urate levels in the allopurinol group decreased significantly by day 10, whereas serum urate levels remained elevated in the placebo group during this period. When open-label allopurinol was initiated in both groups on day 11, average serum urate decreased in both groups to similar levels: less than 6.0mg/dl by day 30.

###### Adverse Events Associated With Allopurinol

Allopurinol has a greater than 40 year history of use, and high level evidence of its harms in treatment of patients with gout and other conditions has been collected. The most common adverse event associated with allopurinol is a skin rash that occurs in up to 5 percent of patients. While most of these events are mild and reversible, serious skin reactions, including Topic Epidermal Necrolysis and Stevens Johnson Syndrome, have been reported. Allopurinol has been proposed as a cause of the DRESS syndrome (Drug Rash with Eosinophilia and Systemic Symptoms).135, 137-139, 142 These serious side effects are sufficiently rare that clinical trials do not have sufficient power to detect them. In two placebo-controlled trials that included 268^119^ and 26^58^ patients treated with allopurinol, no statistically significant increases in skin reactions were observed in the allopurinol groups compared with the placebo group. Only one death was reported across both studies, that of an 80 year old male who had multiple medical problems.58 In an analysis of VA databases, among approximately 200,000 patients treated with allopurinol, 150,000 patients treated with colchicine, and 3000 patients treated with febuxostat, using a multivariable Cox proportional hazards adjusting for demographics and comorbidities, the hazard ratio for DRESS was 1.86 (95% CI 1.55, 2.24), 2.17 (95% CI 0.90, 5.26), and 1.89 (95% CI 1.53, 2.33) respectively.127 In another database analysis, this time of the French Pharmacovigilance Database (BNP), among nearly 1000 cases of toxic epidermal necrolysis or the Steven-Johnson Syndrome (90% of whom were adults), allopurinol use accounted for about 8% of cases.125 The occurrence of DRESS associated with allopurinol is increased in patients with the HLA-B*5801 allele. An abstract from Taiwan, where the HLA-B*5801allele is more common than in the United States (21% of a sample of 2037), assessed prospectively the value of HLA typing in patients with gout or hyperuricemia. Among the 80 percent of patients who tested negative for the allele (N=1618), no cases of severe cutaneous adverse reactions were reported.126 A retrospective case-control study of 70 cases of allopurinol hypersensitivity reactions found that 90 percent of cases occurred within 180 days of initiating allopurinol therapy and that cases had higher starting doses than controls (nearly 200 mg/day compared with approximately 100mg/day). The authors postulated that a “start low, go slow” prescribing practice would reduce the risk of serious adverse events.143 The most commonly reported adverse events in these two trials were upper respiratory tract infections (19 percent) and musculoskeletal and connective tissue signs and symptoms (10 percent), but these rates were not statistically different from those of the placebo group (16 percent and 10 percent, respectively).119 Therefore, our knowledge of serious AEs comes from case reports and case series.123, 129-132 In one large series of patients (N=1,732) being treated with allopurinol for gout (93 percent male, 75 percent white, mean age=51 years, and mean BMI=34 kg/m^2^), 3.0 percent of patients had serious treatment-emergent gout adverse events, death occurred in 0.2 percent; and 4.3 percent experienced adverse events leading to allopurinol withdrawal or study discontinuation.140 HLA-B*5801 is associated with an increased risk of these serious side effects,123, 128, 133, 141 and allopurinol requires a dose reduction in chronic kidney disease patients. A systematic review (AMSTAR rating 8 of 11) that compared the safety of ULT identified four RCTs that met inclusion criteria: No statistically significant differences were seen in overall adverse events between allopurinol and febuxostat.116

##### Febuxostat Versus Placebo

Our literature search identified two SRs27, 110 that included data from two placebo-controlled trials of febuxostat (see Tables 10 and 11). In addition, we identified one new abstract of a febuxostat placebo-controlled trial111 and one new secondary analysis of a febuxostat placebo-controlled trial already included in the systematic reviews (see Tables 13 and 14).

Table 10 Randomized controlled trials included in systematic reviews (febuxostat vs. placebo)

RCTs | Systematic reviews
RCTs | Tayar et al., 2012^27^ | Ye et al., 2013^a,110^
Becker et al., 2005^149^ Goldfarb et al, 2011^112^ | × | ×
Schumacher et al., 2008^119^ | × | ×

a Two trials were excluded from our review that were included in Ye, et al., 2013 as the two trials excluded patient with gouty arthritis

Table 14 Randomized controlled trials of febuxostat versus placebo for the management of chronic gout not included in existing systematic reviews

Author/Year | Population, Sample Size | Intervention | Outcomes | Timing | Results | Cochrane ROB
Saag et al., 2013^111^ Abstract only | Gout patients with hyperuricemia and moderate-to-severe renal impairment fulfilling ARA criteria, patients with tophi were excluded N = 96 (32 placebo, 32 febuxostat 30mg BID, 32 febuxostat 40/80mg QD) Setting unclear. | Febuxostat: 30mg BID Febuxostat: 40/80mg QD (titrated from FEB 40mg to 80mg QD based on day 14 sUA) | Proportion of subjects with serum urate <6.0mg/dL; Change from baseline in serum urate and estimated glomerular filtration rate (eGFR); Adverse events | 12 months | The proportion of participants with sUA < 6.0mg/dL at month 12 was 69%, 45%, and 0% for febuxostat 30mg BID, febuxostat 40/80mg QD, and PLB, respectively (P < 0.001 vs. placebo). Change in serum urate from baseline was -5.1, -4.3 and 0.07 at month 6, and -5.0, -4.2 and -0.15 at month 12 for febuxostat 30mg BID, febuxostat 40/80mg QD, and PLB, respectively (P < 0.001 vs placebo). Mean eGFR change from baseline at month 12 was not significant different across groups. The majority of AEs were mild to moderate in intensity and not considered to be related to study treatment. | 1. Sequence: Low 2. Allocation concealment: High 3a. Blinding participants: Low 3b. Blinding care providers: Low 3c. Blinding outcome assessors: Low 4a. Follow-up less than 20%: Unclear 4b. Loss to follow-up missing data explained: Unclear 4c. Unclear if all participants were randomized 5. Outcome reporting: Low 6. Findings reported as % who responded: Low

A total of two trials that evaluated the effect of febuxostat versus placebo for gout patients were included in the four SRs. The results of one trial are supplemented by a secondary subgroup analysis. The first study, by Becker et al. (2005b),149 was a 28-day double-blind RCT with 38, 37, 40, and 38 patients assigned to placebo, febuxostat 40mg, febuxostat 80mg, and febuxostat 120mg, respectively (note that febuxostat doses above 80mg are not approved for use in the US). Adult patients with gout and hyperuricemia were enrolled. No difference in the overall incidence of gout attacks (flares) were observed between the 40mg febuxostat and placebo, but the incidence increased with dosage of febuxostat (43 percent with 80mg and 55 percent with 120mg). The incidence of gout attacks (flares) was lower (8-13 percent) for all groups when colchicine was administered with febuxostat or placebo. No difference in adverse events was found between febuxostat and placebo groups. All doses of febuxostat were associated with a significantly higher proportion of patients reaching target serum urate < 6.0mg/dl and a greater reduction in serum urate from baseline, with the 120mg febuxostat being the most effective. A five-year open label extension study of this trial found that the percentage of patients who required treatment for acute gout attacks decreased to less than 5 percent after about 12 months of ULT.134 As to treatment effect heterogeneity, significant pairwise differences in percentage reductions in serum urate between each of the febuxostat groups and the placebo group were observed regardless of baseline urinary uric acid production. Compared with either 80 or 120mg, patients with the highest baseline serum urate levels were less likely to reach a serum urate level < 6.0mg/dl when treated with 40mg/day of febuxostat on day 28. A secondary analysis by Goldfarb (2011)112 concluded that the percentage change in serum urate from baseline at day 28 was similar between overproducers and underexcretors among all febuxostat groups and was significantly greater than for the placebo group.

The second study, by Schumacher et al. (2008),119 was a 28-week double-blind RCT (the APEX trial) with 134 patients in the placebo group and 267, 269, and 134 patients in the febuxostat 80, 120 and 240mg groups, respectively (note again that febuxostat doses above 80mg are not approved for use in the US). Adults with hyperuricemia and gout, with normal or impaired renal function, were enrolled. Patients receiving higher doses of febuxostat were more likely to require treatment for gout attacks (flares) during the first 8 weeks when gout flare prophylaxis was provided, but no differences were observed in gout flares across treatment groups after prophylaxis ended, between weeks 8 and 28. There was no substantial difference in the number of tophi, the reduction in median tophus size, or adverse event rate across groups, with the exception that febuxostat 120mg achieved a higher mean percent decrease in the number of tophi compared with placebo at week 28. All doses of febuxostat were associated with a significantly higher proportion of patients reaching serum urate < 6.0mg/dl, with the 240mg febuxostat being the most effective.

###### Adverse Events Associated With Febuxostat

Clinical experience with febuxostat is much lower than with allopurinol. In the three placebo-controlled trials cited above, a total of 779 patients were treated with febuxostat, of which 210 received 120mg per day (higher than the FDA-approved maximum).112, 119, 149 The most commonly reported adverse events in these trials were abdominal pain, diarrhea, and musculoskeletal pain (5 percent-20 percent for each), but the risks for these events were not statistically significantly different than for placebo-treated patients. No deaths were reported. Across all three studies, only one serious adverse event was judged by investigators to be related to febuxostat: an increase in serum creatinine from 1.1mg/dl to 1.5mg/dl while receiving 240mg/day, which decreased to 1.3mg/dl when the dose was reduced to 120mg/day.119 In a one-year open label study of 171 Japanese men treated with febuxostat, four serious AEs were reported (gastric ulcer hemorrhage, spinal stenosis, sinusitis, and aggravated spinal osteoarthritis) but these were all judged to be unrelated to treatment. No deaths were reported.136 Rare skin reactions also occur with febuxostat. One abstract reported that a prior reaction to febuxostat did not significantly increase the risk for a subsequent skin reaction; however, the 95% confidence was very wide, rendering any conclusion tentative, at best.124

According to the manufacturer, the following harms or cautions need to be considered with febuxostat:

- Febuxostat is contraindicated in patients being treated with azathioprine or mercaptopurine
- In the randomized controlled studies, patients treated with febuxostat had a higher rate of cardiovascular thromboembolic events (cardiovascular deaths, non-fatal myocardial infarctions, and non-fatal strokes) (0.74 per 100 P-Y [0.36-1.37]) than those treated with allopurinol (0.60 per 100 P-Y [95% Cl 0.16-1.53]). A causal relationship with febuxostat has not been established. Providers are advised to monitor for signs and symptoms of myocardial infarction (MI) and stroke.
- Post-marketing reports have documented fatal and non-fatal hepatic failure in patients taking febuxostat, although the reports contain insufficient information necessary to establish the probable cause. Transaminase elevations greater than three times the upper limit of normal (ULN) were observed in RCTs (AST: 2%, 2%, and ALT: 3%, 2% in febuxostat and allopurinol-treated patients, respectively). No dose-effect relationship for these transaminase elevations was noted.
- The following adverse reactions occurred in 1 percent or more of febuxostat-treated patients and were at least 0.5 percent greater in frequency than in patients who received placebo in controlled studies: liver function abnormalities, nausea, arthralgia, and rash.

#### Evidence From New Studies

The only new study we identified that met inclusion criteria was published as an abstract only. This abstract reports results from a placebo-controlled trial of febuxostat. We did not identify any new studies that compared allopurinol with placebo.

Saag et al. (2013)111 conducted a RCT with 12-month follow up targeting gout patients with hyperuricemia and moderate-to-severe renal impairment. Thirty two patients each were randomly allocated to receive either febuxostat 30mg twice daily, febuxostat 40/80mg once daily, or placebo. Compared with placebo, febuxostat was associated with a higher proportion of patients achieving a serum urate < 6.0mg/dl and greater reduction in serum urate, with febuxostat 30mg twice daily being more effective than febuxostat 40/80mg once a day. The conclusions from the new RCT were consistent with SRs comparing febuxostat with placebo.

##### Evidence About Subgroups

We found only limited data about differences in effectiveness stratified by the prespecified subgroups:

- Chohan 2012^113^ conducted a meta-analysis that compared the efficacy of febuxostat or allopurinol versus placebo for female patients, pooling data from three major RCTs (the FACT trial, APEX trial and CONFIRM trial). Female patients treated with either febuxostat or allopurinol were more likely to achieve serum urate < 6.0mg/dl than those treated with placebo. No female patients in the placebo group achieved target serum urate levels. The proportion of patients with AEs was similar across placebo, febuxostat, and allopurinol groups.
- Becker (2005) 149 stratified the sample by baseline serum urate levels and found that among patients with highest baseline serum urate, febuxostat 40mg was less effective in reducing serum urate levels than were 80 or 120mg.
- Schumacher (2008)119 compared the effectiveness of febuxostat or allopurinol versus placebo in reducing serum urate in patients with mild to moderate renal impairment. The proportion of patients with impaired renal function who achieved target serum urate levels was numerically lower than among those with normal renal function across all treatment groups. The evidence is of low quality due to the very small sample of patients with impaired renal function (ranging from 5 to 11).

#### Comparative Effectiveness

##### Febuxostat Versus Allopurinol

###### Systematic Reviews Comparing the Effectiveness of Febuxostat and Allopurinol

Four high quality SRs (AMSTAR > 8) reviewed the comparative efficacy of febuxostat and allopurinol.27, 109, 110, 114 The results of these reviews were broadly consistent, and the results of these studies were dominated by the FACT,118 APEX,119 CONFIRMS,120 and EXCEL121 trials (see Tables 15 and 16).

Table 15 Randomized controlled trials included in systematic reviews

RCTs | Systematic reviews
RCTs | Tayar et al., 2012^27^ | Faruque et al., 2013^114^ | Ye, et al., 110 Hyperuricemia with and without gout | Seth et al., 2014^109^ | Manara et al., 2013^115^ | Van Echteld et al., 2014^117^
Singal et al., 2011^151^ Bangladesh | | | | × | ×
Becker et al., 2010^120^ CONFIRMS | × | × | × | × | × | ×
Kamatani et al., 2011^150^ Japan | | × | × | | ×
Schumacher et al., 2008^119^ APEX | × | × | × | × | × | ×
Becker et al., 2009^121^ EXCEL | × | | ×
Becker et al., 2005^118^ FACT | × | × | × | × | ×
Whelton et al., 2010^152^ Renal impairment | ×
Naoyuki et al., 2011^153^ | | × | ×

Table 16 Systematic reviews of febuxostat versus allopurinol for the management of chronic gout

Author/Year Funding | End Date of Search | # of Included Studies | # of Included Patients/Participant Characteristics | Setting | Doses | Outcomes | Results | AMSTAR
Manara, 2013^115^ No external funding | March 2012 | NR | NR | NR | FEB: 40, 80, 120, 240mg/day, ALL:100, 200, 300mg/day | Achievement of sUA <6.0, gout attacks, AEs | Febuxostat is an effective urate lowering agent in patients with gout and has shown greater efficacy at a dosage of 80mg or more when compared with allopurinol at the maximum dose of 300mg in the short-term control of hyperuricaemia. Treatment with febuxostat has been shown to be safer in patients with mild or moderate renal insufficiency when compared with treatment with allopurinol. | 2/11
Tayar, 2012^27^ No external funding | July 2011 | 4 | 3,978 patients at least 16 years old meeting ACR for acute arthritis of primary gout, or diagnosis as described by the authors | Multiple primary care centers, United States and Canada | FEB: 40, 60, 80, 120, 240mg/day ALL: 100, 200, 300mg/day | Gout flare, proportion of patients with sUA <6.0mg/dl AEs, tophus burden, | FEB 40mg vs ALL: groups did not differ by gout flare incidence, achievement of sUA <6mg/dl, or AEs. FEB 80mg vs ALL: groups did not differ by gout flare incidence, but febuxostat patients more likely to achieve sUA <6mg/dl, but reduction of sUA from baseline was not statistically significant. Allopurinol group had more AEs. FEB 120/240mg vs ALL: febuxostat group had more gout flares, but also more likely to achieve sUA <6mg/dl, and there was a statistically significant reduction of sUA from baseline. AEs higher in allopurinol compared with febuxostat 120mg, but AEs were higher than allopurinol at 240mg. All doses: Tophus area reduction was greater in the febuxostat groups, but the proportion of patients with a reduction and the median reduction on the number of tophi were similar. There was no statistically significant difference in harms at 3 years. | 11/11
Faruque, 2013^114^ Alberta Heritage Foundation for Medical Research and University Hospital Foundation | Feb 2012 | 5 | 4,250 patients of all ages with chronic gout (MSU crystals or 6/12 ACR) | Multiple | FEB: 40, 60, 80, 120, 240mg/day ALL: 100, 200, 300mg/day | Proportion of gout glares, proportion achieving target serum urate (<6mg/dl), patient and physician global assessment, tophus resolution, AEs | Patients were more likely to have a gout flare on febuxostat compared with allopurinol, but this difference depends on the dose (high-dose febuxostat produced a high risk of flare while low dose <=80mg/day was similar to allopurinol in flare frequency). Febuxostat recipients had a lower risk of adverse events compared with those on allopurinol. Patients on febuxostat were more likely to reach target serum urate levels. Tophus changes were not significantly different. | 10/11
Ye, 2013^110^ National Natural Science Foundation of China | Feb 2012 | 7 RCTs (10 total studies, 7 for ALL vs. FEB | 5,690 Adults >=18 years with hyperuricemia (SUA >=7mg/dl) with and without gout | NR | ALL: 100-300mg/day FEB: 40-240mg/day | Achievement of target serum urate (<6mg/dl), AEs | SUA target reached in more people in febuxostat group. No difference in AE outcomes Compared with the allopurinol group, the proportion of patients who achieved a target sUA level <=6.0mg/dL at the final visit was higher in the febuxostat-treated group. There were no significant differences in AEs between the two groups. | 10/11
Seth, 2014^109^ No external funding | Jan 2014 | 4 comparing allopurinol with febuxostat | 4203 adults with chronic gout | NR | FEB: 40, 80, 120, 240mg/day, ALL:100, 200, 300mg/day | AEs, SAEs, gout attacks, achievement of target sUA <6mg/dl, tophus resolution | Similar rates of AEs, SEAs, and gout attacks were found when allopurinol was compared with febuxostat (80mg/day). Gout attacks were higher in febuxostat at higher doses (>80 md/day) than allopurinol. Allopurinol was less successful than febuxostat at achieving sUA < 6mg/dl. Tophus resolution was also similar for allopurinol (200-300mg/day) and febuxostat (80 md/day). | 10/10
van Echteld, 2014^117^ | October 2011 | 2 comparing allopurinol with febuxostat | 18 years of age with gout and at least 1 of the defined comorbidities or comedications (renal disease, hematologic malignancy, ischemic heart disease, cardiac failure, hypertension, dyspepsia, ulcer-related disorders, metabolic syndrome, and diabetes mellitus) | NR | FEB: 40, 80 ALL: 100, 300 | SUA | No differences in adverse events between the patient group with normal and those with impaired renal function. There were also no differences between the patient groups receiving febuxostat in different doses and allopurinol in different doses. | 7/9

In terms of clinical outcomes, gout flare incidence was higher at high doses of febuxostat (120mg or 240mg) than with allopurinol 100-300mg. Gout flare incidence was not statistically different between febuxostat 40mg, febuxostat 80mg, and allopurinol (100-300mg). Observed changes in tophi were less consistent. One review concluded that tophus area reduction was greater in patients taking febuxostat than in those taking allopurinol, but the median reduction in the number of tophi did not differ between these groups.27 Other reviews reported non-significant differences in tophi changes and resolution.109, 114

Conclusions about adverse events also varied. One review found that the high-dose febuxostat (240mg) groups experienced more adverse events than patients taking allopurinol, but the allopurinol groups had more adverse events when compared with febuxostat 80mg (note that febuxostat doses above 80mg are not approved for use in the US). When all doses were analyzed together, adverse event rates did not differ between febuxostat and allopurinol.

The research biomarker outcome results for serum urate level were consistent across these reviews: Patients taking febuxostat at doses of 80mg or higher were more likely than patients taking allopurinol 100-300mg to reach target serum urate levels of less than 6.0mg/dl.

One SR110 assessed the comparative effectiveness and safety of febuxostat and allopurinol in patients with and without gout. Patients taking febuxostat were more likely than patients taking allopurinol to achieve target sUA level <=6.0mg/dL at the final visit (all doses analyzed together). The proportion achieving target serum urate increased with the febuxostat dose (40mg: OR 1.2, 95% CI [1.05, 1.49], 80mg: OR 3.27, 95% CI [2.14-5.00], 120mg: OR 6.67 95% CI [5.23, 8.51]. There were no significant differences in AEs between the two groups: Pooled data demonstrate that both febuxostat and allopurinol groups had similar rates of AEs, which were mostly mild or moderate in severity. In the febuxostat groups, the most common AE that led to study withdrawal was elevated liver enzymes and the most frequent serious AEs were cardiovascular in nature.

One low-quality SR was also identified whose results were broadly consistent with those of the high-quality SRs.115

We also identified an SR that specifically compared the safety of urate lowering drugs. This 2014 review included seven RCTs and four SRs. Two of the included studies compared allopurinol with benzbromarone, a drug not included in our scope. The other five RCTs are all described below.118-120, 136, 150 This review concluded that total AEs did not differ significantly between allopurinol and febuxostat (pooled relative risk =1.04, 95% CI, 0.98, 1.11) (AMSTAR of 8/11).116

We also identified a SR of gout treatments in patients with impaired renal function (AMSTAR of 7/9).117

##### Major RCTs Comparing Effectiveness of Febuxostat and Allopurinol

All SRs we identified that compared the efficacy of febuxostat with allopurinol included data from the FACT118 and APEX119 clinical trials, with later SRs also including CONFIRMS120 and EXCEL.121 The results of the SRs are dominated by these studies, because of the small sample sizes of other included trials. Trials included in at least one SR were Singal (2011)151, Kamatani (2011)150, and Naoyuki (2011).153 We also included one abstract.152 The most important trials, FACT, APEX, CONFIRMS, and EXCEL, are summarized here. All of these trials used gout flare prophylaxis during the study period. FACT, APEX, and EXCEL withdrew prophylaxis after week eight. CONFIRMS prescribed prophylaxis for the entire study duration.

The FACT trial118 compared 760 patients who received either febuxostat (80 or 120mg) or allopurinol (300mg) daily for 52 weeks (note that febuxostat doses above 80mg are not approved for use in the US). No statistically significant differences in clinical outcomes were found. The overall incidence of gout attacks (flares) was similar in all groups (64 percent, 70 percent, and 64 percent, respectively) from weeks 9 to 52 (p=0.23 for febuxostat 120mg vs. allopurinol). The median reductions in tophus area were 83 percent, 66 percent, and 50 percent, respectively (p=0.08 for febuxostat 80mg vs. allopurinol, p=0.16 for febuxostat 120mg vs. allopurinol). More patients in the febuxostat 120mg group than in the allopurinol group (p=0.003) or the febuxostat 80mg group discontinued the study. Four of the 507 patients in the febuxostat groups (0.8 percent) died, compared with none in the allopurinol group (p=0.31). The outcome of achieving a target serum urate level of <6.0mg/dl was greater for the febuxostat groups than for the allopurinol group (53 percent, 62 percent, and 21 percent, respectively; p<0.001 for comparing each febuxostat group to allopurinol).

The APEX trial119 compared 1,072 patients over 28 weeks who received either febuxostat (80, 120, or 240mg/day), allopurinol (100mg or 300mg per day, based on renal function), or placebo. No differences were observed between the groups in the proportion of participants with gout attacks (flares) who required treatment between weeks 8 and 28. During the first 8 weeks of the study (when gout flare prophylaxis was provided), more patients in the high-dose (120 and 240mg) febuxostat groups required treatment for gout attacks (flares) (36 percent and 46 percent) compared with those in the febuxostat 80mg (28 percent) and allopurinol (23 percent) groups (p<0.05). No significant differences in number of tophi were observed between the allopurinol and febuxostat groups. Reductions in median tophus size were reported in all treatment groups, but no significant differences were seen between the allopurinol, febuxostat, or placebo groups. The only difference in the decrease in number of tophi was between the febuxostat 120mg group (-1.2) and the placebo group (-0.3) at the end of the study (p<0.05). Proportions of adverse events were similar across groups, except for dizziness and diarrhea, which were more frequent in the febuxostat 240mg group. The outcome of achieving serum urate levels <6.0mg/dl for the last three months of the study was observed in 48 percent of the febuxostat 80mg group, 65 percent of the febuxostat 120mg group, and 69 percent of the febuxostat 240mg group, which was significantly higher than the number who achieved that outcome in the allopurinol group (22 percent). In patients with impaired renal function, more patients treated with febuxostat (all doses) achieved a serum urate of <6.0mg/dl than patients taking allopurinol 100mg.

The CONFIRMS trial120 compared 2,268 patients receiving febuxostat 40mg per day, febuxostat 80mg per day, and allopurinol 200 or 300mg per day (depending on renal function). The only clinical outcomes reported were gout flare and safety outcomes. Rates of flare requiring treatment occurred in 10 percent to 15 percent of patients in all groups during the first two months and declined during the trial. No statistically significant differences were seen between groups. Prior use of ULT was associated with lower rates of flare compared with those without prior use (p<0.001), for each comparison. Adverse events were reported by 56 percent of participants, but the rates of occurrence did not differ among the treatment groups, and most events were mild or moderate. The outcome of serum urate level <6.0mg/dl at six months was reached in 45 percent of the febuxostat 40mg group, 67 percent of the febuxostat 80mg group, and 42 percent of the allopurinol group (p<0.001 for febuxostat 80mg compared with both of the other groups). Febuxostat 80mg was similarly superior in patients with mild to moderate renal impairment, although febuxostat 40mg was superior to allopurinol in these patients as well.

The EXCEL trial121 is an open-label extension study of two phase III trials, in which 1,086 patients received febuxostat 80 or 120mg or allopurinol 300mg for up to 40 months. Gout attacks (flares) increased after prophylaxis withdrawal in week 8, but flare rates decreased over time in all treatment groups. Gout flare was reported in less than 4 percent of participants after 18 months of treatment. Participants with tophi who maintained the target serum urate level over time experienced greater reductions in the areas of index tophi, the number of tophi, and index tophi resolution. Baseline tophus resolution was achieved by 46 percent, 36 percent, and 29 percent of participants maintained on febuxostat 80mg, febuxostat 120mg, and allopurinol, respectively. Overall adverse event rates were similar among the treatment groups. After one month of initial treatment, 81 percent and 87 percent of patients receiving 80mg and 120mg febuxostat achieved serum urate < 6.0mg/dl, as compared with 46 percent for patients receiving allopurinol. To achieve a serum urate <6.0mg/dl, more participants originally assigned to allopurinol switched to febuxostat than the number who switched from febuxostat to allopurinol.

#### RCTs not Included in any Systematic Review

We identified one new RCT122 that compared febuxostat and allopurinol in patients with chronic gout (see Table 17). This study randomized 512 Chinese gout patients to febuxostat 40mg, febuxostat 80mg, or allopurinol 300mg for 28 weeks, with flare prophylaxis provided through week 8. No significant changes in the number of tophi were observed at the final visit from baseline in all treatment groups. The rates of gout flares requiring treatment from weeks 9 through 28 and incidence of adverse events were similar among all groups. The endpoint of serum urate <6.0mg/dl for the last 3 months was reached in 45 percent of patients receiving 80mg of febuxostat, 27 percent of those receiving febuxostat 40mg, and 24 percent of those receiving allopurinol. Efficacy of febuxostat 80mg at reducing serum urate was higher than that of the other groups (p<0.001); allopurinol and febuxostat 40mg were equally effective.

Table 17 Randomized controlled trials of febuxostat versus allopurinol or colchicine versus allopurinol for the management of chronic gout not included in existing systematic reviews

Author/Year | Population, Sample Size | Intervention | Outcomes | Timing | Results | Cochrane ROB
Huang 2014^122^ Febuxostat vs. allopurinol | 516 patients (18-70 years) with gout (ACR criteria) and sUA >8.0mg/dl Chronic 14 sites in China (care setting NR) | Febuxostat 40mg/day Febuxostat 80mg/day Allopurinol 300mg/day | sUA <6.0mg/dl at 20, 24, and 28 weeks Reduction of sUA from baseline Tophi resolution Gout flares requiring treatment AEs | 2, 6, 10, 14, 16, 20, 24, and 28 weeks | 27.33%, 44.77%, and 23.84% of patients in the febuxostat 40mg, 80mg, and allopurinol groups reached target sUA, respectively. Febuxostat 80mg also achieved higher reductions in sUA from baseline. Groups did not differ on tophus resolution, gout flare, or AEs. | 1. Sequence: Low 2. Allocation concealment: Low 3a. Blinding participants: Low 3b. Blinding care providers: Low 3c. Blinding outcome assessors: Low 4a. Follow-up less than 20%: Low 4b. Loss to follow-up missing data explained: Low 4c. All participants randomized 5. Outcome reporting: Unclear 6. Findings reported as % who responded: Yes
Gibson 1982^158^ Colchicine vs. allopurinol | N=59, with at least one acute gouty arthritis attack. | Colchicine (0.5mg/day × 2) vs. Colchicine + Allopurinol (200mg/day) | glomerular filtration rate, blood urea, blood creatinine, renal calculi, urine concentrating ability, urine pH, plasma uric acid | 1 year, 2 year | Greater decline of mean GFR in colchicine group; Greater decline of plasma uric acid in allopurinol group; Greater decline and sharper trend decline for urate clearance in allopurinol group | 1. Sequence: Low 2. Allocation concealment: High 3a. Blinding participants: High 3b. Blinding care providers: High 3c. Blinding outcome assessors: High 4a. Follow-up less than 20%: Low 4b. Loss to follow-up missing data explained: Low 4c. Only those who completed the treatment program 5. Outcome reporting: Low 6. Findings reported as % who responded: Unclear

#### Evidence About Subgroups

No studies stratified results by HLA-B5801 status. One study stratified results by presence of tophi at baseline.120 Two studies118, 120 stratified results by baseline serum urate. Two studies119, 120 stratified results by renal function. Four studies154-157 were identified that compared the effectiveness of febuxostat and allopurinol in various subpopulations of the CONFIRMS trial, including diabetics, older versus younger patients, the elderly, and African Americans. One study performed a meta-analysis of the FACT, APEX, and CONFIRMS studies to assess the comparative efficacy of allopurinol and febuxostat in women with gout.113

##### Presence of Tophi at Baseline

Becker (2010)120 stratified results for achievement of target serum urate by presence of tophi at baseline. Overall, the presence of tophi was associated with lower rates of achieving target serum urate level. Among patients with baseline tophi,, those taking febuxostat 80mg were more likely to achieve target serum urate (57 percent) than patients taking febuxostat 40mg or allopurinol 200-300mg (35 percent and 32 percent). In comparison, patients without tophi at baseline achieved target serum urate levels at rates of 70 percent, 48 percent, and 45 percent, respectively.

##### Baseline Serum Urate

Becker (2005)118 stratified results for achievement of target serum urate by serum urate level at baseline. At all levels of baseline serum urate levels, febuxostat 80mg was more effective than allopurinol 300mg for achieving target serum urate (47 percent for those with baseline serum urate ≥10.0mg/dl and 57 percent for those with baseline serum urate <9.0mg/dl for febuxostat versus 8 percent for those with serum urate ≥10.0mg/dl and 40 percent for those with serum urate <9.0mg/dl for allopurinol). Becker (2010)120 also stratified results for achievement of target serum urate by serum urate level at baseline. Patients with high baseline serum urate achieved target serum urate levels at lower rates than those with lower baseline serum urate. Febuxostat 80mg was more effective for reaching target serum urate among people with high baseline serum urate (>9.0mg/dl) (49 percent to70 percent) compared with febuxostat 40mg (26 percent to 47 percent) or allopurinol 200-300mg (31 percent to 40 percent).

##### Renal Function

Becker (2010)120 stratified results for achievement of target serum urate by renal function at baseline. Compared with patients with normal renal function, patients with mild renal impairment taking either febuxostat or allopurinol were more likely to achieve target serum urate. Across treatment groups, about 71 percent of patients with mild or moderate renal impairment achieved target serum urate levels while taking febuxostat 80mg, compared with 43-52 percent of patients taking febuxostat 40mg or 31-46 percent of patients taking allopurinol 200-300mg. Schumacher (2008)119 observed similar comparative efficacy with febuxostat 80mg compared with allopurinol, but this finding was based on a small number of observations. A SR of gout treatments in patients with impaired renal function also identified only these two trials of allopurinol versus febuxostat compared with placebo (AMSTAR rating of 7 of 9).117

Gibson (1981)158 randomized 59 patients to receive either 0.5mg colchicine (twice daily) or allopurinol (200mg) and colchicine. Patients were followed for up to two years. The mean glomerular filtration rate (GFR) was statistically significantly lower in the colchicine group and declined over the study period as compared with the allopurinol group in which GFR increased slightly. Urate clearance fell in both groups but the trend was significant only in the group that received colchicine plus allopurinol. The study monitored renal function, including blood urea concentration, serum creatinine, GFR, urine concentrating ability, number of patients with proteinuria, and severity of proteinuria. For a subgroup of patients receiving colchicine who had achieved reductions in GFR of more than 10ml/min/(1×73 m^∧^2), the results were stratified by age and presence or absence of hypertension.

##### Age

Becker (2011)154 performed a secondary analysis of the CONFIRMS trial to compare efficacy of febuxostat and allopurinol in the elderly (>65 years) with that of younger patients (<65 years). Among 374 older subjects, the efficacy of both drugs was comparable in younger and older patients and both drugs were well tolerated in spite of high comorbidity rates and renal impairment in this group. Among patients with mild renal impairment and within each treatment group, urate lowering efficacy was higher in patients aged 65 and older than in younger patients. Among patients with moderate renal impairment, older patients within the 40 and 80mg febuxostat groups were more likely to achieve target serum urate than younger patients, but this age difference was not observed for allopurinol treatment.

Jackson (2012),156 another secondary analysis of the CONFIRMS data, assessed treatment efficacy in the elderly subgroup only. Febuxostat 80mg was significantly more efficacious (82 percent) than febuxostat 40mg (62 percent; p < 0.001) or allopurinol (47 percent; p < 0.001) for achieving the primary efficacy endpoint of serum urate <6.0mg/dl. Rates of AEs were low and comparable across treatments.

##### Race

Wells (2012)157 was a secondary analysis of 228 African Americans in the CONFIRMS trial. African American patients were mostly male and obese and were more likely to have diabetes, renal impairment, and cardiovascular disease. Rates of adverse events, gout flare, and efficacy in all treatment groups, were comparable between African American and Caucasian patients, regardless of renal function. Febuxostat 80mg was more effective than febuxostat 40mg or allopurinol 200/300mg in African American patients with mild or moderate renal impairment.

##### Gender

Chohan (2012)113 was a retrospective analysis of the FACT, APEX, and CONFIRMS trials that compared the efficacy of allopurinol and febuxostat in 226 women with gout. Women enrolled in these studies were older, and were more likely to be obese and to have renal impairment, hypertension, hyperlipidemia, and diabetes than the population average. Tophus resolution and incidence of gout flare were not reported. The proportions of women achieving serum urate levels <6.0mg/dl were greater in all febuxostat dosage groups compared with the allopurinol group, with efficacy significantly greater in the 80mg (p<0.001) and 120mg (p=0.006) groups. Efficacy results were similar among women with mild renal impairment, but low-dose febuxostat (40mg) was even less efficacious than higher dose febuxostat in female patients with moderate/severe renal impairment. However the number of patients in most of the renal function subgroups was small and the evidence should be interpreted with caution. Adverse event rates were similar across groups. The most common adverse events were upper respiratory tract infections, musculoskeletal/connective tissue disorders, and diarrhea.

##### Diabetes

Becker (2013)155 performed a secondary analysis of the CONFIRMS trial that compared the efficacy of gout drugs in 312 diabetic and 1957 non-diabetic patients. Diabetic gout patients were older, more likely to be female, and had longer gout duration than non-diabetic patients. Comorbidities were more common among diabetics, including cardiovascular disease, impaired renal function, hyperlipidemia, and obesity. The efficacy of febuxostat 80mg exceeded that of febuxostat 40mg or allopurinol (p <0.050) at all levels of renal function, achieving target serum urate levels in most diabetic and non-diabetic patients. Similar adverse events were reported by both diabetic and non-diabetic patients.

#### Allopurinol Versus Probenecid

We identified one SR that examined the comparative efficacy of probenecid and allopurinol.144 Only one study145 that compared probenecid and allopurinol was included in that review. In terms of clinical outcomes, the effects of allopurinol on the frequency of gout attacks and tophus resolution did not differ significantly from those of probenecid, (although only a small number of patients presented with tophi): Both groups improved on these measures from baseline. The allopurinol group experienced a mean reduction in serum urate from 9.3mg/dl to 4.7mg/dl by the last measurement, whereas serum urate in the probenecid group was reduced from 8.5mg/dl to 5.2mg/dl at the final measurement; the statistical significance of this difference was not stated. The groups did not appear to differ significantly in terms of adverse event frequency, but the nature of these events differed between the groups. All adverse events were deemed to be minor. The investigators did not stratify any of the data by subgroups (see Tables18 and 19).

Table 18 Systematic reviews of allopurinol versus probenecid for the management of chronic gout

Author/Year Funding | End Date of Search | # of Included Studies | # of Included Patients/Participant Characteristics | Setting | Doses | Outcomes | Results | AMSTAR
Kydd, 2014^144^ | May 2013 | 1 study compared probenecid with allopurinol | 37 patients with chronic gout | “clinic” | Allopurinol 300mg daily, raised to 400mg or 600mg where necessary Probenecid 1 g daily, increased to 2 g after 2 weeks | Frequency of acute gout Tophi Serum urate Adverse events | Groups did not differ with respect to reductions in gout attacks, although both groups experienced a reduction. The few patients in the study that had tophi both experienced resolution. Decreases in serum urate were observed in both groups, but the decreases were greater for the patients taking allopurinol. Adverse events occurred in both groups. | 9/9

Table 19 Randomized controlled trials of pharmacologic therapies for chronic gout not included in existing systematic reviews

Author/Year | Population, Sample Size | Intervention | Outcomes | Timing | Results | Cochrane ROB
Scott, 1966^145^ | 37 patients with chronic gout referred to “clinic” | Allopurinol 300mg daily, raised to 400mg or 600mg where necessary Probenecid 1 g daily, increased to 2 g after 2 weeks | Frequency of acute gout Tophi Serum urate Adverse events | 2 weeks, 1 month, 2 months, 3 months, and 3 month intervals up to 24 months | Groups did not differ with respect to reductions in gout attacks, although both groups experienced a reduction. The few patients in the study that had tophi both experienced resolution. Decreased in serum urate were observed in both groups, but the decreases were greater for the patients taking allopurinol. Adverse events occurred in both groups. | 1. Sequence: Low 2. Allocation concealment: High 3a. Blinding participants: High 3b. Blinding care providers: High 3c. Blinding outcome assessors: High 4a. Follow-up less than 20%: Low 4b. Loss to follow-up missing data explained: Low 4c. Only those who completed the treatment program 5. Outcome reporting: Low 6. Findings reported as % who responded: High

##### Prophylaxis Against Acute Gout Attacks (Flares) When Starting Urate Lowering Therapy

For nearly 50 years, it has been known that the initiation of urate lowering therapy is associated with an increase in the frequency of acute gout attacks (flares).159 More than 30 years ago, investigators performed trials using colchicine as prophylaxis against acute attacks when starting uricosuric therapy.74, 160 However, it was not until 2004 that the first randomized, placebo controlled trial of colchicine prophylaxis when initiating allopurinol therapy was published.63 In this study, investigators randomized 51 patients to colchicine, 0.6mg twice daily, or placebo when starting allopurinol at 100mg once a day and titrating upwards with a target serum urate of 6.5mg/dl. Eight patients dropped out before they received any study drug. Seven patients withdrew during treatment: three in the colchicine group and four in the placebo group (two in the latter group due to a high frequency of attacks or flares). The 43 patients who completed the trial averaged approximately 63 years of age, mostly male, mostly (70 percent) white, more than 60 percent had tophi, and about 10 percent had chronic renal insufficiency. Patients were followed for 6 months. The occurrence of gout flares was recorded by patient recall at 3-month and 6-month visits. The difference in the reduction in flares between treatment groups was dramatic: Flares occurred in 77 percent of placebo-treated patients and 33 percent of colchicine-treated patients (p=0.008). During the first 3 months of treatment, placebo-treated patients averaged about 2 attacks (flares) and colchicine-treated patients averaged about 0.5 flares. From months 3 to 6, this advantage diminished somewhat, with about 1 flare per patient in the placebo group and almost no flares in the colchicine group. Diarrhea was much more common in colchicine-treated patients than in placebo-treated patients (43 percent vs. approximately 4 percent).

Since that study was conducted, and even pre-dating publication of this trial, the use of prophylactic therapy concomitant with the initiation of ULT has been the standard of care according to both EULAR and ACR guidelines.31, 32, 161 All three of the recent large ULT trials—FACT, APEX, and CONFIRMS—used prophylaxis with colchicine or NSAIDs,118-120 in spite of the fact that no randomized trials have assessed NSAIDs as a prophylactic therapy in this situation. In the FACT and APEX trials, where prophylaxis was given for 8 weeks, both trials showed spikes in the number of acute attacks (flares) concomitant with the discontinuation of prophylaxis (an approximate doubling of the proportion of patients reporting a flare, from 20 percent to 40 percent). CONFIRMS continued prophylaxis for the entire 6 months of the trial, and no spike in attacks (flares) occurred. Wortmann and colleagues collected the adverse event data from all three trials and pooled data for FACT and APEX.148 It is important to note that in all three trials, patients were not randomized to different prophylaxis regimens; rather assignment was at the discretion of the treating physician. Hence, selection bias is potentially present. Overall adverse events were higher with colchicine prophylaxis than with naproxen prophylaxis (55 percent vs. 44 percent). Diarrhea was about three times more common with colchicine than with naproxen prophylaxis (8.4 percent vs. 2.7 percent). In CONFIRMS, no statistically significant difference was seen in overall AEs reported (about 55 percent in both colchicine and naproxen-treated patients), but gastrointestinal and abdominal pains were about three times more frequent in naproxen-treated patients (3.2 percent vs. 1.2 percent). Headache was more commonly reported in colchicine-treated patients. In all three studies, upper respiratory infection was the most frequently reported AE (8 percent-9 percent in each group, no statistically significant difference). In a 2014 SR that included the one RCT mentioned above,63 plus four others that employed prophylaxis when initiating therapies not included in the scope of this review (rilonacept and canakinumab), Latourte and colleagues concluded that low-dose colchicine and low dose NSAIDs are the two first-line options for prophylaxis, and that the choice depends on comorbidities and tolerance and potential interaction with other prescribed medications (AMSTAR of 3/9).146 In another 2014 SR, on preventing acute gout attacks when initiating ULT, which was conducted as part of the 3e Initiative on the Diagnosis and Management of Gout, Seth and colleagues identified four placebo-controlled RCTs: the one study described above,63 one described below,55 one study included in a SR that we included,74 and one study that used concomitant canakinumab, a drug not included in our scope. This review (AMSTAR of 7/9) concluded, like the other review and our assessment of the original trials, that colchicine prophylaxis for at least six months, when starting ULT, reduces the risk of acute attacks.147

The optimal duration of prophylaxis is unknown. Discontinuation of prophylaxis at 8 weeks is associated with a spike in attacks (flares) that does not occur when prophylaxis is continued for 6 months, but the report of the CONFIRMS trial did not describe whether flares spiked when prophylaxis was discontinued at 6 months.

We identified one RCT that compared different durations of colchicine prophylaxis when initiating allopurinol therapy in patients with gout.55 In this study, 229 patients with gout who were beginning allopurinol therapy were randomized to receive colchicine therapy (1mg/day) for either 3-6 months, 7-9 months, or 9-12 months duration. The only clinical data presented about the patients is that they averaged 47 years of age, were overwhelmingly male, and had a mean pre-treatment serum urate level of 8.5 and an on-treatment serum urate level of 6.1mg/dl. The outcome measure was “any evidence of recurrence of gouty arthritis,” but the criteria for this clinical event were not specified. Of the enrolled patients, 190 (82 percent) contributed data to the outcome. Loss to followup by group was not specified, but almost equal numbers of patients were included in each group at followup, so loss to followup was probably similar in each group. At both 6 months and 1 year, the proportion of patients who experienced recurrence was much higher in those randomized to 3-6 months of therapy than in those randomized to longer durations of therapy (at 6 months, 46 percent vs. 11 percent vs. 6 percent; at 1 year 54 percent vs. 27.5 percent vs. 23 percent, respectively). We judged this study as being at high risk of bias; therefore we could draw no conclusions from it.

##### Effect of Dietary Modification in Addition to Pharmacologic Therapy

The only randomized trial of dietary modification in addition to pharmacologic therapy tested specific dietary advice compared with general dietary advice.106 No difference was seen in serum urate between groups. The trial is discussed in more detail in KQ 2.

#### Strength of Evidence

##### Urate Lowering Therapy and Short Term Changes in Acute Gout Attacks

We judged the strength of evidence as high that urate lowering therapy does not reduce the risk of acute gout attacks, up to about six months, based on two placebo-controlled trials that each reported no difference in that outcome between groups.

##### Urate Lowering Therapy and Longer Term Changes in Acute Gout Attacks

No placebo controlled RCTs examined acute gout outcomes longer than six months from initiation of therapy. Nevertheless, we judged the strength of evidence as moderate that urate lowering therapy reduces the risk of acute gout attacks, based on the RCT evidence that urate lowering therapy reduces serum urate, the primary role of elevated serum urate as a risk factor for acute gout attacks, and the results of open-label extensions of the urate lowering therapy trials that show a steadily decreasing risk for acute gout attacks and a sustained decrease in this risk after about 1 year of therapy (< 5 percent/year).

##### Prophylactic Therapy

Although only one placebo-controlled trial tested the efficacy of prophylactic therapy when starting urate lowering therapy, we judged the strength of evidence as high that such therapy reduces the risk of acute gout attacks. We base this assessment on the large size of the effect in this trial (of colchicine), and the evidence from three large RCTs of urate lowering therapy.

In two of these trials, prophylaxis was given for eight weeks, and discontinuation of prophylaxis was accompanied by a sudden two-fold increase in the risk of acute gout attacks. In the third trial, prophylaxis was continuous throughout the six-month trial, and no “spike” of flares occurred.

##### Duration of Prophylaxis

We judge the strength of evidence as moderate that a course of prophylaxis longer than eight weeks is more effective than one of eight weeks duration based primarily on a comparison of acute gout attacks in the three ULT trials described above. This assessment is also supported by one RCT with high risk of bias.

##### Addition of Dietary Advice

We judged the strength of evidence as insufficient that the addition of gout-specific dietary advice adds to the effectiveness of urate lowering therapy, based on the existence of only one small RCT at high risk of bias.

## Key Question 4 Treatment Monitoring of Patients with Gout

a. In adults with gout, does monitoring serum urate levels with pharmacologic treatment and/or dietary and/or lifestyle change measures (e.g., compliance) improve treatment outcomes?
b. Is achieving lower subsequent serum urate levels (less than 5 vs. 5–7mg/dL) associated with decreased risk for recurrent acute gout attack, progression to chronic arthritis or disability, resolution of tophi, or other clinical outcomes (including risk for comorbidities or progression of comorbidities) or patient-reported outcomes?

### Key Points

- Evidence is insufficient to support or refute that monitoring serum urate improves outcomes.
- Low-strength evidence supports the finding that treating to a specific target serum urate level reduces the risk of gout attacks. However, the only way to know if urate lowering therapy affects serum urate is by monitoring serum urate levels. Therefore, this logic supports some monitoring, although how often and to what target have not been experimentally tested.

### Description of Included Studies

For KQ4a, we include one SR162 from which 16 original studies were reference mined.163-178

For KQ4b, we identified one SR179 and eight studies that addressed the question.11, 180-186

### Detailed Synthesis

a. In adults with gout, does monitoring serum urate levels with pharmacologic treatment and/or dietary and/or lifestyle change measures (e.g., compliance) improve treatment outcomes?

Our literature search identified one SR of studies assessing factors associated with medication adherence in gout (AMSTAR rating of 5 out of 9).162 This study searched multiple databases through July 2013 and supplemented this search with hand searches and Google scholar. Inclusion criteria were a patient population with gout, measurement and/or reporting of medication adherence, and publication in one of three languages. Data from RCTs were excluded as not being representative of real-world patient settings. From 1,398 titles, the authors identified 16 studies. We retrieved these studies and reviewed them to see if the investigators assessed the association between monitoring serum urate levels and compliance. Eleven studies did not test for the effect of serum urate on compliance.165-167, 169, 171, 172, 174, 176-178, 187 Four studies did assess serum uric acid, but analyzed whether measures of compliance were associated with subsequent serum urate levels.163, 168, 173, 188 One study tested the effect of serum “uric acid measurements” on compliance.175 This analysis included 9,823 Medicare patients who had a pharmacy benefit via the Pennsylvania Pharmacy Assistance Contract for the Elderly. The measure of compliance was the Percentage of Days Covered, which the authors claimed is nearly identical to the more commonly used Medication Possession Ratio. A value of 80 percent was used as the threshold between compliance and non-compliance. A number of factors were considered as possible predictors of noncompliance, including socio-demographic variables and “gout specific factors.” The latter included uric acid measurements. This factor was not a statistically significant predictor of compliance, an observation confirmed by contacting the first author of the paper, who said, “We found no evidence that performing tests was associated with adherence” (DH Solomon, personal communication, Jan 30th, 2015).

We performed an update search, using the authors' search strategy, from May 2013 to January 2015, and identified an additional 115 titles. Applying the same inclusion/exclusion criteria yielded no new studies assessing the effect of serum urate measurement on compliance or outcomes.

We identified no studies that assessed whether monitoring serum urate levels for gout patients influences treatment outcomes.

#### Summary

We found no evidence to support or refute the hypothesis that monitoring gout patients on treatment with serum urate measurements leads to improved compliance or improved outcomes. However, the only way to know if ULT is having an effect on serum urate is by monitoring serum urate levels, and this logic supports some monitoring, although how is unknown.

b Is achieving lower subsequent serum urate levels (less than 5 vs. 5-7mg/dl) associated with decreased risk for recurrent gout attack, progression to chronic arthritis or disability, resolution of tophi, or other clinical outcomes (including risk for comorbidities or progression of comorbidities) or patient reported outcomes?

A large body of evidence supports the hypothesis that lower serum urate levels are causally associated with a lower rate of acute gout attacks (flares). Underlying this hypothesis is the basic chemistry of uric acid, namely that it is soluble up to a concentration of about 6.8mg/dl, above which it may start to precipitate. However, patients with serum urate levels above this threshold may still be asymptomatic whereas gout patients with serum urate levels below this threshold still may have acute attacks (flares).

The best data on the relationship between serum urate levels and risk of acute attack may come from analyses of the large trials of ULT, FACT and APEX. In a post-hoc analysis that combined data from both of these trials, and that included more than 1800 subjects with gout and a baseline serum urate level of 8.0mg/dl or greater, the achieved serum urate level was one of three variables (along with the baseline presence of tophi and the percent change in serum urate level from baseline) that, in multivariate logistic regression, was associated with acute gout attacks (flares) requiring treatment (adjusted odd ratio of 1.42 [95% CI 1.16, 1.73] and adjusted odds ratio of 2.70 [95% CI 1.72, 4.22], at either 6 months or 12 months after initiation of therapy, respectively).182 When the serum urate level achieved was dichotomized at 6.0mg/dl, at the end of one year, those patients, that had achieved a value below 6.0mg/dl, regardless of treatment group, had acute gout attacks (flares) at a rate of approximately 5 percent, whereas this rate was between 10 percent and 15 percent for patients with serum urate levels at or above 6.0mg/dl (p value reported as less than 0.05).

Supporting the results of this trial are the findings many retrospective cohort studies. Although not all of these studies restricted the eligible patients to those with gout on ULT, we nevertheless deemed their results relevant for this study question. For example, among 2237 patients aged 65 and older in the Integrated Healthcare Information Services claims database between 1999 and 2005were 633 patients with gout and a serum urate level less than 6mg/dl, 1,173 persons with a serum urate level between 6.0 and 8.99mg/dl, and 431 patients with a serum urate level of 9.0mg/dl or greater. The proportions of patients among these three groups with at least one gout flare over a 12-month period, as defined by a visit for gout and receiving a prescription for typical acute gout pharmacologic therapy, were 27 percent, 43 percent, and 46 percent, respectively.180

In another study, patient-level data were collected from 125 rheumatologists and 124 primary care providers in the US. Data on 1,245 patients with gout were analyzed. Serum urate level was positively correlated with the occurrence of a gout flare over 12 months (r=0.29, p value reported as less than 0.01) 185

In another study of similar design, patient-level data were collected from 50 U.S. practices on recent patients with gout seen from 2010 to 2011. Of 479 patients assessed, serum urate level was associated with a flare-related visit in bivariate analyses (p=0.004).184

Two other administrative claims analysis studies, one including 18,243 patients and the other including 5,942 patients, both of which used algorithms involving claims and pharmacologic prescriptions to identify gout patients, reported that patients with a serum urate level of greater than 6.0 had 1.3 times the odds of an acute gout flare181 or a 1.59 relative risk.183

A SR (AMSTAR rating 7 of 9) identified 11 studies that assessed the association among allopurinol administration, serum urate levels, and subsequent outcomes; subsequent gout attacks were the outcomes in seven of the 11 studies. None of the included studies were experimental. Six were cohort studies, three were administrative database analyses, and two were case control studies. All of the studies were judged as being at high risk of bias, thus limiting any conclusions that could be drawn. Nevertheless the authors concluded that reductions in serum urate (SUA) “are significantly associated with the achievement of desirable gout outcomes.” However, the authors caution that the “the level to which SUA must be reduced (cut off point) remains unclear.”179

Few studies have related serum urate levels to comorbidities. One study of U.S. Veterans with gout used the VA data warehouse to follow 2116 patients for a mean followup of 6.5 years. Comparing patients with high versus low serum urate levels, the investigators reported about a two-fold difference in new diagnoses of kidney disease (4 percent vs. 2 percent at year 1, 9 percent vs. 5 percent at year 3, respectively).11 However, this study had a high risk of bias.

Lastly, an abstract presented by investigators at the Mayo Clinic described a study that followed 158 patients with incident gout (mean serum urate level was 8.1mg/dl; 70 percent of cases presented as podagra) in Rochester MN for a mean of 13 years. . Higher serum urate levels predicted a subsequent acute gout flare (odds ratio 1.35, 95% CI 1.2, 1.5). However, only 70 percent of the patients had a flare during the extended followup, meaning that 30 percent of patients had only the single incident episode .189

Limiting the evidence base for using serum urate as a target value for treatment, (as blood pressure and hemoglobin A1c are used, for example, for the management of hypertension and diabetes), is the lack of any experimental study that has based treatment decisions on a target. Treating to a target necessarily means increasing doses of medication, which increases the risk of side effects, and therefore changes the benefit: risk assessment.

#### Strength of Evidence

##### Monitoring Serum Urate Levels

Evidence is insufficient for an effect of monitoring serum urate levels. An argument can be made that without monitoring, treatment cannot be adjusted.

##### Treating to Target

The strength of evidence is low that treating to a specific serum urate level reduces the risk of acute gout attacks. While elevated serum urate is the primary risk factor for acute gout attacks, and lowering serum urate levels can be expected to reduce the risk of acute gout attacks, the concept of a specific target value, such as 6.0mg/dl, has not been tested. Different targets have been proposed (e.g., 7.0mg/dl, 6.0mg/dl, 5.0mg/dl) and trying to lower serum urate levels to a target in patients who may be asymptomatic (in that they have not had a recent acute gout attack) at higher-than-target levels will necessitate increasing use of medication. The value of that strategy has yet to be proven, and examples exist from other asymptomatic conditions, in which treating to target resulted in more side effects than benefit. Thus, despite the strong biologic appeal of such a strategy, we judged the strength of evidence as low.

## Key Question 5 Discontinuation of Pharmaceutical Management for Patients on Acute or Chronic Gout Medications

In adults with gout, are there criteria that can identify patients who are good candidates for discontinuing

a. urate lowering therapy?
b. anti-inflammatory prophylaxis against acute gout attack for patients on urate lowering therapy after an acute gout attack?

### Key Points

- The evidence is insufficient that discontinuing urate lowering therapy results in no increase in risk of acute gout attacks in gout patients who have completed 5 years of urate lowering therapy that kept serum urate levels < 7mg/dl, and in whom subsequent annual serum urate levels (off of urate lowering therapy) stayed < 7mg/dl.
- Moderate-strength evidence supports the finding that prophylaxis for acute gout with low dose colchicine or NSAIDs when initiating urate lowering therapy results in fewer gout attacks when treatment is given for longer than 8 weeks.

### Description of Included Studies

We identified three observational (prospective cohorts) studies that assessed two clinical cohorts of patients in whom urate lowering therapy was discontinued.190-192

The data about duration of anti-inflammatory prophylaxis when initiating urate lowering therapy comes from the results of the FACT, APEX, and CONFIRMS trials, previously discussed in detail in response to KQ4.

### Detailed Synthesis

#### Discontinuation of Urate Lowering Therapy

We identified three prospective observational cohort studies of patients in whom ULT was discontinued and patients were followed for an extended period of time.190-192

More than 30 years ago, Loebl and Scott followed 33 patients with gout on allopurinol. All but one patient was male, their mean age was 58, and none of the patients were overproducers of uric acid as assessed by 24-hour urinary uric acid analysis. The mean serum urate level before treatment was 8.4mg/dl, decreasing to 5.5mg/dl while on therapy. Patients were on therapy for a mean of 93 weeks before discontinuation. They were followed for a mean of 86 weeks off therapy. In all patients, serum urate levels rose quickly following discontinuation of therapy. However, only 12 patients (36 percent) experienced a recurrence; the other 21 patients remained asymptomatic during the period of observation. Twenty of these patients continued off allopurinol at a mean of 107 weeks. The main difference between symptomatic and asymptomatic patients was their serum urate level on therapy: 6.2mg/dl in the symptomatic patients and 5.1mg/dl in those who were asymptomatic (statistical testing was not performed).191

In the second study, Perez-Ruiz and colleagues190 assembled a cohort of 211 patients with gout who met the following criteria:

- An average serum urate level of <7mg/dl for “the entire duration of” ULT
- Compliance with ULT for 5 years, or 5 years after resolution of any tophi. Compliance was defined as ≥ 80 percent of all serum urate levels <6mg/dl during therapy.

Patients were overwhelming male and averaged 65 years of age. About 25 percent had subcutaneous tophi at baseline. Mean pre-treatment serum urate levels were 8.0mg/dl, the mean duration of ULT was 66 months, the mean serum urate level on therapy was 4.9mg/dl, and the mean serum urate level following discontinuation of therapy was 8.5mg/dl. The mean followup time was 33 months. Among the 27 patients who maintained a serum urate level less than 7mg/dl off therapy, none had a clinical recurrence. Of the remainder, clinical recurrences were highly correlated with off-treatment serum urate levels: 13 percent of 61 patients with a value of 7.0-8.2mg/dl, 51 percent of 61 patients with a value of 8.2-9.3mg/dl, and 61 percent of 62 patients with a serum urate level about 9.3mg/dl. These results confirmed the findings of an earlier report by the same author, of about 100 patients, some or all of whom probably contributed data to their cohort of 211. In the earlier paper the median “survival” off ULT to the first acute gout attack was 34 months for patients with higher SUA (≥ 8.75 mg/dl) and 49 months for patients with lower levels (≤ 5.05 mg/dl).192 The authors speculate that a period of 5 years of “crystal depletion” with a target serum urate level “far below” 6mg/dl, could be followed by more relaxed, or even no therapy, designed to keep serum urate levels less than 7mg/dl.

#### Discontinuation of Prophylaxis

In FACT and APEX, anti-inflammatory prophylaxis was discontinued after 8 weeks and in both studies, acute gout flare spiked immediately thereafter (about double the rate). In CONFIRMS, anti-inflammatory prophylaxis was continued for 6 months, to the conclusion of the trial, and no spike occurred at 8 weeks.

One older 1989 trial of intermittent ULT concluded that intermittent therapy was less effective than continuous therapy. This study did not use true random assignment and therefore did not meet our eligibility criteria; however, we have included it, as it is the only trial of its type. This study assigned 50 patients by the even/odd hospital number to either continuous allopurinol (titrated to a dose of about 300mg/day) or 8 weeks cycles on and off allopurinol. In the first two years of therapy, the number of acute gout attacks did not differ statistically significantly between groups, but up to 4 years after therapy, attacks were more common in the intermittent treatment group (10 attacks) than in the continuous treatment group (0 attacks).193

#### Strength of Evidence

##### Discontinuation of ULT

We judged the strength of evidence as insufficient that patients who were asymptomatic for five years with a serum uric acid of <7mg/dl could have their ULT discontinued. Only one cohort study, which enrolled more than 200 patients with gout, found evidence supporting discontinuation of medication. This strategy will need to be tested in an RCT. Selection bias is always a concern in observational studies of treatment strategies.

##### Prophylactic Discontinuation

A moderate strength of evidence supports the finding that prophylaxis longer than eight weeks is associated with better outcomes than prophylaxis of eight weeks duration, based on the cross-study comparison of risk of acute gout in three urate lowering therapy trials.