# References

1 Geronikolou SA. Treatment of gout in a recently published 9th century manuscript of Rhazes. Vesalius. Winter. 2014;20(2):95-8. [pmid: 25739155].
2 Zhu Y, Pandya BJ, Choi HK. Prevalence of gout and hyperuricemia in the US general population: the National Health and Nutrition Examination Survey 2007-2008. Arthritis Rheum. Oct. 2011;63(10):3136-41. [pmid: 21800283].
3 Annemans L, Spaepen E, Gaskin M, et al. Gout in the UK and Germany: prevalence, comorbidities and management in general practice 2000-2005. Ann Rheum Dis. Jul. 2008;67(7):960-6. [pmid: 17981913].
4 Li C, Martin BC, Cummins DF, et al. Ambulatory resource utilization and cost for gout in United States. American Journal of Pharmacy Benefits. March/April. 2013;5(2):e46-e54.
5 Bhole V, de Vera M, Rahman MM, et al. Epidemiology of gout in women: Fifty-two-year followup of a prospective cohort. Arthritis Rheum. Apr. 2010;62(4):1069-76. [pmid: 20131266].
6 Shoji A, Yamanaka H, Kamatani N. A retrospective study of the relationship between serum urate level and recurrent attacks of gouty arthritis: evidence for reduction of recurrent gouty arthritis with antihyperuricemic therapy. Arthritis Rheum. Jun. 15. 2004;51(3):321-5. [pmid: 15188314].
7 De Miguel E, Puig JG, Castillo C, et al. Diagnosis of gout in patients with asymptomatic hyperuricaemia: A pilot ultrasound study. Ann Rheum Dis. January. 2012;71(1):157-8. [medline: 21953340]. http://dx.doi.org/10.1136/ard.2011.154997. [pmid: 21953340].
8 Singh JA, Reddy SG, Kundukulam J. Risk factors for gout and prevention: a systematic review of the literature. Curr Opin Rheumatol. Mar. 2011;23(2):192-202. [pmid: 21285714].
9 Diagnosis of Gout Protocol. Rockville, MD. Agency for Health Care Research and Quality, Effective Health Care Program. July. 17. 2014. http://effectivehealthcare.ahrq.gov/ehc/products/564/1937/gout-protocol-140716.pdf. July 17 2014.
10 Doghramji PP, Wortmann RL. Hyperuricemia and gout: new concepts in diagnosis and management. Postgrad Med. Nov. 2012;124(6):98-109. [pmid: 23322143].
11 Krishnan E, Akhras KS, Sharma H, et al. Serum urate and incidence of kidney disease among veterans with gout. J Rheumatol. Jul. 2013;40(7):1166-72. [pmid: 23678154].
12 Zhu Y, Pandya BJ, Choi HK. Comorbidities of gout and hyperuricemia in the US general population: NHANES 2007-2008. Am J Med. Jul. 2012;125(7):679-87 e1. [pmid: 22626509].
13 Perez-Ruiz F, Hernandez-Baldizon S, Herrero-Beites AM, et al. Risk factors associated with renal lithiasis during uricosuric treatment of hyperuricemia in patients with gout. Arthritis Care Res (Hoboken). Sep. 2010;62(9):1299-305. [pmid: 20506124].
14 Thompson GR, Duff IF, Robinson WD, et al. Long term uricosuric therapy in gout. Arthritis Rheum. Aug. 1962;5:384-96. [pmid: 13920871].
15 Wang Y, Yan S, Li C, et al. Risk factors for gout developed from hyperuricemia in China: a five-year prospective cohort study. Rheumatol Int. Mar. 2013;33(3):705-10. [pmid: 22544037].
16 Wang DD, Sievenpiper JL, de Souza RJ, et al. The effects of fructose intake on serum uric acid vary among controlled dietary trials. J Nutr. May. 2012;142(5):916-23. [pmid: 22457397].
17 Choi HK, Willett W, Curhan G. Fructose-rich beverages and risk of gout in women. JAMA. Nov. 24. 2010;304(20):2270-8. [pmid: 21068145].
18 Wang MY, Jiang XB, Wu WL, et al. A meta-analysis of alcohol consumption and the risk of gout. Clinical Rheumatology. Nov. 2013;32(11):1641-8. PMID:. WOS:000325809900011. [pmid: 23881436].
19 DeMarco M, Maynard J, Coresh J. Alcohol intake is associated with incident gout in ARIC. American Journal of Epidemiology. 1. SUPPL. 11. 2011;173:S57.
20 Choi HK, Curhan G. Coffee consumption and risk of incident gout in women: the Nurses' Health Study. Am J of Clin Nutr. Oct. 2010;92(4):922-7. PMID:. WOS:000282234100032. [pmid: 20739424].
21 Juraschek SP, Miller ER 3rd, Gelber AC. Effect of oral vitamin C supplementation on serum uric acid: a meta-analysis of randomized controlled trials. Arthritis Care Res (Hoboken). Sep. 2011;63(9):1295-306. [pmid: 21671418].
22 Aune D, Norat T, Vatten LJ. Body mass index and the risk of gout: a systematic review and dose-response meta-analysis of prospective studies. Eur J Nutr. Dec. 2014;53(8):1591-601. [pmid: 25209031].
23 Zhu Y, Zhang Y, Choi HK. The serum urate-lowering impact of weight loss among men with a high cardiovascular risk profile: the Multiple Risk Factor Intervention Trial. Rheumatology (Oxford). Dec. 2010;49(12):2391-9. [pmid: 20805117].
24 Lu N, Shai I, Zhang Y, et al. High-protein diet (Atkins Diet) and uric acid response. Arthritis Rheumatol. 2014:S71-s2.
25 Anderson A, Singh Jasvinder A. Pegloticase for chronic gout. Cochrane Database Syst Rev. John Wiley & Sons, Ltd. 2010.
26 Crittenden DB, Pillinger MH. New therapies for gout. Annu Rev Med. 2013;64:325-37. [pmid: 23327525].
27 Tayar Jean H, Lopez-Olivo Maria A, Suarez-Almazor Maria E. Febuxostat for treating chronic gout. Cochrane Database Syst Rev. John Wiley & Sons, Ltd. 2012.
28 Hamburger M, Baraf HSB, Adamson TC Jr, et al. 2011 recommendations for the diagnosis and management of gout and hyperuricemia. Physician and Sportsmedicine. November. 2011;39(4):98-123. [medline: 22293773]. http://dx.doi.org/10.3810/psm.2011.11.1946. [pmid: 22293773].
29 Zhang W, Doherty M, Pascual E, et al. EULAR evidence based recommendations for gout. Part I: Diagnosis. Report of a task force of the Standing Committee for International Clinical Studies Including Therapeutics (ESCISIT). Ann Rheum Dis. Oct. 2006;65(10):1301-11. [pmid: 16707533].
30 Glazebrook KN, Guimaraes LS, Murthy NS, et al. Identification of intraarticular and periarticular uric acid crystals with dual-energy CT: initial evaluation. Radiology. Nov. 2011;261(2):516-24. [pmid: 21926378].
31 Khanna D, Fitzgerald JD, Khanna PP, et al. 2012 American college of rheumatology guidelines for management of gout. part 1: Systematic nonpharmacologic and pharmacologic therapeutic approaches to hyperuricemia. Arthritis Care Res. 2012;64(10):1431-46.
32 Khanna D, Khanna PP, Fitzgerald JD, et al. 2012 American college of rheumatology guidelines for management of gout. part 2: Therapy and antiinflammatory prophylaxis of acute gouty arthritis. Arthritis Care Res. 2012;64(10):1447-61.
33 The University of Texas at Austin, School of Nursing, Family Nurse Practitioner Program. Management of chronic gout in adults. Austin (TX). University of Texas at Austin, School of Nursing. 2012. May.
34 The University of Texas at Austin, School of Nursing, Family Nurse Practitioner Program. Management of initial gout in adults. Austin (TX). University of Texas at Austin, School of Nursing. 2009. May.
35 Kahan JP, Park RE, Leape LL, et al. Variations by specialty in physician ratings of the appropriateness and necessity of indications for procedures. Med Care. Jun. 1996;34(6):512-23. [pmid: 8656718].
36 Garber AM, Browner WS. Cholesterol screening guidelines. Consensus, evidence, and common sense. Circulation. Mar. 18. 1997;95(6):1642-5. [pmid: 9118535].
37 Whitlock EP, Lin JS, Chou R, et al. Using existing systematic reviews in complex systematic reviews. Ann Intern Med. May. 20. 2008;148(10):776-82. [pmid: 18490690].
38 Higgins JP, Altman DG, Gotzsche PC, et al. The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. BMJ. 2011;343:d5928. [pmid: 22008217].
39 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
40 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2014. Chapters available at: www.effectivehealthcare.ahrq.gov.
41 Hill AB. The Environment and Disease: Association or Causation?. Proc R Soc Med. May. 1965;58:295-300. [pmid: 14283879].
42 Atkins D, Chang S, Gartlehner G, et al. Assessing the Applicability of Studies When Comparing Medical Interventions. Agency for Healthcare Research and Quality. December. 2010. Methods Guide for Comparative Effectiveness Reviews. AHRQ Publication No.11-EHC019-EF.
43 Wechalekar Mihir D, Vinik O, Schlesinger N, et al. Intra-articular glucocorticoids for acute gout. Cochrane Database Syst Rev. John Wiley & Sons, Ltd. 2013.
44 Moi John HY, Sriranganathan Melonie K, Edwards Christopher J, et al. Lifestyle interventions for acute gout. Cochrane Database Syst Rev. John Wiley & Sons, Ltd. 2013.
45 Janssens Hein J, Lucassen Peter LBJ, Van de Laar Floris A, et al. Systemic corticosteroids for acute gout. Cochrane Database Syst Rev. John Wiley & Sons, Ltd. 2008.
46 Daoussis D, Antonopoulos I, Andonopoulos AP. ACTH as a treatment for acute crystal-induced arthritis: Update on clinical evidence and mechanisms of action. Semin Arthritis Rheum. Apr. 2014;43(5):648-53. [pmid: 24762710].
47 Khanna PP, Gladue HS, Singh MK, et al. Treatment of acute gout: A systematic review. Semin Arthritis Rheum. 2014. Feb. 13. [pmid: 24650777].
48 Richette P, Bardin T. Colchicine for the treatment of gout. Expert Opin Pharmacother. Dec. 2010;11(17):2933-8. [pmid: 21050036].
49 Terkeltaub RA. Colchicine Update: 2008. Seminars in Arthritis and Rheumatism. Jun. 2009;38(6):411-9. PMID:. WOS:000267026600001. [pmid: 18973929].
50 van Echteld I, Wechalekar Mihir D, Schlesinger N, et al. Colchicine for acute gout. Cochrane Database Syst Rev. John Wiley & Sons, Ltd. 2014.
51 Wechalekar MD, Vinik O, Moi JHY, et al. The efficacy and safety of treatments for acute gout: Results from a series of systematic literature reviews including cochrane reviews on intraarticular glucocorticoids, colchicine, nonsteroidal antiinflammatory drugs, and interleukin-1 inhibitors. J Rheumatol. 2014;41(SUPPL. 92):15-25. [pmid: 24187110].
52 van Durme CM, Wechalekar MD, Buchbinder R, et al. Non-steroidal anti-inflammatory drugs for acute gout. Cochrane Database Syst Rev. 2014;9. CD010120. [pmid: 25225849].
53 Li T, Chen SL, Dai Q, et al. Etoricoxib versus indometacin in the treatment of Chinese patients with acute gouty arthritis: a randomized double-blind trial. Chin Med J (Engl). 2013;126(10):1867-71. [pmid: 23673101].
54 Zhang YK, Yang H, Zhang JY, et al. Comparison of intramuscular compound betamethasone and oral diclofenac sodium in the treatment of acute attacks of gout. Int J Clin Pract. May. 2014;68(5):633-8. [pmid: 24472084].
55 Karimzadeh H, Nazari J, Mottaghi P, et al. Different duration of colchicine for preventing recurrence of gouty arthritis. J Res Med Sci. 2006;11:104-7.
56 Almalki Z, Guo JJ, Kelton CM, et al. Adverse events associated with colchicine drug interactions: Analysis of the public version of the FDA adverse event reporting system. Value in Health. May. 2013;16(3):A218.
57 Singh J, Yang S, Foster J. The risk of aplastic anemia and pancytopenia with colchicine: A retrospective study of integrated health system database. Arthritis Rheumatol. October. SUPPL. 10. 2014;66:S20.
58 Tylor TH, Mecchella JN, Larson RJ, et al. Initiation of allopurinol at first medical contact for acute attacks of gout: a randomized clinical trial. Am J Med. Nov. 2012;125(11):1126-34 e7. [pmid: 23098865].
59 Ahern MJ, Reid C, Gordon TP, et al. Does colchicine work? The results of the first controlled study in acute gout. Aust N Z J Med. Jun. 1987;17(3):301-4. [pmid: 3314832].
60 Alloway JA, Moriarty MJ, Hoogland YT, et al. Comparison of triamcinolone acetonide with indomethacin in the treatment of acute gouty arthritis. J Rheumatol. Jan. 1993;20(1):111-3. [pmid: 8441139].
61 Altman RD, Honig S, Levin JM, et al. Ketoprofen versus indomethacin in patients with acute gouty arthritis: a multicenter, double blind comparative study. J Rheumatol. Sep. 1988;15(9):1422-6. [pmid: 3058974].
62 Axelrod D, Preston S. Comparison of parenteral adrenocorticotropic hormone with oral indomethacin in the treatment of acute gout. Arthritis Rheum. Jun. 1988;31(6):803-5. [pmid: 2454635].
63 Borstad GC, Bryant LR, Abel MP, et al. Colchicine for prophylaxis of acute flares when initiating allopurinol for chronic gouty arthritis. J Rheumatol. Dec. 2004;31(12):2429-32. [pmid: 15570646].
64 Butler RC, Goddard DH, Higgens CS, et al. Double-blind trial of flurbiprofen and phenylbutazone in acute gouty arthritis. Br J Clin Pharmacol. Nov. 1985;20(5):511-3. [pmid: 3907678].
65 Cheng TT, Lai HM, Chiu CK, et al. A single-blind, randomized, controlled trial to assess the efficacy and tolerability of rofecoxib, diclofenac sodium, and meloxicam in patients with acute gouty arthritis. Clin Ther. Mar. 2004;26(3):399-406. [pmid: 15110132].
66 Chou CT, Kuo SC. The anti-inflammatory and anti-hyperuricemic effects of Chinese herbal formula danggui-nian-tong-tang on acute gouty arthritis: a comparative study with indomethacin and allopurinol. Am J Chin Med. 1995;23(3-4):261-71. [pmid: 8571922].
67 Douglas G, Thompson M. A comparison of phenylbutazone and flufenamic acid in the treatment of acute gout. Ann Phys Med. May. 1970;10(6):275-80. [pmid: 4913482].
68 Eberl R, Dunky A. Meclofenamate sodium in the treatment of acute gout. Results of a double-blind study. Arzneimittelforschung. 1983;33(4A):641-3. [pmid: 6349648].
69 Bakris GL, Doghramji PP, Keenan RT, et al. CaseBook Challenges: Managing Gout, Hyperuricemia and Comorbidities-Dialogue with the Experts. American Journal of Medicine. 2013.
70 Lederman R. A double-blind comparison of etodolac and high doses of naproxen in the treatment of acute gout. Adv Ther. 1990;7:344-54.
71 Lomen PL, Turner LF, Lamborn KR, et al. Flurbiprofen in the treatment of acute gout. A comparison with indomethacin. Am J Med. Mar. 24. 1986;80(3A):134-9. [pmid: 3963020].
72 Maccagno A, Di Giorgio E, Romanowicz A. Effectiveness of etodolac (‘Lodine’) compared with naproxen in patients with acute gout. Current Medical Research and Opinion. 1991. 1991;12(7):423-9. [medline: 1838075]. [pmid: 1838075].
73 Man CY, Cheung IT, Cameron PA, et al. Comparison of oral prednisolone/paracetamol and oral indomethacin/paracetamol combination therapy in the treatment of acute goutlike arthritis: a double-blind, randomized, controlled trial. Ann Emerg Med. May. 2007;49(5):670-7. [pmid: 17276548].
74 Paulus HE, Schlosstein LH, Godfrey RG, et al. Prophylactic colchicine therapy of intercritical gout. A placebo-controlled study of probenecid-treated patients. Arthritis Rheum. Sep-Oct. 1974;17(5):609-14. [pmid: 4606955].
75 Rubin BR, Burton R, Navarra S, et al. Efficacy and safety profile of treatment with etoricoxib 120 mg once daily compared with indomethacin 50 mg three times daily in acute gout: a randomized controlled trial. Arthritis Rheum. Feb. 2004;50(2):598-606. [pmid: 14872504].
76 Ruotsi A, Vainio U. Treatment of acute gouty arthritis with proquazone and indomethacin. A comparative, double-blind trial. Scand J Rheumatol Suppl. 1978;(21):15-7. [pmid: 356235].
77 Schlesinger N, Detry MA, Holland BK, et al. Local ice therapy during bouts of acute gouty arthritis. J Rheumatol. Feb. 2002;29(2):331-4. [pmid: 11838852].
78 Schumacher HR Jr., Boice JA, Daikh DI, et al. Randomised double blind trial of etoricoxib and indometacin in treatment of acute gouty arthritis. BMJ. Jun. 22. 2002;324(7352):1488-92. [pmid: 12077033].
79 Schumacher HR, Berger MF, Li-Yu J, et al. Efficacy and Tolerability of Celecoxib in the Treatment of Acute Gouty Arthritis: A Randomized Controlled Trial. J Rheumatol. Sep. 2012;39(9):1859-66. PMID:. WOS:000308774000018. [pmid: 22859357].
80 Shi XD, Li GC, Qian ZX, et al. Randomized and controlled clinical study of modified prescriptions of Simiao Pill in the treatment of acute gouty arthritis. Chin J Integr Med. Mar. 2008;14(1):17-22. [pmid: 18219456].
81 Shrestha M, Morgan DL, Moreden JM, et al. Randomized double-blind comparison of the analgesic efficacy of intramuscular ketorolac and oral indomethacin in the treatment of acute gouty arthritis. Ann Emerg Med. Dec. 1995;26(6):682-6. [pmid: 7492036].
82 Siegel LB, Alloway JA, Nashel DJ. Comparison of adrenocorticotropic hormone and triamcinolone acetonide in the treatment of acute gouty arthritis. J Rheumatol. Jul. 1994;21(7):1325-7. [pmid: 7966077].
83 Siegmeth W, Placheta P. Double-blind trial: ketoprofen versus phenylbutazone in acute gouty arthritis (author's transl). Wien Klin Wochenschr. Sep. 3. 1976;88(16):535-7. [pmid: 793186].
84 Terkeltaub RA, Furst DE, Bennett K, et al. High versus low dosing of oral colchicine for early acute gout flare: Twenty-four-hour outcome of the first multicenter, randomized, double-blind, placebo-controlled, parallel-group, dose-comparison colchicine study. Arthritis Rheum. Apr. 2010;62(4):1060-8. [pmid: 20131255].
85 Tumrasvin T, Deesomchok U. Piroxicam in treatment of acute gout high dose versus low dose. J Med Assoc Thai. Mar. 1985;68(3):111-6. [pmid: 3894554].
86 Valdes EF. Use of tenoxicam in patients with acute gouty arthritis. Eur J Rheumatol Inflamm. 1987;9(2):133-6. [pmid: 3329106].
87 Weiner GI, White SR, Weitzner RI, et al. Double-blind study of fenoprofen versus phenylbutazone in acute gouty arthritis. Arthritis Rheum. Apr. 1979;22(4):425-6. [pmid: 371630].
88 Zhou L, Xu QF, Zhang WS. Comparative observation of therapeutic effects of acupuncture combined with infrared irradiation and western medicine on acute gouty arthritis. World Journal of Acupuncture - Moxibustion. 2012:30-4.
89 Torre Gdl. A comparative, double-blind, parallel study with tenoxicam vs placebo in acute in acute gouty arthritis. Invest Med Int. 1987;14:92-7.
90 Ofman JJ, MacLean CH, Straus WL, et al. A metaanalysis of severe upper gastrointestinal complications of nonsteroidal antiinflammatory drugs. J Rheumatol. Apr. 2002;29(4):804-12. [pmid: 11950025].
91 Ofman JJ, Maclean CH, Straus WL, et al. Meta-analysis of dyspepsia and nonsteroidal antiinflammatory drugs. Arthritis Rheum. Aug. 15. 2003;49(4):508-18. [pmid: 12910557].
92 Gabriel SE, Jaakkimainen L, Bombardier C. Risk for serious gastrointestinal complications related to use of nonsteroidal anti-inflammatory drugs. A meta-analysis. Ann Intern Med. Nov. 15. 1991;115(10):787-96. [pmid: 1834002].
93 Choi TY, Kim TH, Kang JW, et al. Moxibustion for rheumatic conditions: A systematic review and meta-analysis. Clinical Rheumatology. July. 2011;30(7):937-45. [medline: 21331532]. [pmid: 21331532].
94 Lee WB, Woo SH, Min BI, et al. Acupuncture for gouty arthritis: a concise report of a systematic and meta-analysis approach. Rheumatology (Oxford). Jul. 2013;52(7):1225-32. [pmid: 23424263].
95 Li XX, Han M, Wang YY, et al. Chinese herbal medicine for gout: a systematic review of randomized clinical trials. Clin Rheumatol. Jul. 2013;32(7):943-59. [pmid: 23666318].
96 Zhou L, Liu L, Liu X, et al. Systematic review and meta-analysis of the clinical efficacy and adverse effects of Chinese herbal decoction for the treatment of gout. PLoS One. 2014;9(1):e85008. [pmid: 24465466].
97 Dalbeth N, Chen P, White M, et al. Impact of bariatric surgery on serum urate targets in people with morbid obesity and diabetes: a prospective longitudinal study. Ann Rheum Dis. May. 1. 2014;73(5):797-802. [pmid: 24255548].
98 Neogi T, Chen C, Niu J, et al. Alcohol Quantity and Type on Risk of Recurrent Gout Attacks: An Internet-based Case-crossover Study. Am J Med. Apr. 2014;127(4):311-8. [pmid: 24440541].
99 Zhang Y, Chen C, Choi H, et al. Purine-rich foods intake and recurrent gout attacks. Ann Rheum Dis. Sep. 2012;71(9):1448-53. [pmid: 22648933].
100 Zhang Y, Neogi T, Chen C, et al. Cherry consumption and decreased risk of recurrent gout attacks. Arthritis Rheum. Dec. 2012;64(12):4004-11. [pmid: 23023818].
101 Zhang Y, Woods R, Chaisson CE, et al. Alcohol consumption as a trigger of recurrent gout attacks. Am J Med. Sep. 2006;119(9):800 e13-8. [pmid: 16945617].
102 Dalbeth N, Ames R, Gamble GD, et al. Effects of skim milk powder enriched with glycomacropeptide and G600 milk fat extract on frequency of gout flares: a proof-of-concept randomised controlled trial. Ann Rheum Dis. Jun. 2012;71(6):929-34. [pmid: 22275296].
103 Zeng YC, Huang SF, Mu GP, et al. Effects of adjusted proportional macronutrient intake on serum uric acid, blood lipids, renal function, and outcome of patients with gout and overweight. Chinese Journal of Clinical Nutrition. August. 2012;20(4):210-4. http://dx.doi.org/10.3760/cma.j.issn.1674-635X.2012.04.004.
104 Stamp LK, O'Donnell JL, Frampton C, et al. Clinically insignificant effect of supplemental vitamin C on serum urate in patients with gout: a pilot randomized controlled trial. Arthritis Rheum. Jun. 2013;65(6):1636-42. [pmid: 23681955].
105 Zhang SJ, Liu JP, He KQ. Treatment of acute gouty arthritis by blood-letting cupping plus herbal medicine. J Tradit Chin Med. Mar. 2010;30(1):18-20. [pmid: 20397456].
106 Holland R, McGill NW. Comprehensive dietary education in treated gout patients does not further improve serum urate. Intern Med J. Feb. 2015;45(2):189-94. [pmid: 25495503].
107 Wang Y, Wang L, Li E, et al. Chuanhu anti-gout mixture versus colchicine for acute gouty arthritis: a randomized, double-blind, double-dummy, non-inferiority trial. Int J Med Sci. 2014;11(9):880-5. [pmid: 25013367].
108 Feng WM, Luo J. Ginger cake separated moxibustion treatment for acute gouty arthritis of 33 cases. J Clin Acupunct Moxibustion. 2003;19:39-40.
109 Seth R, Kydd AS, Buchbinder R, et al. Allopurinol for chronic gout. Cochrane Database Syst Rev. 2014;10. CD006077. [pmid: 25314636].
110 Ye P, Yang S, Zhang W, et al. Efficacy and tolerability of febuxostat in hyperuricemic patients with or without gout: a systematic review and meta-analysis. Clin Ther. Feb. 2013;35(2):180-9. [pmid: 23332451].
111 Saag KG, Becker MA, Whelton A, et al. Effect of febuxostat on serum urate levels in gout subjects with hyperuricemia and moderate-to-severe renal impairment: A randomized controlled trial. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S498-S9.
112 Goldfarb DS, MacDonald PA, Hunt B, et al. Febuxostat in gout: serum urate response in uric acid overproducers and underexcretors. J Rheumatol. Jul. 2011;38(7):1385-9. [pmid: 21572152].
113 Chohan S, Becker MA, MacDonald PA, et al. Women with gout: efficacy and safety of urate-lowering with febuxostat and allopurinol. Arthritis Care Res (Hoboken). Feb. 2012;64(2):256-61. [pmid: 22052584].
114 Faruque LI, Ehteshami-Afshar A, Wiebe N, et al. A systematic review and meta-analysis on the safety and efficacy of febuxostat versus allopurinol in chronic gout. Semin Arthritis Rheum. Dec. 2013;43(3):367-75. [pmid: 24326033].
115 Manara M, Bortoluzzi A, Favero M, et al. Italian Society of Rheumatology recommendations for the management of gout. Reumatismo. 2013;65(1):4-21. [pmid: 23550256].
116 Castrejon I, Toledano E, Rosario MP, et al. Safety of allopurinol compared with other urate-lowering drugs in patients with gout: a systematic review and meta-analysis. Rheumatol Int. 2014. Dec. 18. [pmid: 25519877].
117 van Echteld IA, van Durme C, Falzon L, et al. Treatment of gout patients with impairment of renal function: a systematic literature review. J Rheumatol Suppl. Sep. 2014;92:48-54. [pmid: 25180128].
118 Becker MA, Schumacher HR Jr., Wortmann RL, et al. Febuxostat compared with allopurinol in patients with hyperuricemia and gout. N Engl J Med. Dec. 8. 2005;353(23):2450-61. [pmid: 16339094].
119 Schumacher HR Jr, Becker MA, Wortmann RL, et al. Effects of febuxostat versus allopurinol and placebo in reducing serum urate in subjects with hyperuricemia and gout: A 28-week, phase III, randomized, double-blind, parallel-group trial. Arthritis Care Res. 2008;59(11):1540-8.
120 Becker MA, Schumacher HR, Espinoza LR, et al. The urate-lowering efficacy and safety of febuxostat in the treatment of the hyperuricemia of gout: the CONFIRMS trial. Arthritis Res Ther. 2010;12(2):R63. [pmid: 20370912].
121 Becker MA, Schumacher HR, MacDonald PA, et al. Clinical Efficacy and Safety of Successful Longterm Urate Lowering with Febuxostat or Allopurinol in Subjects with Gout. J Rheumatol. Jun. 2009;36(6):1273-82. PMID:. WOS:000266891500030. [pmid: 19286847].
122 Huang X, Du H, Gu J, et al. An allopurinol-controlled, multicenter, randomized, double-blind, parallel between-group, comparative study of febuxostat in Chinese patients with gout and hyperuricemia. Int J Rheum Dis. 2014. Jan. 28. [pmid: 24467549].
123 Ramasamy SN, Korb-Wells CS, Kannangara DR, et al. Allopurinol hypersensitivity: a systematic review of all published cases, 1950-2012. Drug Saf. Oct. 2013;36(10):953-80. [pmid: 23873481].
124 Bardin T, Chales G, Pascart T, et al. Is the rate of skin reactions to febuxostat increased in patients with a history of skin intolerance to allopurinol? A retrospective, hospital-based study involving 101 patients consecutively treated with allopurinol and febuxostat. Arthritis Rheumatol. October. SUPPL. 10. 2014;66:S68.
125 Guy C, Lebrun-Vignes B, Jean-Pastor MJ. Drug-induced toxic epidermal necrolysis and Stevens-Johnson syndrome: Analysis of the French national pharmacovigilance database. Fundamental and Clinical Pharmacology. May. SUPPL. 1. 2014;28:65. [pmid: 22913740].
126 Ko TM, Wu JY, Chen YT, et al. A prospective study of HLAnullB-5801 genotyping in preventing allopurinol-induced severe cutaneous adverse reactions. Clinical and Translational Allergy. 18. SUPPL. 3. 2014;4:2. [pmid: 24405811].
127 Singh JA, Yang S, Foster J. Increased risk of skin reactions with gout medications: An analysis of va databases. Arthritis Rheumatol. October. SUPPL. 10. 2014;66:S71.
128 Chung WH, Chang WC, Stocker SL, et al. Insights into the poor prognosis of allopurinol-induced severe cutaneous adverse reactions: the impact of renal insufficiency, high plasma levels of oxypurinol and granulysin. Ann Rheum Dis. 2014. Aug. 12. [pmid: 25115449].
129 Lupton GP, Odom RB. The allopurinol hypersensitivity syndrome. J Am Acad Dermatol. Oct. 1979;1(4):365-74. [pmid: 159913].
130 Kumar A, Edward N, White MI, et al. Allopurinol, erythema multiforme, and renal insufficiency. BMJ. Jan. 20. 1996;312(7024):173-4. [pmid: 8563541].
131 Chen IH, Kuo MC, Hwang SJ, et al. Allopurinol-induced severe hypersensitivity with acute renal failure. Kaohsiung J Med Sci. May. 2005;21(5):228-32. [pmid: 15960069].
132 Hande KR, Noone RM, Stone WJ. Severe allopurinol toxicity. Description and guidelines for prevention in patients with renal insufficiency. Am J Med. Jan. 1984;76(1):47-56. [pmid: 6691361].
133 Lee MH, Stocker SL, Anderson J, et al. Initiating allopurinol therapy: do we need to know the patient's human leucocyte antigen status?. Internal Medicine Journal. Apr. 2012;42(4):411-6. PMID:. WOS:000302796000017. [pmid: 21790926].
134 Schumacher HR, Becker MA, Lloyd E, et al. Febuxostat in the treatment of gout: 5-yr findings of the FOCUS efficacy and safety study. Rheumatology. Feb. 2009;48(2):188-94. PMID:. WOS:000262518500020. [pmid: 19141576].
135 Yaylaci S, Demir MV, Temiz T, et al. Allopurinol-induced DRESS syndrome. Indian J Pharmacol. May. 2012;44(3):412-4. [pmid: 22701258].
136 Kamatani N, Fujimori S, Hada T, et al. Multicenter, open-label study of long-term administration of febuxostat (TMX-67) in Japanese patients with hyperuricemia including gout. J Clin Rheumatol. Jun. 2011;17(4 Suppl 2):S50-6. [pmid: 21654270].
137 Weiss KM, Jain R, Wells C, et al. A case of allopurinol-induced dress syndrome in a patient withasymptomatic gout. Annals of Allergy, Asthma and Immunology. November. 2011;107(5 SUPPL. 1):A26.
138 Ibie NC, Alper AB. She is all dressed up: A case of allopurinol deadly complication. Journal of Investigative Medicine. February. 2014;62(2):504-5.
139 Chaudrey K, Khan M, Madhoun M, et al. Allopurinol-induced dress syndrome: A reversible fatality. American Journal of Gastroenterology. October. SUPPL. 1. 2013;108:S153.
140 Becker MA, Fitz-Patrick D, Storgard C, et al. A large-scale, multicenter, prospective, open-label, 6-month study to evaluate the safety of allopurinol monotherapy in patients with gout. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S502-S3.
141 Tassaneeyakul W, Jantararoungtong T, Chen P, et al. Strong association between HLA-B*5801 and allopurinol-induced Stevens-Johnson syndrome and toxic epidermal necrolysis in a Thai population. Pharmacogenet Genomics. Sep. 2009;19(9):704-9. [pmid: 19696695].
142 Gilchrist MJ, Hebert B. Drug reaction with eosinophilia and systemic symptoms (DRESS). Journal of General Internal Medicine. May. SUPPL. 1. 2011;26:S423.
143 Stamp LK, Taylor WJ, Jones PB, et al. Starting dose is a risk factor for allopurinol hypersensitivity syndrome: a proposed safe starting dose of allopurinol. Arthritis Rheum. Aug. 2012;64(8):2529-36. [pmid: 22488501].
144 Kydd AS, Seth R, Buchbinder R, et al. Uricosuric medications for chronic gout. Cochrane Database Syst Rev. 2014;11. CD010457. [pmid: 25392987].
145 Scott JT. Comparison of allopurinol and probenecid. Ann Rheum Dis. Nov. 1966;25(6 Suppl):623-6. [pmid: 5335059].
146 Latourte A, Bardin T, Richette P. Prophylaxis for acute gout flares after initiation of urate-lowering therapy. Rheumatology (Oxford). 2014. Apr. 23. [pmid: 24758886].
147 Seth R, Kydd AS, Falzon L, et al. Preventing attacks of acute gout when introducing urate-lowering therapy: a systematic literature review. J Rheumatol Suppl. Sep. 2014;92:42-7. [pmid: 25180127].
148 Wortmann RL, Macdonald PA, Hunt B, et al. Effect of prophylaxis on gout flares after the initiation of urate-lowering therapy: analysis of data from three phase III trials. Clin Ther. Dec. 2010;32(14):2386-97. [pmid: 21353107].
149 Becker MA, Schumacher HR Jr., Wortmann RL, et al. Febuxostat, a novel nonpurine selective inhibitor of xanthine oxidase: a twenty-eight-day, multicenter, phase II, randomized, double-blind, placebo-controlled, dose-response clinical trial examining safety and efficacy in patients with gout. Arthritis Rheum. Mar. 2005;52(3):916-23. [pmid: 15751090].
150 Kamatani N, Fujimori S, Hada T, et al. An allopurinol-controlled, randomized, double-dummy, double-blind, parallel between-group, comparative study of febuxostat (TMX-67), a non-purine-selective inhibitor of xanthine oxidase, in patients with hyperuricemia including those with gout in Japan: phase 3 clinical study. J Clin Rheumatol. Jun. 2011;17(4 Suppl 2):S13-8. [pmid: 21654265].
151 Singal KK, Goyal S, Gupta P, et al. Comparison between Allopurinol and Febuxostat in management of gout patients - A prospective study. Bangladesh Journal of Medical Science. 2011. 2011;10(4):257-9.
152 Whelton A, Becker MA, MacDonald P, et al. Gout subjects with hyperuricemia and renal impairment treated with febuxostat or allopurinol for 6 months. International Journal of Rheumatic Diseases. 2010;13:172-7.
153 Naoyuki K, Shin F, Toshikazu H, et al. An allopurinol-controlled, multicenter, randomized, open-label, parallel between-group, comparative study of febuxostat (TMX-67), a non-purine-selective inhibitor of xanthine oxidase, in patients with hyperuricemia including those with gout in Japan: phase 2 exploratory clinical study. J Clin Rheumatol. Jun. 2011;17(4 Suppl 2):S44-9. [pmid: 21654269].
154 Becker MA, MacDonald PA, Hunt B, et al. Treating hyperuricemia of gout: safety and efficacy of febuxostat and allopurinol in older versus younger subjects. Nucleosides Nucleotides Nucleic Acids. Dec. 2011;30(12):1011-7. [pmid: 22132950].
155 Becker MA, MacDonald PA, Hunt BJ, et al. Diabetes and gout: efficacy and safety of febuxostat and allopurinol. Diabetes Obes Metab. Nov. 2013;15(11):1049-55. [pmid: 23683134].
156 Jackson RL, Hunt B, MacDonald PA. The efficacy and safety of febuxostat for urate lowering in gout patients >/=65 years of age. BMC Geriatr. 2012;12:11. [pmid: 22436129].
157 Wells AF, MacDonald PA, Chefo S, et al. African American patients with gout: efficacy and safety of febuxostat vs allopurinol. BMC Musculoskelet Disord. 2012;13:15. [pmid: 22316106].
158 Gibson T, Rodgers V, Potter C, et al. Allopurinol treatment and its effect on renal function in gout: a controlled study. Ann Rheum Dis. Feb. 1982;41(1):59-65. [pmid: 7039523].
159 Rundles RW, Metz EN, Silberman HR. Allopurinol in the treatment of gout. Ann Intern Med. Feb. 1966;64(2):229-58. [pmid: 5322938].
160 Hollingworth P, Reardon JA, Scott JT. Acute gout during hypouricaemic therapy: prophylaxis with colchicine. Ann Rheum Dis. Oct. 1980;39(5):529. [pmid: 7436588].
161 Zhang W, Doherty M, Bardin T, et al. EULAR evidence based recommendations for gout. Part II: Management. Report of a task force of the EULAR standing committee for international clinical studies including therapeutics (ESCISIT). Ann Rheum Dis. Oct. 2006;65(10):1312-24. PMID:. WOS:000240508600009. [pmid: 16707532].
162 De Vera M, Rai S, Bhole V. Medication adherence in patients with gout: A systematic review. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S85.
163 Zandman-Goddard G, Amital H, Shamrayevsky N, et al. Rates of adherence and persistence with allopurinol therapy among gout patients in Israel. Rheumatology (Oxford). Jun. 2013;52(6):1126-31. [pmid: 23392592].
164 Martini N, Bryant L, Karu LT, et al. Living With Gout in New Zealand An Exploratory Study Into People's Knowledge About the Disease and Its Treatment. Jcr-Journal of Clinical Rheumatology. Apr. 2012;18(3):125-9. PMID:. WOS:000302141900003. [pmid: 22426580].
165 Silva L, Miguel ED, Peiteado D, et al. Compliance in gout patients. Acta Reumatol Port. Oct-Dec. 2010;35(5):466-74. [pmid: 21245815].
166 Harrold LR, Andrade SE, Briesacher B, et al. The dynamics of chronic gout treatment: medication gaps and return to therapy. Am J Med. Jan. 2010;123(1):54-9. [pmid: 20102992].
167 Harrold LR, Andrade SE, Briesacher BA, et al. Adherence with urate-lowering therapies for the treatment of gout. Arthritis Res Ther. 2009;11(2):R46. [pmid: 19327147].
168 Halpern R, Mody RR, Fuldeore MJ, et al. Impact of noncompliance with urate-lowering drug on serum urate and gout-related healthcare costs: administrative claims analysis. Curr Med Res Opin. Jul. 2009;25(7):1711-9. [pmid: 19485724].
169 Riedel AA, Nelson M, Joseph-Ridge N, et al. Compliance with allopurinol therapy among managed care enrollees with gout: a retrospective analysis of administrative claims. J Rheumatol. Aug. 2004;31(8):1575-81. [pmid: 15290738].
170 Rascati K, Prasla K, Park H, et al. Evaluation of healthcare costs for patients with gout by serum uric acid. Arthritis and Rheumatism. 2011;63(10):2011-11.
171 Dalbeth N, House ME, Horne A, et al. Prescription and dosing of urate-lowering therapy, rather than patient behaviours, are the key modifiable factors associated with targeting serum urate in gout. BMC Musculoskelet Disord. 2012;13:174. [pmid: 22978848].
172 Dalbeth N, Petrie KJ, House M, et al. Illness perceptions in patients with gout and the relationship with progression of musculoskeletal disability. Arthritis Care Res (Hoboken). Nov. 2011;63(11):1605-12. [pmid: 22034122].
173 Singh JA, Hodges JS, Asch SM. Opportunities for improving medication use and monitoring in gout. Ann Rheum Dis. Aug. 2009;68(8):1265-70. PMID:. WOS:000268010500006. [pmid: 18701554].
174 Sarawate CA, Brewer KK, Yang W, et al. Gout medication treatment patterns and adherence to standards of care from a managed care perspective. Mayo Clin Proc. Jul. 2006;81(7):925-34. [pmid: 16835972].
175 Solomon DH, Avorn J, Levin R, et al. Uric acid lowering therapy: prescribing patterns in a large cohort of older adults. Ann Rheum Dis. May. 2008;67(5):609-13. [pmid: 17728328].
176 Briesacher BA, Andrade SE, Fouayzi H, et al. Comparison of drug adherence rates among patients with seven different medical conditions. Pharmacotherapy. Apr. 2008;28(4):437-43. [pmid: 18363527].
177 de Klerk E, van der Heijde D, Landewe R, et al. Patient compliance in rheumatoid arthritis, polymyalgia rheumatica, and gout. J Rheumatol. Jan. 2003;30(1):44-54. [pmid: 12508389].
178 Deyo RA, Inui TS, Sullivan B. Noncompliance with arthritis drugs: magnitude, correlates, and clinical implications. J Rheumatol. Nov-Dec. 1981;8(6):931-6. [pmid: 7328568].
179 Andres M, Sivera F, Falzon L, et al. Treatment target and followup measures for patients with gout: a systematic literature review. J Rheumatol Suppl. Sep. 2014;92:55-62. [pmid: 25180129].
180 Wu EQ, Patel PA, Mody RR, et al. Frequency, risk, and cost of gout-related episodes among the elderly: does serum uric acid level matter?. J Rheumatol. May. 2009;36(5):1032-40. [pmid: 19369467].
181 Halpern R, Fuldeore MJ, Mody RR, et al. The effect of serum urate on gout flares and their associated costs: an administrative claims analysis. J Clin Rheumatol. Feb. 2009;15(1):3-7. [pmid: 19125135].
182 Becker MA, MacDonald PA, Hunt BJ, et al. Determinants of the clinical outcomes of gout during the first year of urate-lowering therapy. Nucleosides Nucleotides Nucleic Acids. Jun. 2008;27(6):585-91. [pmid: 18600509].
183 Sarawate CA, Patel PA, Schumacher HR, et al. Serum urate levels and gout flares: analysis from managed care data. J Clin Rheumatol. Apr. 2006;12(2):61-5. [pmid: 16601538].
184 Hamburger MI, Tesser JRP, Skosey JL, et al. Patterns of gout treatment and related outcomes in us community rheumatology practices: The relation between gout flares, time in treatment, serum uric acid level and urate lowering therapy. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S808-S9.
185 Khanna PP, Baumgartner S, Khanna D, et al. Assessing SUA, flare rates, and Tophi in patients with gout treated xanthine oxidase inhibitors in the United States. Ann Rheum Dis. 2013;72(3):2013-06.
186 Zleik N, Michet CJ, Khun H, et al. The risk of subsequent attacks in patients with incident gout: A population-based study. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S853.
187 Martini N, Bryant L, Te Karu L, et al. Living with gout in New Zealand: an exploratory study into people's knowledge about the disease and its treatment. J Clin Rheumatol. Apr. 2012;18(3):125-9. [pmid: 22426580].
188 Park H, Rascati KL, Prasla K, et al. Evaluation of health care costs and utilization patterns for patients with gout. Clin Ther. Mar. 2012;34(3):640-52. [pmid: 22381710].
189 Bongartz T, Zleik N, Clement M, et al. The risk of future attacks in patients with incident gout: A population-based. Ann Rheum Dis. 2013;72(3):2013-06.
190 Perez-Ruiz F, Herrero-Beites AM, Carmona L. A two-stage approach to the treatment of hyperuricemia in gout: the “dirty dish” hypothesis. Arthritis Rheum. Dec. 2011;63(12):4002-6. [pmid: 21898351].
191 Loebl WY, Scott JT. Withdrawal of allopurinol in patients with gout. Ann Rheum Dis. Jul. 1974;33(4):304-7. [pmid: 4416909].
192 Perez-Ruiz F, Atxotegi J, Hernando I, et al. Using serum urate levels to determine the period free of gouty symptoms after withdrawal of long-term urate-lowering therapy: a prospective study. Arthritis Rheum. Oct. 15. 2006;55(5):786-90. [pmid: 17013833].
193 Bull PW, Scott JT. Intermittent control of hyperuricemia in the treatment of gout. J Rheumatol. Sep. 1989;16(9):1246-8. [pmid: 2681764].
194 Kuo CF, Grainge MJ, Mallen C, et al. Eligibility for and prescription of urate-lowering treatment in patients with incident gout in England. JAMA. Dec. 24-31. 2014;312(24):2684-6. [pmid: 25536262].