# Methods

## Criteria for Inclusion/Exclusion of Studies in the Review

Included studies are limited to those that fit the PICOTS (below).

Studies in any clinical setting were included as long as they satisfied all other inclusion/exclusion criteria. The results of the report are intended for primary care and acute care settings, and therefore primary and acute settings are preferred. Case reports were excluded.

Studies were not limited by language. For studies of efficacy and effectiveness, we endeavored to include only randomized controlled trials. However, in the absence of relevant randomized controlled trials, observational studies were included. Observational studies were also included if they reported rare adverse events. Existing systematic reviews were also included both as sources of original data (reference mining) and for their conclusions, following the methods proposed by Whitlock and colleagues.37

### PICOTS

- Population(s)
  ○ Adults (≥18 years of age) diagnosed with gout
    ■ Subgroups
      - Male and female patients (KQ1-5)
      - Patients presenting with an acute episode (KQ1, 2, 5) and those with a history of gout (KQ1-5)
      - Patients with higher versus lower serum UA (e.g., <5 vs. ≥5) (KQ1-5)
      - Patients who are HLA-B*5801-positive (KQ1) (HLA-B*5801 has been associated with an increased risk of allopurinol toxicity)
      - Older (≥65) versus younger patients (KQ1-5)
      - Tophaceous and non-tophaceous gout patients (KQ1-5)
      - Patients with comorbidities, including hypertension, Type 2 diabetes, chronic kidney disease (CKD) (renal insufficiency: CKD 1-4) (KQ1-5)
- Interventions
  ○ Dietary interventions (KQ2, 4)
    ■ Low purine diet
    ■ Fructose restriction, other carbohydrate restriction
    ■ Ethanol restriction
    ■ Sour cherry juice (proposed to be a XOI)
    ■ Dairy products and vegetables
    ■ Mediterranean diet
    ■ DASH (Dietary Approaches to Stop Hypertension) diet
  ○ Other Lifestyle Measures (KQ2, 4)
    ■ Exercise
    ■ Hydration
  ○ Dietary supplements and other alternative treatments (KQ2, 4)
    ■ Vitamin C
    ■ Traditional Chinese Medicine (acupuncture or Chinese herbal remedies: Ermiao wan, Meadow saffron, Dandelion, Burdock root; Huzhang gout granule; Jinhuang ointment; Yinlian gout granule, Si Miao San, Gout chi)
  ○ Pharmacologic agents
    ■ Acute gout treatment (KQ1, 4, 5b)
      - Anti-inflammatories (NSAIDS, corticosteroids [intra-articular and/or oral])
      - Microtubule inhibitors (colchicine)
      - Combination therapy (colchicine and NSAIDS/ oral corticosteroids; intra-articular corticosteroids/anti-inflammatories)
    ■ Urate Lowering Therapies (KQ3, 5a)
      - Xanthine oxidase inhibitors (XOIs: allopurinol, febuxostat) (KQ3, 5)
      - Uricosuric agents (probenecid) (KQ3, 5a)
    ■ Combination medications
      - Probenecid/colchicine (KQ3)
      - XOIs/anti-inflammatories (KQ3)
    ■ Co-interventions (KQ3-5)
      - Included pharmacologic agents plus included diet and life style measures (KQ2, 3,4)
      - Included pharmacologic agents and included Traditional Chinese Medicine interventions
- Comparators
  ○ Placebo or usual care (KQ 1, 3-5)
  ○ Active comparators (that are included interventions) (KQ1, 3-5)
  ○ Usual diet or level of activity or other dietary changes or dietary supplements that are included interventions (KQ2)
  ○ Early initiation of treatment (KQ 1, 2, 3)
- Outcomes:
  ○ For acute gout treatment (KQ1)
    ■ Efficacy
      - Short-term health outcomes (days following acute flare)
        ○ Pain
        ○ Joint swelling, tenderness
      - Longer-term health outcomes:
        ○ sUA
        ○ Pain
        ○ Joint swelling, tenderness
        ○ Activities of daily living (ADLs)
        ○ Patient global assessment
        ○ Recurrence
    ■ Safety
      - Gastrointestinal and renal side effects (NSAIDS, colchicine)
      - Steroid induced osteoporosis, diabetes
  ○ For diet and other lifestyle therapy (KQ2)
    ■ Efficacy
      - Intermediate outcomes: serum and/or urine uric acid
      - Final health outcomes: recurrence and outcomes listed for pharmacologic treatments
    ■ Harms
  ○ For chronic gout treatment (uric acid lowering therapy), monitoring, and discontinuation (KQ3-5)
    ■ Efficacy:
      - Intermediate outcomes: sUA
      - Final health outcomes: pain, joint swelling, tenderness associated with the development of tophi, ADLs, patient global assessment, risk for comorbidities/mortality, recurrence of gout attacks (flares)
    ■ Safety
      - Inflammatory effects, including skin rash
      - Hematologic effects
      - Cardiovascular effects
      - Liver dysfunction
      - Renal dysfunction
  ○ For anti-inflammatory prophylaxis with ULT therapy (same outcomes as for acute gout therapy)
- Timing
  ○ Acute treatment (KQ1): 24-72 hours follow-up
  ○ Chronic treatment (KQ2-4): any follow-up time
  ○ Delayed versus immediate treatment (KQ1)
- Setting (all KQ)
  ○ Priority was given to patients being seen in primary care settings, which also includes urgent care clinics and emergency departments. If evidence from primary care settings was sparse, studies of patients in outpatient specialist settings were included

## Searching for the Evidence

We searched multiple databases for systematic reviews on gout and studies not included in those systematic reviews. In general, we include studies of effectiveness only if they were randomized controlled trials. If no trials could be identified of interest, observational studies were included for assessing the role of nutrition. Observational studies were also included for rare adverse events. Evidence obtained through the systematic review process was considered in light of what is already known about the physiology of gout and about the treatment of painful and inflammatory conditions.

### Literature Search Strategies for Identification of Relevant Studies To Answer the Key Questions

The search strategy was designed by our reference librarian in collaboration with our local content expert, who has participated in the two ACR systematic reviews on gout;31, 32 the search strategy appears in Appendix A. We searched PubMed, EMBASE, the Cochrane Collection, and the Web of Science using the search terms “gout,” and “gouty,” and terms for tophi (January 1, 2010-April 23, 2015; at least one year prior to the search dates for the recent systematic reviews). We also obtained relevant references from at least 28 recent systematic reviews that cover nearly all of the KQs. We also searched Clinicaltrials.gov and the Web of Science for recently completed studies and unpublished or non-peer-reviewed study findings. Searches were not limited by language of publication; however, non-English language studies had to have an English language abstract in order to be screened. This process resulted in assessment of full text articles in the following languages: Chinese, French, German, Japanese, Spanish, Portuguese, and Russian. In addition, we contacted manufacturers of the prescription medications used to treat gout that are listed in Table 1 for unpublished data specific to the use of these medications for treatment of gout or symptoms related to gout.

We also included any relevant studies identified in the searches we conducted for a simultaneous review on diagnosis of gout if not already identified in the searches for this review. Finally, we asked the TEP to assess our list of included studies and to provide references for any additional studies they believed should also be included. An update search was conducted after submission of the draft report and studies identified in the update search underwent the same process.

The output of the literature searches was transferred to DistillerSR™ for screening. Article titles and abstracts identified by the searches were independently screened by two literature reviewers using the predetermined inclusion and exclusion criteria, and those selected by either reviewer were accepted without reconciliation for further, full-text review. Full-text review was also conducted independently by two reviewers to exclude articles that did not meet the inclusion criteria of the review. Disagreements regarding inclusion at the full-text stage were reconciled, with the input of the project lead when necessary.

We also identified a number of systematic reviews on gout management for which we performed reference mining. In addition, we searched the reference lists of included studies for additional titles that appeared to fit our inclusion criteria and screened these articles for inclusion.

## Data Abstraction and Data Management

Study level details from articles accepted for inclusion were abstracted by one reviewer and double checked by a second reviewer. Any disagreements were reconciled by the SCEPC Director, or the local subject matter expert if needed.

## Assessment of Methodological Risk of Bias of Individual Studies

Risk of bias (study quality) of individual included studies was assessed independently by two reviewers using an adapted Cochrane Risk of Bias tool,38 and assessments were reconciled, with any disagreements mediated by the project lead. We used a modified AMSTAR tool to assess the quality of existing systematic reviews that we included;39 AMSTAR assessments were also conducted independently by two reviewers and reconciled.

## Data Synthesis/Analysis

Given the large number of existing systematic reviews on this topic, we used the following strategy for data synthesis/analysis:

1. Identify the existing systematic reviews and make a judgment about relevancy for the KQs, the end date of the search, and the methodologic quality as assessed by AMSTAR,39 following the process outlined by Whitlock and colleagues.37
2. Scan the references of these systematic reviews for included studies.
3. Search for new studies meeting the eligibility criteria for the KQ.
4. Compare the conclusions of the existing systematic reviews.
5. Compare the results of new studies with the conclusions of existing systematic reviews.
6. Use the guide shown in Figure 1 for additional analyses/conclusions.

Figure 1 Framework for incorporating existing systematic reviews and studies not included in these reviews

SR(s) = systematic review(s)

This figure is a flow diagram on the strategy that was used for data synthesis/analysis. The steps are described more in detail right above the figure.

## Grading the Strength of the Body of Evidence for Each Key Question

We assessed the overall SoE for each conclusion (e.g., the efficacy and safety of each pharmacologic agent or class of agents listed in the PICOTs, and differences by subgroup, if identified), using guidance suggested by the Effective Health Care Program.40 This method is based on one developed by the GRADE Working Group and classifies the grade of evidence as High (also called Strong), Moderate, Low or Insufficient. The evidence grade is based on five required domains: study limitations, consistency, directness, precision, and publication bias. The grades and their definitions are presented below.40

High: We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable, i.e., another study would not change the conclusions

Moderate: We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.

Low: We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.

Insufficient: We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

We also considered in our strength of evidence assessments the criteria proposed by Bradford Hill for causality.41 These criteria include the strength, consistency, and specificity of the association, the temporal relationship, the “biologic gradient” or dose-response curve, the biologic plausibility, and coherence. These principles allow us to construct and evaluate evidence chains. For example, in assessing the evidence regarding pharmacological urate lowering therapy (ULT) agents, we considered the biochemical properties of urate in serum: urate is soluble in serum up to a concentration of about 6.0-7.0mg/dl. Numerous cohort studies show a gradient of gout attacks related to increasing serum urate levels. RCTs of ULTs have demonstrated evidence that they lower serum urate levels, but the longest trials have lasted only 6 to12 months and have not shown reductions in acute gout attacks, in part because the same pharmaceutical interventions increase the risk of acute gout attacks in the short term (months). Long term observational extension studies from these RCTs show that patients who continued on pharmaceutical therapy had reduced serum urate levels and, after about 1 year, a less-than-5 percent risk of acute gout attacks. This evidence chain includes biologic plausibility, consistency of association, the appropriate temporal relationship, experimental evidence, the biologic gradient, and coherence. We rated this chain of evidence as moderate for pharmaceutical therapies to reduce the risk of acute gout attacks after about 1 year.

## Applicability

Because the charge for this review is clear on the setting, care providers, and patient population the review is intended to cover, applicability assessment was based primarily on the similarity of the settings and populations to those for which this report is intended, namely primary and acute care settings that treat individuals, a high proportion of whom have comorbidities or are at risk for comorbidities such as hypertension and renal insufficiency.42

## Peer Review and Public Commentary

A draft version of the report was posted for peer review on June 25, 2015, and revised in response to reviewer comments.