# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Hyon K. Choi, M.D., Ph.D.^*^
  * This Technical Expert Panel (TEP) member also provided review of the draft report.
  Professor of Medicine, Harvard Medical School
  Director, Gout and Crystal Arthropathy Center
  Director, Clinical Epidemiology and Health Outcomes
  Division of Rheumatology, Allergy, and Immunology
  Department of Medicine
  Massachusetts General Hospital
  Boston, MA
- Russell Harris, M.D., M.P.H.
  Sheps Center for Health Services Research
  University of North Carolina
  Professor, Division of General Medicine
  University of North Carolina–Chapel Hill
  Chapel Hill, NC
- Gerald D. Levy, M.D.^*^
  Rheumatologist
  Southern California Permanent Medical Group
  Downey, CA
- Shari Ling, M.D.
  Deputy Chief Medical Officer
  Office of Clinical Standards and Quality
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- Ted Mikuls, M.D.^*^
  Umbach Professor of Rheumatology
  Division of Rheumatology
  Department of Internal Medicine
  University of Nebraska Medical Center and VA Nebraska-Western Iowa Health Care System
  Omaha, NE
- Esther Myers, Ph.D, R.D.^*^
  Registered Dietitian
  EF Myers Consulting, Inc.
  Former Chief Science Officer
  Academy of Nutrition and Dietetics
  Chicago, IL
- Tuhina Neogi, M.D., Ph.D,^*^
  Associate Professor of Medicine and of Epidemiology
  Boston University School of Medicine
  Boston University School of Public Health
  Boston, MA
- Richard Treger, M.D.
  Board-Certified Nephrologist
  Greater Los Angeles VA Health Care System
  Los Angeles, CA
- Daniel Waxman, M.D., Ph.D.^*^
  Senior Natural Scientist, RAND Corporation
  Visiting Associate Professor of Emergency Medicine, University of California, Los Angeles
  Los Angeles, CA
- Neil Wenger, M.D.
  General Internist
  General Internal Medicine Physician and Senior Researcher
  RAND and University of California, Los Angeles
  Los Angeles, CA