# List of Excluded Studies

## Not Human (N=2)

1 Shih YC, Huang KK, Tsai YF, et al. Anisomeles indica and its active principles modulate IL-1BETA. Ann Rheum Dis. 2013;71(3):2012-06.
2 Stocker SL, McLachlan AJ, Savic RM, et al. The pharmacokinetics of oxypurinol in people with gout. Br J Clin Pharmacol. Sep. 2012;74(3):477-89. [pmid: 22300439].

## Not gout or hyperuricemia associated with gout (N=26)

1 Arai M, Yokosuka O, Fujiwara K, et al. Fulminant hepatic failure associated with benzbromarone treatment: a case report. J Gastroenterol Hepatol. May. 2002;17(5):625-6. [pmid: 12084041].
2 Aujero M, Richards JS, Nunziato CA, et al. Chronic renal injury does not prevent achievement of target serum uric acid in tophaceous gout. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S506-S7.
3 Bastow MD, Durrington PN, Ishola M. Hypertriglyceridemia and hyperuricemia: effects of two fibric acid derivatives (bezafibrate and fenofibrate) in a double-blind, placebo-controlled trial. Metabolism. Mar. 1988;37(3):217-20. [pmid: 3278190].
4 Becker MA, Kisicki J, Khosravan R, et al. Febuxostat (TMX-67), a novel, non-purine, selective inhibitor of xanthine oxidase, is safe and decreases serum urate in healthy volunteers. Nucleosides Nucleotides Nucleic Acids. Oct. 2004;23(8-9):1111-6. [pmid: 15571211].
5 Bresalier RS, Sandler RS, Quan H, et al. Cardiovascular events associated with rofecoxib in a colorectal adenoma chemoprevention trial. N Engl J Med. Mar. 17. 2005;352(11):1092-102. [pmid: 15713943].
6 Caraco Y, Putterman C, Rahamimov R, et al. Acute colchicine intoxication--possible role of erythromycin administration. J Rheumatol. Mar. 1992;19(3):494-6. [pmid: 1578471].
7 Chao SC, Yang CC, Lee JY. Hypersensitivity syndrome and pure red cell aplasia following allopurinol therapy in a patient with chronic kidney disease. Ann Pharmacother. Sep. 2005;39(9):1552-6. [pmid: 16076905].
8 Dalbeth N, Wong S, Gamble GD, et al. Acute effect of milk on serum urate concentrations: a randomised controlled crossover trial. Ann Rheum Dis. Sep. 2010;69(9):1677-82. [pmid: 20472590].
9 Grossman JM, Gordon R, Ranganath VK, et al. American College of Rheumatology 2010 recommendations for the prevention and treatment of glucocorticoid-induced osteoporosis. Arthritis Care Res (Hoboken). Nov. 2010;62(11):1515-26. [pmid: 20662044].
10 Hunt SA, Abraham WT, Chin MH, et al. ACC/AHA 2005 Guideline Update for the Diagnosis and Management of Chronic Heart Failure in the Adult: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Writing Committee to Update the 2001 Guidelines for the Evaluation and Management of Heart Failure): developed in collaboration with the American College of Chest Physicians and the International Society for Heart and Lung Transplantation: endorsed by the Heart Rhythm Society. Circulation. Sep. 20. 2005;112(12):e154-235. [pmid: 16160202].
11 Kanbay M, Ozkara A, Selcoki Y, et al. Effect of treatment of hyperuricemia with allopurinol on blood pressure, creatinine clearence, and proteinuria in patients with normal renal functions. Int Urol Nephrol. 2007;39(4):1227-33. [pmid: 17701281].
12 Kullich W, Ulreich A, Klein G. Changes in uric acid and blood lipids in patients with asymptomatic hyperuricemia treated with diet therapy in a rehabilitation procedure. Rehabilitation. (Stuttg). Aug. 1989;28(3):134-7. [pmid: 2799055].
13 Lang PG Jr. Severe hypersensitivity reactions to allopurinol. South Med J. Nov. 1979;72(11):1361-8. [pmid: 159491].
14 Lee HY, Ariyasinghe JT, Thirumoorthy T. Allopurinol hypersensitivity syndrome: a preventable severe cutaneous adverse reaction?. Singapore Med J. May. 2008;49(5):384-7. [pmid: 18465047].
15 Minetti EE, Minetti L. Multiple organ failure in a kidney transplant patient receiving both colchicine and cyclosporine. J Nephrol. May-Jun. 2003;16(3):421-5. [pmid: 12832745].
16 Puig JG, Mateos F, Buno A, et al. Effect of eprosartan and losartan on uric acid metabolism in patients with essential hypertension. J Hypertens. Jul. 1999;17(7):1033-9. [pmid: 10419078].
17 Rollot F, Pajot O, Chauvelot-Moachon L, et al. Acute colchicine intoxication during clarithromycin administration. Ann Pharmacother. Dec. 2004;38(12):2074-7. [pmid: 15494379].
18 Rosenfeld JB. Effect of long-term allopurinol administration on serial GFR in normotensive and hypertensive hyperuricemic subjects. Adv Exp Med Biol. 1974;41:581-96. [pmid: 4832585].
19 Shalom R, Rimbroth S, Rozenman D, et al. Allopurinol-induced recurrent DRESS syndrome: pathophysiology and treatment. Ren Fail. 2008;30(3):327-9. [pmid: 18350453].
20 Singh JA, Furst DE, Bharat A, et al. 2012 update of the 2008 American College of Rheumatology recommendations for the use of disease-modifying antirheumatic drugs and biologic agents in the treatment of rheumatoid arthritis. Arthritis Care Res (Hoboken). May. 2012;64(5):625-39. [pmid: 22473917].
21 Siu YP, Leung KT, Tong MK, et al. Use of allopurinol in slowing the progression of renal disease through its ability to lower serum uric acid level. Am J Kidney Dis. Jan. 2006;47(1):51-9. [pmid: 16377385].
22 Solomon SD, McMurray JJ, Pfeffer MA, et al. Cardiovascular risk associated with celecoxib in a clinical trial for colorectal adenoma prevention. N Engl J Med. Mar. 17. 2005;352(11):1071-80. [pmid: 15713944].
23 Wagayama H, Shiraki K, Sugimoto K, et al. Fatal fulminant hepatic failure associated with benzbromarone. J Hepatol. May. 2000;32(5):874. [pmid: 10845680].
24 Wang SM, Patel BV, Gao S, et al. Impact of utilization management strategies for febuxostat on the use of chronic gout therapy. Journal of Managed Care Pharmacy. March. 2012;18(2):183-4.
25 Wetzels JJ, Kremers SP, Vitoria PD, et al. The alcohol-tobacco relationship: a prospective study among adolescents in six European countries. Addiction. Dec. 2003;98(12):1755-63. [pmid: 14651508].
26 Zhang W, Doherty M, Arden N, et al. EULAR evidence based recommendations for the management of hip osteoarthritis: report of a task force of the EULAR Standing Committee for International Clinical Studies Including Therapeutics (ESCISIT). Ann Rheum Dis. May. 2005;64(5):669-81. [pmid: 15471891].

## Not gout diagnosis or management or does not address the key question (N=154)

1 Adithya Acharya K, Sharma A. Evaluation of the efficacy of siravyadha and guduchi siddha yoga basti in the management of vatarakta with special reference to gout. International Journal of Research in Ayurveda and Pharmacy. 2013. 2013;4(3):402-9. FULL TEXT LINK http://dx.doi.org/10.7897/2277-4343.04319.
2 Ahmad M, Faraazi AA, Aamir MN. The Effect of Ocimum Sanctum and Ledum Palustre on Serum Uric Acid Level in Patients Suffering from Gouty Arthritis and Hyperuricaemia. Bulletin of the Chemical Society of Ethiopia. 2013;27(3):469-73. PMID:. WOS:000328168600016.
3 Al-Omoush O, Samaranayke M, Bukhari M. Quality of life, lifestyle factors and deprivation scores in patients with gout in primary care. Ann Rheum Dis. 2013;71(3):2012-06.
4 Altman RD, Gibofsky A, Jaros M, et al. Lower-dose indomethacin submicron particle capsules' efficacy in acute pain: Results from two phase 3 studies. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S872-S3.
5 Alvarez-Hernandez E, Pelaez-Ballestas I, Vazquez-Mellado J, et al. Validation of the Health Assessment Questionnaire disability index in patients with gout. Arthritis Rheum. May. 15. 2008;59(5):665-9. [pmid: 18438898].
6 Andres M, Sivera F, Falzon L, et al. Dietary supplements for chronic gout. Cochrane Database Syst Rev. 2014;10. Cd010156. [pmid: 25287939].
7 Ang A, Riches P, Thomson J, et al. Audit of arma 2012 standards of care for people with gout in primary care in edinburgh and the lothians. Rheumatology. April. (2013). SUPPL. 1. 2013;52:i67-i8.
8 Ang KYR, Lee YK, Koh EY, et al. Intestinal Microbial Study of Gout Patients. Annals of the Academy of Medicine Singapore. 9. 2013;42:S98.
9 Araujo F, Cordeiro I, Ramiro S, et al. Outcomes assessed in trials of gout and accordance with OMERACT recommendations. Annals of the Rheumatic Diseases. 2013;72(3):2013-06.
10 Arroll B, Bennett M, Dalbeth N, et al. More allopurinol is needed to get gout patients < 0.36 mmol/l: a gout audit in the form of a before-after trial. J Prim Health Care. Dec. 2009;1(4):315-8. [pmid: 20690341].
11 Aune D, Norat T, Vatten LJ. Body mass index and the risk of gout: a systematic review and dose-response meta-analysis of prospective studies. Eur J Nutr. Dec. 2014;53(8):1591-601. [pmid: 25209031].
12 Bae J, Shin DH, Chun BY, et al. The effect of vitamin C intake on the risk of hyperuricemia and serum uric acid level in Korean Multi-Rural Communities Cohort. Joint Bone Spine. Dec. 2014;81(6):513-9. PMID:. WOS:000346418700009. [pmid: 24998789].
13 Bakker R, Ede AV, Lamers-Karnebeek F, et al. Protocol-bvased pharmacotherapy in gout delivered by specialised health care professional under supervision of a rheumathologist is similar but not significantly superior to care as usual. Annals of the Rheumatic Diseases. 2013;72(3):2013-06.
14 Barg A, Knupp M, Kapron AL, et al. Total ankle replacement in patients with gouty arthritis. J Bone Joint Surg Am. Feb. 16. 2011;93(4):357-66. [pmid: 21325587].
15 Baumgartner S, Choi H, Dalbeth N, et al. Allopurinol dose titration and efficacy: A large-scale, 6-month, multicenter, prospective study. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S503-S4.
16 Beard SM, von Scheele BG, Nuki G, et al. Cost-effectiveness of febuxostat in chronic gout. Eur J Health Econ. 2013. May. 30. [pmid: 23719971].
17 Becker M, Yood R, Perez-Ruiz F, et al. Time to resolution of tophi with urate lowering agents: A literature analysis of randomized trials. Ann Rheum Dis. 2013;71(3):2012-06.
18 Becker MA, Schumacher HR, Benjamin KL, et al. Quality of life and disability in patients with treatment-failure gout. J Rheumatol. May. 2009;36(5):1041-8. [pmid: 19332629].
19 Becker MA, Schumacher HR, Chohan S, et al. Documentation of Fewer Gout Flares after Long-Term Urate Lowering Therapy. J Clin Rheumatol. Apr. 2010;16(3):S21-S2. PMID:. WOS:000276765300062.
20 Bonnel RA, Villalba ML, Karwoski CB, et al. Deaths associated with inappropriate intravenous colchicine administration. J Emerg Med. May. 2002;22(4):385-7. [pmid: 12113850].
21 Bottiglieri S, Tierson N, Patel R, et al. Gemcitabine-induced gouty arthritis attacks. J Oncol Pharm Pract. Sep. 2013;19(3):284-8. [pmid: 23169898].
22 Butendieck R, Parikh P, Calamia K, et al. Using Dual-Energy Computed Tomography for the Diagnosis of Peripheral and Axial Gouty Arthritis. Clin Exp Rheumatology. Jan-Feb. 2011;29(1):206. PMID:. WOS:000288292000276.
23 Chandrasekaran D, Cioffi S, Waterman J. Evaluation of the use of colchicine in the management of chronic gout. Annals of the Rheumatic Diseases. 2013;72(3):2013-06.
24 Chandratre P, Mallen C, Richardson J, et al. Prospective observational cohort study of Health Related Quality of Life (HRQOL), chronic foot problems and their determinants in gout: a research protocol. BMC Musculoskelet Disord. 2012;13:219. [pmid: 23148573].
25 Chen Y, Akhras KS, Grabner M, et al. Treatment patterns and monitoring of serum URIC acid levels in a large cohort of gout patients in the united states: Is there room for improvement?. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S867.
26 Choi HK, Atkinson K, Karlson EW, et al. Purine-rich foods, dairy and protein intake, and the risk of gout in men. N Engl J Med. Mar. 2004;350(11):1093-103. PMID:. WOS:000220110100006. [pmid: 15014182].
27 Choi HK, Curhan G. Independent impact of gout on mortality and risk for coronary heart disease. Circulation. Aug. 21. 2007;116(8):894-900. [pmid: 17698728].
28 Choi HK, Curhan G. Soft drinks, fructose consumption, and the risk of gout in men: prospective cohort study. Br Med J. Feb. 2008;336(7639):309-+. PMID:. WOS:000253437400031. [pmid: 18244959].
29 Choi HK, Curhan G. Coffee consumption and risk of incident gout in women: the Nurses' Health Study. Am J Clinic Nutr. Oct. 2010;92(4):922-7. PMID:. WOS:000282234100032.
30 Choi HK, Willett W, Curhan G. Fructose-rich beverages and risk of gout in women. JAMA. Nov. 24. 2010;304(20):2270-8. [pmid: 21068145].
31 Choy G, Bell A, Baria N, et al. Current gout management practices in Canada. J Rheumatol. August. 2012;39(8):1748.
32 Cohen SD, Kimmel PL, Neff R, et al. Association of incident gout and mortality in dialysis patients. J Am Soc Nephrol. Nov. 2008;19(11):2204-10. [pmid: 18508965].
33 Conway R, Coughlan RJ, Carey JJ. Adherence to uric acid treatment guidelines in a rheumatology clinic. Clin Rheumatol. Dec. 2012;31(12):1707-11. [pmid: 22948225].
34 Cuesta M, Perez Alcantara F, Brosa M. Cost-effectiveness of febuxostat in managing hyperuricemia in gout patients in Spain. Value in Health. November. 2012;15(7):A513.
35 Dalbeth N, Aati O, Gamble GD, et al. Zoledronate for prevention of bone erosion in tophaceous gout: a randomised, double-blind, placebo-controlled trial. Ann Rheum Dis. 2014. Jan. 17. [pmid: 24442886].
36 Dalbeth N, Clark B, Gregory K, et al. Mechanisms of bone erosion in gout: a quantitative analysis using plain radiography and computed tomography. Ann Rheum Dis. Aug. 2009;68(8):1290-5. [pmid: 18708415].
37 De Vera MA, Marcotte G, Rai S, et al. Medication adherence in gout: A systematic review. Arthritis Care Res (Hoboken). 2014. Apr. 1. [pmid: 24692321].
38 De Vuono A, Scicchitano F, Palleria C, et al. Lack of efficacy during the switch from brand to generic allopurinol. J Forensic Leg Med. Jul. 2013;20(5):540-2. [pmid: 23756530].
39 DeMarco M, Maynard J, Coresh J. Alcohol intake is associated with incident gout in ARIC. Am J Epidemiol. 1. SUPPL. 11. 2011;173:S57.
40 DeMarco MA, Maynard JW, Huizinga MM, et al. Obesity and younger age at gout onset in a community-based cohort. Arthritis Care Res (Hoboken). Aug. 2011;63(8):1108-14. [pmid: 21485022].
41 Dubreuil M, Zhu Y, Zhang Y, et al. Allopurinol initiation and all-cause mortality in the general population. Ann Rheum Dis. 2014. Mar. 24. [pmid: 24665118].
42 Eliseev MS, Denisov IS, Gluhova SI, et al. Independent risk factors for cardiovascular events in male patients with gout: Results of the 7-year prospective follow-up study. Annals of the Rheumatic Diseases. 2013;72(3):2013-06.
43 Fara N, Vazquez Mellado J, Sequeira G, et al. A survey on the current evaluation and treatment of gout in Buenos Aires, Argentina. Reumatol Clin. Nov-Dec. 2012;8(6):306-9. [pmid: 22854175].
44 Ferraz MB, O'Brien B. A cost effectiveness analysis of urate lowering drugs in nontophaceous recurrent gouty arthritis. J Rheumatol. May. 1995;22(5):908-14. [pmid: 8587081].
45 Flynn RWV, Jennings C, Mackenzie IS, et al. Experience of using gout flare prophylaxis in the fast trial. Pharmacoepidemiology and Drug Safety. October. SUPPL. 1. 2013;22:421-2.
46 Fraunfelder FT, Hanna C, Dreis MW, et al. Cataracts associated with allopurinol therapy. Am J Ophthalmol. Aug. 1982;94(2):137-40. [pmid: 7114136].
47 George M, Pullman-Mooar S, Hussain F, et al. Evaluating appropriate use of prophylactic colchicine for gout flare prevention. Arthritis Care Res (Hoboken). 2013. Dec. 24. [pmid: 24376081].
48 George M, Pullman-Mooar SW, Schumacher HR. Evaluating appropriate use of prophylactic colchicine and urate lowering therapy in gout. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S60.
49 Gerster JC, Zufferey P. Impairment of the ankle and the hind-foot in metabolic diseases. Medecine Et Chirurgie Du Pied. Jun. 2012;28(2):54-8. PMID:. WOS:000304910400002.
50 Goldfarb DS, MacDonald PA, Gunawardhana L, et al. Randomized controlled trial of febuxostat versus allopurinol or placebo in individuals with higher urinary uric acid excretion and calcium stones. Clin J Am Soc Nephrol. Nov. 2013;8(11):1960-7. [pmid: 23929928].
51 Goldfien RD, Ng MS, Yip GM, et al. Feasibility of using a pharnacist-based gout management clinic to improve serum uric acid in gout patients an a large prepaid health plan. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S356.
52 Hamaguchi Y, Fujimoto M, Enokido Y, et al. Intractable genital ulcers from herpes simplex virus reactivation in drug-induced hypersensitivity syndrome caused by allopurinol. Int J Dermatol. Jun. 2010;49(6):700-4. [pmid: 20618479].
53 Hamburger MI, Pillinger MH, Sederman R, et al. Many gout patients treated by rheumatologists do not meet established treatment goals despite long-term urate lowering therapy: Results of a gout patient encounter survey. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S367-S8.
54 Harrold L, Greenberg J, Saunders K, et al. Characteristics of gout patients cared for by rheumatologists-results from the corrona gout registry site survey. Annals of the Rheumatic Diseases. 2013;72(3):2013-06.
55 Henry D, Page J, Whyte I, et al. Consumption of non-steroidal anti-inflammatory drugs and the development of functional renal impairment in elderly subjects. Results of a case-control study. Br J Clin Pharmacol. Jul. 1997;44(1):85-90. [pmid: 9241101].
56 Higa J, Reardon G, Tong G. A retrospective evaluation of the clinical and economic implications of gout in nursing home residents in hawaii treated with allopurinol. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S771.
57 Hill EM, Sky K, Sit M, et al. Does starting allopurinol prolong acute treated gout? A randomized clinical trial. J Clin Rheumatol. Apr. 2015;21(3):120-5. [pmid: 25807090].
58 Hoeltzenbein M, Stieler K, Panse M, et al. First trimester use of allopurinol-outcome of 31 prospectively ascertained pregnancies and a phenotype possibly indicative for teratogenicity. Medizinische Genetik. March. 2013;25(1):124.
59 Hu HJ, Liao MY, Tian ZX, et al. The value of using dual-energy CT in the detection of monosodium urate crystals in patients with gout. Chinese Journal of Radiology. December. (2012). 2012;46(12):1101-4. FULL TEXT LINK http://dx.doi.org/10.3760/cma.j.issn.1005-1201.2012.12.011.
60 Jaszczyk B, Wislowska M. Treatment of gout in patients after organ transplantation. ORIGINAL (NON-ENGLISH) TITLE. Leczenie dny moczanowej u pacjentow po przeszczepieniu narzadu. Reumatologia. 2013. 2013;51(3):215-20. FULL TEXT LINK http://dx.doi.org/10.5114/reum.2013.35773.
61 Jennings C, Mackenzie IS, Flynn R, et al. Demographics of the patient population recruited into the Febuxostat vs. Allopurinol streamlined trial (FAST). Pharmacoepidemiology and Drug Safety. October. SUPPL. 1. 2013;22:400.
62 Jung JW, Song WJ, Kim YS, et al. HLA-B58 can help the clinical decision on starting allopurinol in patients with chronic renal insufficiency. Nephrology Dialysis Transplantation. Nov. 2011;26(11):3567-72. PMID:. WOS:000296350400023.
63 Juraschek SP, Miller ER 3rd, Gelber AC. Effect of oral vitamin C supplementation on serum uric acid: a meta-analysis of randomized controlled trials. Arthritis Care Res (Hoboken). Sep. 2011;63(9):1295-306. [pmid: 21671418].
64 Kamlow F, Pakozdi A, Jawad A. Management of gout in a primary care practice. Rheumatology. May. (2012). SUPPL. 3. 2012;51:iii111-iii2.
65 Kannangara D, Datta I, Indraratna P, et al. Individualising allopurinol therapy in gout. Internal Medicine Journal. May. SUPPL. 1. 2011;41:30.
66 Khanna D, Fitzgerald JD, Khanna PP, et al. 2012 American college of rheumatology guidelines for management of gout. part 1: Systematic nonpharmacologic and pharmacologic therapeutic approaches to hyperuricemia. Arthritis Care and Research. 2012;64(10):1431-46. [pmid: 23024028].
67 Khanna D, Forsythe A, Khanna P. Patient management/treatment and outcomes of gout between primary care physicians and rheumatologists: A chart review of 1,039 patients with gout in the United States. Arthritis and Rheumatism. 2011;63(10):2011-11.
68 Khanna D, Hagerty D, Mischler R, et al. Assessing patients that continue to flare despite apparent optimal urate lowering therapy. Ann Rheum Dis. 2013;71(3):2012-06.
69 Khanna D, Khanna P, Storgard C, et al. More than one-third of patients reach serum urate target and continue to report multiple flares. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S501-S2.
70 Khanna P, Hagerty D, Mischler R, et al. Adherence to EULAR recommendations for the treatment of Gout. Ann Rheum Dis. 2013;71(3):2012-06.
71 Khanna P, Singh MK, Bae S, et al. Oral urate lowering therapies in chronic gout: A systematic review and meta-analysis. Arthritis and Rheumatism. 2011;63(10):2011-11.
72 Khanna P, Tausche AK, Forsythe A, et al. Gout patient burden associated with flares, tophi, and awareness of uric acid levels in US and EU. Arthritis and Rheumatism. 2011;63(10):2011-11.
73 Kim YS, Park EH, Lee HJ, et al. First metatarsophalangeal joint arthrodesis for the treatment of tophaceous gouty arthritis. Orthopedics. Feb. 2014;37(2):e141-7. [pmid: 24679199].
74 Kim YW, Park BS, Ryu CH, et al. Allopurinol-induced aplastic anemia in a patient with chronic kidney disease. Clin Nephrol. Feb. 2009;71(2):203-6. [pmid: 19203517].
75 Krishnan E, Baker JF, Furst DE, et al. Gout and the risk of acute myocardial infarction. Arthritis Rheum. Aug. 2006;54(8):2688-96. [pmid: 16871533].
76 Krishnan E, Svendsen K, Neaton JD, et al. Long-term cardiovascular mortality among middle-aged men with gout. Arch Intern Med. May. 26. 2008;168(10):1104-10. [pmid: 18504339].
77 Lakhoua G, Kastalli S, Zaiem A, et al. Colchicine side effects'. Drug Safety. September. 2013;36(9):851.
78 Lim AY, Shen L, Tan CH, et al. Achieving treat to target in gout: a clinical practice improvement project. Scand J Rheumatol. 2012;41(6):450-7. [pmid: 22839705].
79 Lin CS, Wang XD. The staging and typing syndrome differentiating treatment of gout. Zhongguo Zhong Xi Yi Jie He Za Zhi. Apr. 2011;31(4):461-2. [pmid: 21608211].
80 Liu ZM, Ho CS, Chen YM, et al. Can soy intake affect serum uric acid level? Pooled analysis from two 6-month randomized controlled trials among Chinese postmenopausal women with prediabetes or prehypertension. Eur J Nutr. Feb. 2015;54(1):51-8. PMID:. WOS:000348440400004. [pmid: 24659208].
81 Li-Yu J, Clayburne G, Sieck M, et al. Treatment of chronic gout. Can we determine when urate stores are depleted enough to prevent attacks of gout?. J Rheumatol. Mar. 2001;28(3):577-80. [pmid: 11296962].
82 Loeb JN. The influence of temperature on the solubility of monosodium urate. Arthritis Rheum. Mar-Apr. 1972;15(2):189-92. [pmid: 5027604].
83 Lonjou C, Borot N, Sekula P, et al. A European study of HLA-B in Stevens-Johnson syndrome and toxic epidermal necrolysis related to five high-risk drugs. Pharmacogenet Genomics. Feb. 2008;18(2):99-107. [pmid: 18192896].
84 Lu N, Shai I, Zhang Y, et al. High-protein diet (Atkins Diet) and uric acid response. Arthritis Rheum. 2014:S71-s2.
85 Ly J, Gow P, Dalbeth N. Colchicine prescribing and safety monitoring in patients with gout. N Z Med J. 2007;120(1265).
86 Marinier FC. A relief in the setting of a gout attack. ORIGINAL (NON-ENGLISH) TITLE. Une delivrance dans le cadre d'une crise de goutte. Actualites Pharmaceutiques. April. 2010;(495):47-9.
87 Mikuls TR, Farrar JT, Bilker WB, et al. Suboptimal physician adherence to quality indicators for the management of gout and asymptomatic hyperuricaemia: results from the UK General Practice Research Database (GPRD). Rheumatology (Oxford). Aug. 2005;44(8):1038-42. [pmid: 15870145].
88 Mikuls TR, Farrar JT, Bilker WB, et al. Gout epidemiology: results from the UK General Practice Research Database, 1990-1999. Ann Rheum Dis. Feb. 2005;64(2):267-72. [pmid: 15647434].
89 Moi John HY, Sriranganathan Melonie K, Edwards Christopher J, et al. Lifestyle interventions for chronic gout. Cochrane Database of Syst Rev. John Wiley & Sons, Ltd. 2013.
90 Mullins M, Cannarozzi AA, Bailey TC, et al. Unrecognized fatalities related to colchicine in hospitalized patients. Clin Toxicol (Phila). Aug. 2011;49(7):648-52. [pmid: 21740149].
91 Nakayama DA, Barthelemy C, Carrera G, et al. Tophaceous gout: a clinical and radiographic assessment. Arthritis Rheum. Apr. 1984;27(4):468-71. [pmid: 6712761].
92 Naoyuki K, Shin F, Toshikazu H, et al. Placebo-controlled, double-blind study of the non-purine-selective xanthine oxidase inhibitor Febuxostat (TMX-67) in patients with hyperuricemia including those with gout in Japan: phase 3 clinical study. J Clin Rheumatol. Jun. 2011;17(4 Suppl 2):S19-26. [pmid: 21654266].
93 Naoyuki K, Shin F, Toshikazu H, et al. Placebo-controlled double-blind dose-response study of the non-purine-selective xanthine oxidase inhibitor febuxostat (TMX-67) in patients with hyperuricemia (including gout patients) in japan: late phase 2 clinical study. J Clin Rheumatol. Jun. 2011;17(4 Suppl 2):S35-43. [pmid: 21654268].
94 Neal DA, Tom BD, Gimson AE, et al. Hyperuricemia, gout, and renal function after liver transplantation. Transplantation. Nov. 27. 2001;72(10):1689-91. [pmid: 11726834].
95 Oh HS, Park W, Kwon SR, et al. Effects of gout web based self-management program on knowledge related to disease, medication adherence, and self-management. J Korean Acad Nurs. Aug. 2013;43(4):547-56. [pmid: 24071759].
96 Pan F, Li Q, Tang X, et al. Method and effectiveness of arthroscopic debridement for treating gouty arthritis of the knee. Zhongguo Xiu Fu Chong Jian Wai Ke Za Zhi. Aug. 2011;25(8):937-40. [pmid: 21923020].
97 Pascual E. Persistence of monosodium urate crystals and low-grade inflammation in the synovial fluid of patients with untreated gout. Arthritis Rheum. Feb. 1991;34(2):141-5. [pmid: 1994910].
98 Perez-Ruiz F, Martin I, Canteli B. Ultrasonographic measurement of tophi as an outcome measure for chronic gout. J Rheumatol. Sep. 2007;34(9):1888-93. [pmid: 17659752].
99 Pham NM, Yoshida D, Morita M, et al. The relation of coffee consumption to serum uric Acid in Japanese men and women aged 49-76 years. J Nutr Metab. 2010;2010. [pmid: 20798877].
100 Primatesta P, Plana E, Rothenbacher D. Gout treatment and comorbidities: a retrospective cohort study in a large US managed care population. BMC Musculoskelet Disord. 2011;12:103. [pmid: 21599917].
101 Rabi R, Elliott R, Quinn C. Estimating the impact of adherence to allopurinol therapy on cardiovascular outcomes in gout patients using the health improvement network (THIN) general practice database. Value in Health. November. 2011;14(7):A383.
102 Rajan A, Aati O, Kalluru R, et al. Lack of change in urate deposition by dual-energy computed tomography among clinically stable patients with long-standing tophaceous gout: a prospective longitudinal study. Arthritis Res Ther. 2013;15(5):R160. [pmid: 24286500].
103 Rana SS, Giuliani MJ, Oddis CV, et al. Acute onset of colchicine myoneuropathy in cardiac transplant recipients: case studies of three patients. Clin Neurol Neurosurg. Dec. 1997;99(4):266-70. [pmid: 9491303].
104 Rashid N, Coburn BW, Wu YL, et al. Modifiable factors associated with allopurinol adherence and outcomes among patients with gout in an integrated healthcare system. J Rheumatol. Mar. 2015;42(3):504-12. [pmid: 25512479].
105 Redding L, Hornberger J, Cowens W, et al. Cost-effectiveness of febuxostat in managing Hyperuricemia in gout patients in Canada. Journal of Population Therapeutics and Clinical Pharmacology. 2011. 2011;18(2):e195-e6.
106 Rees F, Jenkins W, Doherty M. Patients with gout adhere to curative treatment if informed appropriately: proof-of-concept observational study. Ann Rheum Dis. Jun. 2013;72(6):826-30. [pmid: 22679303].
107 Rodnan GP, Robin JA, Tolchin SF, et al. Allopurinol and gouty hyperuricemia. Efficacy of a single daily dose. JAMA. Mar. 17. 1975;231(11):1143-7. [pmid: 1172813].
108 Romeijnders AC, Gorter KJ. Summary of the Dutch College of General Practitioners' “Gout” Standard. Ned Tijdschr Geneeskd. Feb. 16. 2002;146(7):309-13. [pmid: 11876034].
109 Roughley MJ, Belcher J, Mallen CD, et al. Gout and risk of chronic kidney disease and nephrolithiasis: meta-analysis of observational studies. Arthritis Res Ther. 2015;17(1):90. [pmid: 25889144].
110 Saokaew S, Tassaneeyakul W, Maenthaisong R, et al. Cost-Effectiveness Analysis of HLA-B*5801 Testing in Preventing Allopurinol-Induced SJS/TEN in Thai Population. PLoS One. 2014;9(4):e94294. [pmid: 24732692].
111 Schlesinger N, Young TC, Radvanski DC, et al. Treatment of acute gout in the emergency department evaluated according to the 2012 american college of rheumatology guidelines. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S849.
112 Sedlakova J, Rovensky J. Tophaceous gout in the spine without prior hyperuricemia or tophi in other locations. ORIGINAL (NON-ENGLISH) TITLE. Tofozna dna v oblasti chrbtice bez predchadzajucej hyperurikemie alebo vyskytu tofov v inych lokalitach. Rheumatologia. 2012. 2012;26(4):179-82.
113 Sharim R, Musselman M, Blum M. Factors associated with a prolonged hospital length of stay for patients with acute gout. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S772.
114 Singer JZ, Wallace SL. The allopurinol hypersensitivity syndrome. Unnecessary morbidity and mortality. Arthritis Rheum. Jan. 1986;29(1):82-7. [pmid: 3947418].
115 Singh J, Hagerty D, Mischler R, et al. Adherence to proposed ACR treatment guidelines for gout. Journal of Managed Care Pharmacy. September. 2012;18(7):541.
116 Singh J, Hagerty D, Mischler R, et al. Majority of us patients would not meet the proposed ACR gout treatment guideline goal of SUA <6 mg/dl. Ann Rheum Dis. 2013;71(3):2012-06.
117 Singh JA, Hagerty D, Storgard C, et al. Proposed gout treatment guidelines and meeting serum urate and flare goals. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S62-S3.
118 Singh JA, Hodges JS, Toscano JP, et al. Quality of care for gout in the US needs improvement. Arthritis Rheum. Jun. 15. 2007;57(5):822-9. [pmid: 17530682].
119 Singh JA, Reddy SG, Kundukulam J. Risk factors for gout and prevention: a systematic review of the literature. Curr Opin Rheumatol. Mar. 2011;23(2):192-202. [pmid: 21285714].
120 Singh JA, Richman J. Poor quality of gout care is strongly associated with higher gout-related health care utilization. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S863-S4.
121 Singh JA, Strand V. Gout is associated with more comorbidities, poorer health-related quality of life and higher healthcare utilisation in US veterans. Ann Rheum Dis. Sep. 2008;67(9):1310-6. [pmid: 18178692].
122 Sivera F, Andres M, Carmona L, et al. Multinational evidence-based recommendations for the diagnosis and management of gout: integrating systematic literature review and expert opinion of a broad panel of rheumatologists in the 3e initiative. Annals of the Rheumatic Diseases. Feb. 2014;73(2):328-35. PMID:. WOS:000329488000001. [pmid: 23868909].
123 Slot O, Terslev L. The double contour sign is a consistent finding in MTP joints in gout patients. Results from an ultrasound pilot study in daily clinical practice. Ann Rheum Dis. 2013;71(3):2012-06.
124 Somkrua R, Eickman EE, Saokaew S, et al. Association of HLA-B*5801 allele and allopurinol-induced Stevens Johnson syndrome and toxic epidermal necrolysis: a systematic review and meta-analysis. BMC Med Genet. 2011;12:118. [pmid: 21906289].
125 Spencer KT, Carr A, Doherty M. Patient-related barriers to the effective management and treatment of gout. Rheumatology. April. SUPPL. 3. 2011;50:iii84-iii5.
126 Stamp LK, Barclay ML, O'Donnell JL, et al. Relationship between serum urate and plasma oxypurinol in the management of gout: determination of minimum plasma oxypurinol concentration to achieve a target serum urate level. Clin Pharmacol Ther. Sep. 2011;90(3):392-8. [pmid: 21796116].
127 Stamp LK, Barclay ML, O'Donnell JL, et al. Furosemide increases plasma oxypurinol without lowering serum urate--a complex drug interaction: implications for clinical practice. Rheumatology (Oxford). Sep. 2012;51(9):1670-6. [pmid: 22539486].
128 Stocker SL, Graham GG, McLachlan AJ, et al. Pharmacokinetic and pharmacodynamic interaction between allopurinol and probenecid in patients with gout. J Rheumatol. May. 2011;38(5):904-10. [pmid: 21285173].
129 Su H, Li X, Zhao N, et al. Comparing four imaging techniques of visualzing gouty tophi using one single patient. International Journal of Rheumatic Diseases. September. SUPPL. 1. 2012;15:131.
130 Su H, Li X, Zhao N, et al. Comparing four imaging techniques of visualzing gouty tophi using one single patient. Ann Rheum Dis. 2013;71(3):2012-06.
131 Tausche A, Nuki G, Perez-Ruiz F, et al. Chronic gout in Europe in 2010: Clinical profile of 1380 patients in the UK, Germany, France, Italy and Spain on urate-lowering therapy. Zeitschrift fur Rheumatologie. September. SUPPL. 2. 2012;71:50-1.
132 Taylor W, Dalbeth N, Singh JA, et al. Towards a preliminary definition of remission from gout. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S64-S5.
133 Templeton JS. Azapropazone or allopurinol in the treatment of chronic gout and/or hyperuricaemia. A preliminary report. Br J Clin Pract. Oct. 1982;36(10):353-8. [pmid: 7171423].
134 Tuomilehto J, Zimmet P, Wolf E, et al. Plasma uric acid level and its association with diabetes mellitus and some biologic parameters in a biracial population of Fiji. Am J Epidemiol. Feb. 1988;127(2):321-36. [pmid: 3337086].
135 Tweddell ED, Willcocks WA. An evaluation of piroxicam, a new non-steroidal anti-inflammatory agent. A multicentre trial. S Afr Med J. Jun. 13. 1981;59(25):915-6. [pmid: 7015542].
136 Vazquez-Mellado J, Cuan A, Magana M, et al. Intradermal tophi in gout: a case-control study. J Rheumatol. Jan. 1999;26(1):136-40. [pmid: 9918254].
137 Ventura F, Fracasso T, Leoncini A, et al. Death caused by toxic epidermal necrolysis (Lyell syndrome). J Forensic Sci. May. 2010;55(3):839-41. [pmid: 20345799].
138 Vogel D, Van De Laar MAFJ, Jansen TL, et al. Association between oxipurinol serum concentration and successful lowering of serum urate concentration in gout patients treated with allopurinol. ORIGINAL (NON-ENGLISH) TITLE. Associatie tussen serumconcentratie oxipurinol en succesvolle verlaging van serumconcentratie urinezuur bij behandeling van jichtpatienten met allopurinol. Pharmaceutisch Weekblad. 16. 2012;147(11):41-4.
139 Wang DD, Sievenpiper JL, de Souza RJ, et al. The effects of fructose intake on serum uric acid vary among controlled dietary trials. J Nutr. May. 2012;142(5):916-23. [pmid: 22457397].
140 Wang L, Qiu L, Zhang LY. High-frequency ultrasonographic findings of gouty arthritis. Chinese Journal of Medical Imaging Technology. February. 2011;27(2):376-9.
141 Wang MY, Jiang XB, Wu WL, et al. A meta-analysis of alcohol consumption and the risk of gout. Clin Rheumatol. Nov. 2013;32(11):1641-8. PMID:. WOS:000325809900011. [pmid: 23881436].
142 Wang Y, Yan S, Li C, et al. Risk factors for gout developed from hyperuricemia in China: a five-year prospective cohort study. Rheumatol Int. Mar. 2013;33(3):705-10. [pmid: 22544037].
143 Ward M, Louder AM, Szymanski K, et al. Evaluating allopurinol therapy and serum uric acid levels in medicare beneficiaries with gout. Journal of General Internal Medicine. July. SUPPL. 2. 2012;27:S184.
144 Wason S, Faulkner RD, Brimhall DB, et al. No dosing adjustments are required for colchicine in patients over age 60 years compared to younger adults on the basis of age and mild renal impairment. Arthritis and Rheumatism. 2011;63(10):2011-11.
145 Wasserman A, Shnell M, Boursi B, et al. Prognostic significance of serum uric acid in patients admitted to the Department of Medicine. Am J Med Sci. Jan. 2010;339(1):15-21. [pmid: 19996731].
146 Whelton A, MacDonald PA, Chefo S, et al. Preservation of renal function during gout treatment with febuxostat: a quantitative study. Postgrad Med. Jan. 2013;125(1):106-14. [pmid: 23391676].
147 Wong OF, Koo CK, Tang KS, et al. Bronchiolitis obliterans organising pneumonia in a case of colchicine overdose. Hong Kong Journal of Emergency Medicine. Jul. 2011;18(4):249-53. PMID:. WOS:000292797600011.
148 Wu ML, Deng JF, Yang CY. Acute hepatitis and jaundice due to tinospora sinensis or tinospora crispa. Clinical Toxicol. May. 2013;51(4):268-9.
149 Wu YQ, Hu JH, Zhao ZY, et al. Clinical observation on senile patients with acute gouty arthritis treated by acupoint application. Journal of the American Geriatrics Society. September. SUPPL. 2. 2014;62:S381.
150 Yahiaoui N, Logerot S, Villier C, et al. Conditions use of colchicine in practice and risk factors of intoxication. Fundamental and Clinical Pharmacology. June. SUPPL. 1. 2013;27:68.
151 Yu KH, Kuo CF, Luo SF, et al. Risk of end-stage renal disease associated with gout: a nationwide population study. Arthritis Res Ther. 2012;14(2):R83. [pmid: 22513212].
152 Zandman-Goddard G, Shamrayevsky N, Chodick G, et al. Patterns of compliance to allopurinol in real life population-is everything crystal clear?. Ann Rheum Dis. 2013;71(3):2012-06.
153 Zhang W, Doherty M, Bardin T, et al. EULAR evidence based recommendations for gout. Part II: Management. Report of a task force of the EULAR standing committee for international clinical studies including therapeutics (ESCISIT). Annals of the Rheumatic Diseases. Oct. 2006;65(10):1312-24. PMID:. WOS:000240508600009. [pmid: 16707532].
154 Zurmi IB, Abdulkareem IH, Carroll C. Systematic review of clinical effectiveness of allopurinol in treating gout, compared to febuxostat, among patients with confirmed diagnosis of gout. British Journal of Surgery. May. 2011;98:81. PMID:. WOS:000291978800239.

## Study of risk factor(s) for gout that doesn't test possible treatment (N=18)

1 Batt C, Phipps-Green AJ, Black MA, et al. Sugar-sweetened beverage consumption: a risk factor for prevalent gout with SLC2A9 genotype-specific effects on serum urate and risk of gout. Ann Rheum Dis. 2013. Sep. 11. [pmid: 24026676].
2 Bruderer S, Bodmer M, Jick SS, et al. Use of diuretics and risk of incident gout: a population-based case-control study. Arthritis Rheumatol. Jan. 2014;66(1):185-96. [pmid: 24449584].
3 Chang SJ, Ko YC, Wang TN, et al. High prevalence of gout and related risk factors in Taiwan's Aborigines. J Rheumatol. Jul. 1997;24(7):1364-9. [pmid: 9228138].
4 Choi HK, Atkinson K, Karlson EW, et al. Alcohol intake and risk of incident gout in men: a prospective study. Lancet. Apr. 17. 2004;363(9417):1277-81. [pmid: 15094272].
5 Choi HK, Gao X, Curhan G. Vitamin C intake and the risk of gout in men: a prospective study. Arch Intern Med. Mar. 9. 2009;169(5):502-7. [pmid: 19273781].
6 Choi HK, Willett W, Curhan G. Coffee consumption and risk of incident gout in men - A prospective study. Arthritis and Rheumatism. Jun. 2007;56(6):2049-55. PMID:. WOS:000247164300034. [pmid: 17530645].
7 DeMarco MM, Kottgen A, Law A, et al. Kidney function and alcohol intake and the risk of incident gout in a population-based cohort of adults: Atherosclerosis risk in communities study. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S36.
8 DeMarco MM, Maynard JW, Baer AN, et al. Alcohol intake is associated with incident gout among black and white, men and women in the atherosclerosis risk in communities study. Arthritis and Rheumatism. 2011;63(10):2011-11.
9 Dubreuil M, Neogi T, Chen CA, et al. Increased risk of recurrent gout attacks with hospitalization. Am J Med. Dec. 2013;126(12):1138-41 e1. [pmid: 24054179].
10 Eliseev MS, Denisov IS, Barskova VG. Survival of Gout Patients. Terapevticheskii Arkhiv. 2012;84(5):45-50. PMID:. WOS:000306781700009.
11 Frank O. Observations concerning the incidence of disturbance of lipid and carbohydrate metabolism in gout. Adv Exp Med Biol. 1974;41:495-8. [pmid: 4832573].
12 Jacobelli S, Arteaga A, Bidegain F. Cholesterol distribution among lipoprotein fractions in patients with gout and normal controls. J Rheumatol. Aug. 1986;13(4):774-7. [pmid: 3464758].
13 Kontogianni MD, Chrysohoou C, Panagiotakos DB, et al. Adherence to the Mediterranean diet and serum uric acid: the ATTICA study. Scand J Rheumatol. 2012;41(6):442-9. [pmid: 22827465].
14 Lin KC, Lin HY, Chou P. Community based epidemiological study on hyperuricemia and gout in Kin-Hu, Kinmen. J Rheumatol. Apr. 2000;27(4):1045-50. [pmid: 10782835].
15 Lin KC, Lin HY, Chou P. The interaction between uric acid level and other risk factors on the development of gout among asymptomatic hyperuricemic men in a prospective study. J Rheumatol. Jun. 2000;27(6):1501-5. [pmid: 10852278].
16 Lyu LC, Hsu CY, Yeh CY, et al. A case-control study of the association of diet and obesity with gout in Taiwan. Am J Clin Nutr. Oct. 2003;78(4):690-701. [pmid: 14522726].
17 Takahashi S, Yamamoto T, Moriwaki Y, et al. Increased concentrations of serum Lp(a) lipoprotein in patients with primary gout. Ann Rheum Dis. Feb. 1995;54(2):90-3. [pmid: 7702412].
18 Williams PT. Effects of diet, physical activity and performance, and body weight on incident gout in ostensibly healthy, vigorously active men. Am J Clin Nutr. May. 2008;87(5):1480-7. PMID:. WOS:000255880500049. [pmid: 18469274].

## No original data or non-systematic review background (N=97)

1 Indocin (indomethacin) oral suspension [prescribing information]. Whitehouse Station, NJ. Merck & Co, Inc. 2008.
2 Allopurinol tablets USP [prescribing information]. Corona, CA. Watson Laboratories Inc. 2009.
3 Probenecid tablets [prescribing information]. Corona, CA. Watson Laboratories Inc. 2010.
4 Colcrys (colchicine USP) tablets [prescribing information]. Philadelphia, PA. AR Scientific. 2012.
5 Orapred ODT (prednisolone sodium phosphate) [prescribing information]. Atlanta, GA. Shionogi Pharma, Inc. 2012.
6 Pathogenesis of Gout Tophus Formation. Zeitschrift Fur Rheumatologie. Sep. 2013;72(7):626. PMID:. WOS:000323744400001. [pmid: 23989689].
7 Uloric (febuxostat) tablets for oral use [prescribing information]. Deerfield, IL. Takeda Pharmaceuticals America, Inc. 2013.
8 Medrol (methylprednisolone, USP) tablets [prescribing information]. New York. Pfizer. 2013.
9 Abdellatif AA, Elkhalili N. Management of Gouty Arthritis in Patients With Chronic Kidney Disease. Am J Ther. 2012. Sep. 6. [pmid: 22960848].
10 Arellano F, Sacristan JA, Saint-Pierre J. Allopurinol hypersensitivity syndrome: A review. Ann Pharmacother. 1993. 1993;27(3):337-43. [medline: 8453174]. (http://www.ncbi.nlm.nih.gov/pubmed/8453174). [pmid: 8453174].
11 Bardin T, Desideri G. How to manage patients with gout. Curr Med Res Opin. Apr. Suppl 3. 2013;29:17-24. [pmid: 23621556].
12 Boss GR. ACP Journal Club: allopurinol during acute gout attacks did not differ from delayed allopurinol for pain or recurrence. Ann Intern Med. Apr. 16. 2013;158(8):JC6. [pmid: 23588771].
13 Castrejon I, Yazici Y, Pincus T. Formal education level is more explanatory of variation in patient global estimate than age, duration of disease or gender in patients with rheumatoid arthritis, osteoarthritis, systemic lupus erythematosus and gout. Ann Rheum Dis. 2013;72(3):2013-06.
14 Chan E, House ME, Petrie KJ, et al. Complementary and alternative medicine use in patients with gout: a longitudinal observational study. J Clin Rheumatol. Jan. 2014;20(1):16-20. [pmid: 24356480].
15 Chatham WW, Saag KG. Is febuxostat a more effective treatment for hyperuricemia and gout than allopurinol?. Nat Clin Pract Rheumatol. May. 2006;2(5):240-1. [pmid: 16932692].
16 Christalla P, Wittkopper K, El-Armouche A. Febuxostat a new drug for treatment of gout. Increased cardiovascular risk in gout patients?. ORIGINAL (NON-ENGLISH) TITLE. Febuxostat, ein neues Pharmakon zur Behandlung der Gicht. Erhohtes Herz-Kreislauf-Risiko bei Gichtpatienten?. Kardiologe. February. 2011;5(1):45-50. FULL TEXT LINK http://dx.doi.org/10.1007/s12181-010-0320-0.
17 Conway N, Schwartz S. Diagnosis and management of acute gout. Med Health R I. Nov. 2009;92(11):356-8. [pmid: 19999893].
18 Curiel RV, Guzman NJ. Challenges associated with the management of gouty arthritis in patients with chronic kidney disease: a systematic review. Semin Arthritis Rheum. Oct. 2012;42(2):166-78. [pmid: 22560299].
19 Dalbeth N, Palmano K. Effects of dairy intake on hyperuricemia and gout. Curr Rheumatol Rep. Apr. 2011;13(2):132-7. [pmid: 21188562].
20 Desideri G, Castaldo G, Lombardi A, et al. Is it time to revise the normal range of serum uric acid levels?. European Review for Medical and Pharmacological Sciences. 2014;18(9):1295-306. [pmid: 24867507].
21 Dubost JJ, Mathieu S, Soubrier M. Treatment of gout. Rev Med Interne. Dec. 2011;32(12):751-7. [pmid: 21382654].
22 El-Zawawy H, Mandell BF. Managing gout: how is it different in patients with chronic kidney disease?. Cleve Clin J Med. Dec. 2010;77(12):919-28. [pmid: 21147946].
23 Fellet AJ, De Oliveira Aires Pinto E, Barbosa LF, et al. Gout. ORIGINAL (NON-ENGLISH) TITLE. Gota. Revista Brasileira de Medicina. July. 2013;70(7):252-9.
24 Foong HBB. Allopurinol and the risk of Stevens-Johnson syndrome and toxic epidermal necrolysis. J Royal Coll Phys Edinburgh. 2009;39:144-5.
25 Fravel MA, Ernst ME. Management of gout in the older adult. Am J Geriatr Pharmacother. Oct. 2011;9(5):271-85. [pmid: 21849262].
26 Fulde G, Fulde S. Colchicine A, case of unexpected fatal toxicity. Medicine Today. February. 2012;13(2):55-7.
27 Fuldeore MJ, Riedel AA, Zarotsky V, et al. Chronic kidney disease in gout in a managed care setting. BMC Nephrol. 2011;12:36. [pmid: 21812963].
28 Gaffo AL, Saag KG. Febuxostat: The evidence for its use in the treatment of hyperuricemia and gout. Core Evidence. 2009;4:25-36. [pmid: 20694062].
29 Garcia-Valladares I, Khan T, Espinoza LR. Efficacy and safety of febuxostat in patients with hyperuricemia and gout. Ther Adv Musculoskelet Dis. Oct. 2011;3(5):245-53. [pmid: 22870483].
30 Gelber AC. Febuxostat versus allopurinol for gout. N Engl J Med. Apr. 6. 2006;354(14):1532-3. author reply -3. [pmid: 16602151].
31 Geronikolou SA. Treatment of gout in a recently published 9th century manuscript of Rhazes. Vesalius. Winter. 2014;20(2):95-8. [pmid: 25739155].
32 Goldfien RD, Ng MS, Yip G, et al. Effectiveness of a pharmacist-based gout care management programme in a large integrated health plan: results from a pilot study. BMJ Open. 2014;4(1):e003627. [pmid: 24413343].
33 Grodzicki T, Palmer A, Bulpitt CJ. Incidence of diabetes and gout in hypertensive patients during 8 years of follow-up. The General Practice Hypertension Study Group. J Hum Hypertens. Sep. 1997;11(9):583-5. [pmid: 9364276].
34 Grusch B, Rintelen B, Leeb BF. European League Against Rheumatism evidence-based recommendations for diagnosis and management of gout. Zeitschrift Fur Rheumatologie. Nov. 2007;66(7):568-72. PMID:. WOS:000251214100005. [pmid: 17891407].
35 Hisatome I. Impact of serum uric acid level on the cardiovascular system as a risk factor. Nihon Yakurigaku Zasshi. Dec. 2010;136(6):325-9. [pmid: 21139282].
36 Hollingworth P, Reardon JA, Scott JT. Acute gout during hypouricaemic therapy: prophylaxis with colchicine. Ann Rheum Dis. Oct. 1980;39(5):529. [pmid: 7436588].
37 Huizinga T, Nigrovic P, Ruderman E, et al. High versus low dosing of oral colchicine for early acute gout flare: Twenty-four-hour outcome of the first multicenter, randomized, double-blind, placebo-controlled, parallel-group, dose-comparison colchicine study. Commentary. International Journal of Advances in Rheumatology. 2010. 2010;8(3):120.
38 Jansen TL, Reinders MK, van Roon EN, et al. Benzbromarone withdrawn from the European market: another case of “absence of evidence is evidence of absence”?. Clin Exp Rheumatol. Sep-Oct. 2004;22(5):651. [pmid: 15485024].
39 Janssens HJEM. Gouty arthritis. ORIGINAL (NON-ENGLISH) TITLE. Jichtartritis. Huisarts en Wetenschap. May. 2011;54(5):254-8.
40 Jordan KM, Cameron JS, Snaith M, et al. British Society for Rheumatology and British Health Professionals in rheumatology guideline for the management of gout. Rheumatology. Aug. 2007;46(8):1372-4. PMID:. WOS:000248686800029. [pmid: 17522099].
41 Joseph-Ridge N. Phase II, dose-response, safety and efficacy clinical trial of a new oral xanthine oxidase inhibitor TMX-67 (febuxostat) in subjects with gout. Arthritis Rheum. 2002;46:S142.
42 Kamatani N, Fujimori S, Hada T, et al. Phase II dose-response clinical trial using febuxostat (TMX-67), a novel-type xanthine oxidase/xanthine dehydrogenase inhibitor, for gout and hyperuricemia. Arthritis Rheum. 2003;48:S530.
43 Kamatani N, Fujimori S, Hada T, et al. Febuxostat, a novel non-purine selective inhibitor of xanthine oxidase, in a phase III placebo-controlled double-blind clinical trial in Japanese subjects with gout or hyperuricemia. Arthritis Rheum. 2004;50:S337.
44 Kamatani N, Fujimori S, Hada T, et al. Febuxostat, a novel non-purine selective inhibitor of xanthine oxidase, in an allopurinol-controlled phase III clinical trial in Japanese subjects with gout or hyperuricemia. Arthritis Rheum. 2004;50:S336-7.
45 Kelly VM, Krishnan E. Febuxostat for the treatment of hyperuricemia in patients with gout. International Journal of Clinical Rheumatology. October. 2011;6(5):485-93. FULL TEXT LINK http://dx.doi.org/10.2217/ijr.11.46.
46 Khanna PP, Khanna D. Health-related quality of life and outcome measures in gout. R T. Gout and other crystal arthropathies. Philadelphia, PA. Elsevier. 2011:217-25.
47 Khanna PP, Perez-Ruiz F, Maranian P, et al. Long-term therapy for chronic gout results in clinically important improvements in the health-related quality of life: short form-36 is responsive to change in chronic gout. Rheumatology (Oxford). Apr. 2011;50(4):740-5. [pmid: 21147824].
48 Kuo CF, Grainge MJ, Mallen C, et al. Eligibility for and prescription of urate-lowering treatment in patients with incident gout in England. JAMA. Dec. 24-31. 2014;312(24):2684-6. [pmid: 25536262].
49 Li ZB. Mechanism and Chinese medicine treatment of gout. Zhongguo Zhong Xi Yi Jie He Za Zhi. Apr. 2011;31(4):459-60. [pmid: 21608210].
50 Liberopoulos E, Christides D, Elisaf M. Comparative effects of losartan and irbesartan on serum uric acid in hypertensive patients with hyperuricemia and gout. J Hypertens. Feb. 2002;20(2):347. [pmid: 11821722].
51 Lin KC, Tsao HM, Chen CH, et al. Hypertension was the major risk factor leading to development of cardiovascular diseases among men with hyperuricemia. J Rheumatol. Jun. 2004;31(6):1152-8. [pmid: 15170929].
52 Ling X, Bochu W. A review of phytotherapy of gout: Perspective of new pharmacological treatments. Pharmazie. 2014;69(4):243-56. [pmid: 24791587].
53 Manger B. Gout of the Axial Skeleton. Zeitschrift Fur Rheumatologie. Sep. 2013;72(7):626. PMID:. WOS:000323744400002. [pmid: 23989689].
54 Manger B. Gout and other Crystal Arthropathies. Aktuelle Rheumatologie. Jun. 2013;38(3):180-3. PMID:. WOS:000321336100009.
55 Markel A. Allopurinol-induced DRESS syndrome. Israel Medical Association Journal. October. 2005;7(10):656-60. [medline: 16259349]. (http://www.ncbi.nlm.nih.gov/pubmed/16259349). [pmid: 16259349].
56 McCarthy GM, Barthelemy CR, Veum JA, et al. Influence of antihyperuricemic therapy on the clinical and radiographic progression of gout. Arthritis Rheum. Dec. 1991;34(12):1489-94. [pmid: 1747133].
57 Meltzer M, Pizzi LT, Jutkowitz E. Payer decision-making with limited comparative and cost effectiveness data: the case of new pharmacological treatments for gout. Evid Based Med. Aug. 2012;17(4):105-8. [pmid: 22345034].
58 Monev SD. How should hyperuricemia be treated in a patient with allopurinol hypersensitivity?. Cleve Clin J Med. Jul. 2001;68(7):597-8. [pmid: 11453075].
59 Moreland LW. Febuxostat--treatment for hyperuricemia and gout?. N Engl J Med. Dec. 8. 2005;353(23):2505-7. [pmid: 16339099].
60 Neogi T. Clinical practice. Gout. N Engl J Med. Feb. 3. 2011;364(5):443-52. [pmid: 21288096].
61 NICE. Febuxostat for the management of hyperuricaemia in people with gout. London, UK. December. 2008.
62 Pavelka K. Recommendations of the Czech Society for Rheumatology for the treatment of gouty arthritis. ORIGINAL (NON-ENGLISH) TITLE. Doporuceni Ceske revmatologicke spolecnosti pro lecbu dnave artritidy. Ceska Revmatologie. 2012. 2012;20(2):82-92.
63 Perez-Ruiz F, Hernandez-Baldizon S, Herrero-Beites AM, et al. Risk factors associated with renal lithiasis during uricosuric treatment of hyperuricemia in patients with gout. Arthritis Care Res (Hoboken). Sep. 2010;62(9):1299-305. [pmid: 20506124].
64 Perry ME. Allopurinol and Stevens-Johnson risk. Journal of the Royal College of Physicians of Edinburgh. 2009;39(3):285.
65 Petersel D, Schlesinger N. Treatment of acute gout in hospitalized patients. J Rheumatol. Jul. 2007;34(7):1566-8. [pmid: 17610315].
66 Pullmann R, Rovensky J, Bosmansky K. Gout and hyperuricaemia in elderly. ORIGINAL (NON-ENGLISH) TITLE. Dna vo vyssom veku. Rheumatologia. 2012. 2012;26(2):71-88.
67 Radak-Perovic M, Zlatkovic-Svenda M. Quality of treatment in gouty patients considering EULAR recommendations. Srp Arh Celok Lek. Nov-Dec. 2012;140(11-12):717-21. [pmid: 23350244].
68 Rapado A. Relationship between gout and arterial hypertension. Adv Exp Med Biol. 1974;41:451-9. [pmid: 4832570].
69 Reinders MK, Jansen T. Management of hyperuricemia in gout: focus on febuxostat. Clinical Interventions in Aging. 2010;5:7-18. PMID:. WOS:000208239100002. [pmid: 20169038].
70 Reuss-Borst M. Differential diagnosis and therapy of gout. Med Klin (Munich). Sep. 15. 2009;104(9):710-20. quiz 21-2. [pmid: 19779676].
71 Rho YH, Zhu Y, Choi HK. The epidemiology of uric acid and fructose. Semin Nephrol. Sep. 2011;31(5):410-9. [pmid: 22000647].
72 Richette P, Briere C, Hoenen-Clavert V, et al. Rasburicase for tophaceous gout not treatable with allopurinol: An exploratory study. J Rheumatol. Oct. 2007;34(10):2093-8. PMID:. WOS:000249956100026. [pmid: 17896799].
73 Rundles RW, Metz EN, Silberman HR. Allopurinol in the treatment of gout. Ann Intern Med. Feb. 1966;64(2):229-58. [pmid: 5322938].
74 Saar J, Kirch W. A new application for well-known pharmaceutics--losartan and fenofibrate as potential remedies against gout?. Dtsch Med Wochenschr. Mar. 2014;139(12):608. [pmid: 24619720].
75 Saseen J, Agashivala N, Yadao A, et al. Presence of comorbid diseases and use of concomitant drugs that are contraindicated or could potentially complicate treatment when used with gout drugs in patients with frequent gouty arthritis attacks. Journal of Managed Care Pharmacy. March. 2012;18(2):193-4.
76 Sautner J, Gruber J, Herold M, et al. Austrian 3e-recommendations for diagnosis and management of gout 2013. Wien Klin Wochenschr. Feb. 2014;126(3-4):79-89. [pmid: 24297266].
77 Seegmiller JE. The acute attack of gouty arthritis. Arthritis Rheum. Oct. 1965;8(5):714-25. [pmid: 5859545].
78 Singh JA. Advances in gout: some answers, more questions. Arthritis Res Ther. 2010;12(5):136. [pmid: 20959031].
79 Singh JA. Can racial disparities in optimal gout treatment be reduced? Evidence from a randomized trial. BMC Med. 2012;10:15. [pmid: 22316088].
80 Singh JA, Storgard C, Baumgartner S, et al. Use of high-dose allopurinol to reach serum uric acid targets in patients with gout across multiple countries. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S502.
81 Singh JA, Storgard C, Baumgartner S, et al. High dose allopurinol in France, Germany, Italy, Spain and the UK. Ann Rheum Dis. 2013;72(3):2013-06.
82 Söllner B. Long-term treatment with febuxostat protects against serious complications of systemic hyperuricemia. Langzeittherapie mit febuxostat schützt vor schwerwiegenden folgen der systemischen hyperurikämie. 2012;21(2):53-4.
83 Stevenson M, Pandor A. Febuxostat for the treatment of hyperuricaemia in people with gout: a single technology appraisal. Health Technol Assess. Oct. Suppl 3. 2009;13:37-42. [pmid: 19846027].
84 Taylor CT, Brooks NC, Kelley KW. Corticotropin for acute management of gout. Ann Pharmacother. Mar. 2001;35(3):365-8. [pmid: 11261536].
85 Thompson GR, Duff IF, Robinson WD, et al. Long term uricosuric therapy in gout. Arthritis Rheum. Aug. 1962;5:384-96. [pmid: 13920871].
86 Thurston MM, Phillips BB, Bourg CA. Safety and efficacy of allopurinol in chronic kidney disease. Ann Pharmacother. Nov. 2013;47(11):1507-16. [pmid: 24259601].
87 Tikly M, Bellingan A, Lincoln D, et al. Risk factors for gout: a hospital-based study in urban black South Africans. Rev Rhum Engl Ed. Apr. 1998;65(4):225-31. [pmid: 9599790].
88 Underwood M. Gout. Clin Evid (Online). 2011;2011. [pmid: 21575286].
89 Underwood M. Gout. BMJ Clin Evid. 2015;2015. [pmid: 25789770].
90 Uri DS, Biavis M. Colchicine neuromyopathy. J Clin Rheumatol. Jun. 1996;2(3):163-6. [pmid: 19078054].
91 van der Heijde D, Buchbinder R. Introduction: diagnosis and management of gout. Systematic literature reviews of the 3e Initiative 2011-2012. J Rheumatol Suppl. Sep. 2014;92:1-2. [pmid: 25180121].
92 Villazor-Isidro EBS, Brojan JCG, Pega-Flores CJR, et al. Urate lowering efficacy of febuxostat versus allopurinol in hyperuricemic patients with gout. Phillippine Journal of Internal Medicine. 2014;52(1).
93 White WB, Chohan S, Dabholkar A, et al. Cardiovascular safety of febuxostat and allopurinol in patients with gout and cardiovascular comorbidities. Am Heart J. Jul. 2012;164(1):14-20. [pmid: 22795277].
94 Yamanaka H. Revised version of Guideline for the Management of Hyperuricemia and Gout. Nihon Rinsho. Apr. 2008;66(4):643-6. [pmid: 18409508].
95 Yang LP. Oral colchicine (Colcrys): in the treatment and prophylaxis of gout. Drugs. Aug. 20. 2010;70(12):1603-13. [pmid: 20687623].
96 Yu KH. Febuxostat: a novel non-purine selective inhibitor of xanthine oxidase for the treatment of hyperuricemia in gout. Recent Pat Inflamm Allergy Drug Discov. Feb. 2007;1(1):69-75. [pmid: 19075968].
97 Yue TF, Gutman AB. Effect of Allopurinol (4-Hydroxypyrazolo-(3,4-D)Pyrimidine) on Serum and Urinary Uric Acid in Primary and Secondary Gout. Am J Med. Dec. 1964;37:885-98. [pmid: 14246090].

## Study Design (N=66)

1 Annemans L, Spaepen E, Gaskin M, et al. Gout in the UK and Germany: prevalence, comorbidities and management in general practice 2000-2005. Ann Rheum Dis. Jul. 2008;67(7):960-6. [pmid: 17981913].
2 Bartels EC, Matossian GS. Gout: six-year follow-up on probenecid (benemid) therapy. Arthritis Rheum. Jun. 1959;2(3):193-202. [pmid: 13662213].
3 Bull PW, Scott JT. Intermittent control of hyperuricemia in the treatment of gout. J Rheumatol. Sep. 1989;16(9):1246-8. [pmid: 2681764].
4 Chohan S. Safety and efficacy of febuxostat treatment in subjects with gout and severe allopurinol adverse reactions. J Rheumatol. Sep. 2011;38(9):1957-9. [pmid: 21724706].
5 Choi HJ, Lee CH, Choi ST, et al. Prophylactic duration and serum uric acid level are associated with gout flare during urate lowering treatment. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S854-S5.
6 Choi HJ, Lee CH, Lee JH, et al. Clinical factors affecting gout flare during urate lowering therapy. International Journal of Rheumatic Diseases. April. SUPPL. 1. 2014;17:108.
7 Coman-Wright N, Chapman PT, O'Donnell JL, et al. Allopurinol dose above creatinine clearance based dose is safe and effective in gout-compliance, efficacy and safety at 2 and 3 years. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S507.
8 Crittenden DB, Kimmel JN, Pike VC, et al. Colchicine use and the risk of myocardial infarction among gout patients: Interim results from a VA retrospective cohort study. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S499.
9 Crittenden DB, White CJ, DeBerardine M, et al. Colchicine is associated with a decreased rate of myocardial infarction in gout patients: Interim results from a retrospective cohort study. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S71-S2.
10 Dalbeth N, House M, Horne A, et al. What factors are associated with target serum urate concentrations in patients with gout?. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S808.
11 Dalbeth N, Kumar S, Stamp L, et al. Dose adjustment of allopurinol according to creatinine clearance does not provide adequate control of hyperuricemia in patients with gout. J Rheumatol. Aug. 2006;33(8):1646-50. [pmid: 16783857].
12 Daoussis D, Antonopoulos I, Yiannopoulos G, et al. Acth as first line treatment for gout in hospitalized patients. Ann Rheum Dis. 2013;71(3):2012-06.
13 Darmawan J, Rasker JJ, Nuralim H. The effect of control and self-medication of chronic gout in a developing country. Outcome after 10 years. J Rheumatol. Nov. 2003;30(11):2437-43. [pmid: 14677190].
14 DeBerardine M, Fisher MC, Keenan RT, et al. Low-dose allopurinol promotes greater serum urate lowering in gout patients with chronic kidney disease vs normal renal function. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S72.
15 Dessein PH, Shipton EA, Stanwix AE, et al. Beneficial effects of weight loss associated with moderate calorie/carbohydrate restriction, and increased proportional intake of protein and unsaturated fat on serum urate and lipoprotein levels in gout: a pilot study. Ann Rheum Dis. Jul. 2000;59(7):539-43. [pmid: 10873964].
16 Feher MD, Hepburn AL, Hogarth MB, et al. Fenofibrate enhances urate reduction in men treated with allopurinol for hyperuricaemia and gout. Rheumatology (Oxford). Feb. 2003;42(2):321-5. [pmid: 12595630].
17 Fernandez C, Noguera R, Gonzalez JA, et al. Treatment of acute attacks of gout with a small dose of intraarticular triamcinolone acetonide. J Rheumatol. Oct. 1999;26(10):2285-6. [pmid: 10529162].
18 Gandhi PK, Gentry WM, Bottorff MB. Cardiovascular thromboembolic events associated with febuxostat: Investigation of cases from the FDA adverse event reporting system database. Seminars in Arthritis and Rheumatism. Jun. 2013;42(6):562-6. PMID:. WOS:000320972300002. [pmid: 23352248].
19 Garbe E, Suissa S, LeLorier J. Exposure to allopurinol and the risk of cataract extraction in elderly patients. Arch Ophthalmol. Dec. 1998;116(12):1652-6. [pmid: 9869797].
20 Graham GG, Kannangara DR, Stocker SL, et al. Understanding the dose-response relationship of allopurinol: predicting the optimal dosage. Br J Clin Pharmacol. Dec. 2013;76(6):932-8. [pmid: 23590252].
21 Groff GD, Franck WA, Raddatz DA. Systemic steroid therapy for acute gout: a clinical trial and review of the literature. Semin Arthritis Rheum. Jun. 1990;19(6):329-36. [pmid: 2196674].
22 Harrold LR, Etzel C, Gibofsky A, et al. Sex differences in gout evaluation and management. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S506.
23 Hatoum H, Khanna D, Shiozawa A, et al. Outcome of gout patients placed on febuxostat after failing to reach serum urate target with allopurinol. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S855.
24 Hiramitsu S, Ishiguro Y, Matsuyama H, et al. Febuxostat (Feburic tablet) in the management of hyperuricemia in a general practice cohort of Japanese patients with a high prevalence of cardiovascular problems. Clin Exp Hypertens. 2013. Oct. 28. [pmid: 24164405].
25 Huang CH, Wang MC, Yen CT, et al. The effectiveness and safety of febuxostat for chronic kidney disease patients with gout and hyperuricemia. Pharmacoepidemiology and Drug Safety. October. SUPPL. 1. 2014;23:435-6. [pmid: 24706417].
26 Huded S, Gummadi SV, Sankh K, et al. Evaluation of guduchi yoga in the management of vatarakta (gouty arthritis): A clinical study. International Journal of Research in Ayurveda and Pharmacy. September/October. 2013;4(5):688-92. FULL TEXT LINK http://dx.doi.org/10.7897/2277-4343.04512.
27 Hung SI, Chung WH, Liou LB, et al. HLA-B*5801 allele as a genetic marker for severe cutaneous adverse reactions caused by allopurinol. Proc Natl Acad Sci U S A. Mar. 15. 2005;102(11):4134-9. [pmid: 15743917].
28 Jennings CG, Mackenzie IS, Flynn R, et al. Up-titration of allopurinol in patients with gout. Semin Arthritis Rheum. 2014. Jan. 23. [pmid: 24560169].
29 Joo K, Park W, Kwon SR, et al. The effect of uric acid lowering therapy in preventing comorbidity and acute attack of gout; A retrospective study. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S500.
30 Khanna P, Hatoum H, Lin SJ, et al. Outcome of allopurinol or febuxostat treatment in gout patients naive to urate-lowering therapy. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S857.
31 Khoo BP, Leow YH. A review of inpatients with adverse drug reactions to allopurinol. Singapore Med J. Apr. 2000;41(4):156-60. [pmid: 11063179].
32 Kim SC, Newcomb C, Margolis D, et al. Severe cutaneous reactions requiring hospitalization in allopurinol initiators: A population-based cohort study. Arthritis Care and Research. April. 2013;65(4):578-84. [medline: 22899369]. (http://www.ncbi.nlm.nih.gov/pubmed/22899369). FULL TEXT LINK http://dx.doi.org/10.1002/acr.21817. [pmid: 22899369].
33 Kim SC, Schmidt BMW, Liu J, et al. Clinical and health care use characteristics of patients newly prescribed allopurinol, febuxostat and colchicine for gout. Pharmacoepidemiology and Drug Safety. October. SUPPL. 1. 2013;22:55. [pmid: 23135758].
34 Kim SC, Schneeweiss S, Choudhry N, et al. Risk of cardiovascular disease and use of xanthine oxidase inhibitors for gout. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S729.
35 Kim SC, Solomon DH. Management of gout in patients hospitalized with heart failure. Ann Rheum Dis. 2013;71(3):2012-06.
36 Komatsu T. Treatment of acute gouty attack with local infiltration of Kenacort-A and the study of gout and hyperuricemia at the Tanabe National Hospital during 1967. Iryo. Jan. 1969;23(1):54-61. [pmid: 5783218].
37 Lee SS, Lin HY, Wang SR, et al. Allopurinol hypersensitivity syndrome. Zhonghua Min Guo Wei Sheng Wu Ji Mian Yi Xue Za Zhi. Aug. 1994;27(3):140-7. [pmid: 9747344].
38 Liu CS, Brown NA, Leonard TJ, et al. The prevalence and morphology of cataract in patients on allopurinol treatment. Eye (Lond). 1988;2(Pt 6):600-6. [pmid: 3256496].
39 Lu N, Choi H, Dubreuil M, et al. Can allopurinol survival impact reverse depending on patients' characteristics? A propensity-score-based subgroup analysis. Arthritis Rheum. October. SUPPL. 10. 2014;66:S825.
40 Moon KW, Kim J, Kim JH, et al. Risk factors for acute kidney injury by non-steroidal anti-inflammatory drugs in patients with hyperuricaemia. Rheumatology (Oxford). Dec. 2011;50(12):2278-82. [pmid: 22019809].
41 Morlock R, Kern DM, Tunceli O, et al. Rate of serum uric acid (SUA) assessment in gout patients treated with urate-lowering therapy: Treating to target?. Arthritis Rheum. October. SUPPL. 10. 2014;66:S398-S9.
42 Neogi T, Chen C, Niu J, et al. Effectiveness of prophylaxis with anti-gout medications on risk of gout attacks. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S61-S2.
43 Paisansinsup T, Breitenstein MK, Schousboe JT. Association between adverse reactions to allopurinol and exposures to high maintenance doses: implications for management of patients using allopurinol. J Clin Rheumatol. Jun. 2013;19(4):180-6. [pmid: 23669799].
44 Panomvana D, Sripradit S, Angthararak S. Higher therapeutic plasma oxypurinol concentrations might be required for gouty patients with chronic kidney disease. J Clin Rheumatol. Feb. 2008;14(1):6-11. [pmid: 18431090].
45 Perez-Ruiz F, Calabozo M, Herrero-Beites AM, et al. Improvement of renal function in patients with chronic gout after proper control of hyperuricemia and gouty bouts. Nephron. Nov. 2000;86(3):287-91. [pmid: 11096285].
46 Perez-Ruiz F, Calabozo M, Pijoan JI, et al. Effect of urate-lowering therapy on the velocity of size reduction of tophi in chronic gout. Arthritis Rheum. Aug. 2002;47(4):356-60. [pmid: 12209479].
47 Perez-Ruiz F, Hernando I, Villar I, et al. Correction of allopurinol dosing should be based on clearance of creatinine, but not plasma creatinine levels: another insight to allopurinol-related toxicity. J Clin Rheumatol. Jun. 2005;11(3):129-33. [pmid: 16357730].
48 Perez-Ruiz F, Herrero-Beites AM. Increase of thyroid stimulating hormone in patients on febuxostat treatment. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S809.
49 Perez-Ruiz F, Herrero-Beites AM. Liver outcomes in gout patients treated with febuxostat and altered liver function tests. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S847.
50 Pui K, Gow PJ, Dalbeth N. Efficacy and tolerability of probenecid as urate-lowering therapy in gout; clinical experience in high-prevalence population. J Rheumatol. Jun. 2013;40(6):872-6. [pmid: 23457380].
51 Radak-Perovic M, Zlatkovic-Svenda M. The efficacy and tolerability of allopurinol dose escalation in patients with gout. Srp Arh Celok Lek. May-Jun. 2013;141(5-6):333-6. [pmid: 23858803].
52 Ryu HJ, Song R, Kim HW, et al. Clinical risk factors for adverse events in allopurinol users. J Clin Pharmacol. Feb. 2013;53(2):211-6. [pmid: 23436266].
53 Shah A, Sundy JS. Predictors of outcomes in gout with comorbid chronic kidney disease. Arthritis and Rheumatism. 2011;63(10):2011-11.
54 Shi L, Wang L, Zhao Y, et al. Association between colchicine use and risk of incident diabetes among veterans with gout. Diabetes. July. SUPPL. 1. 2013;62:A407.
55 Singh J, Pandya BJ, Gomez RG, et al. Comparative effectiveness of allopurinol and febuxostat in lowering serum uric acid in a large U.S. Commercially insured population. Journal of Managed Care Pharmacy. September. 2011;17(7):555.
56 Stamp LK, O'Donnell JL, Zhang M, et al. Using allopurinol above the dose based on creatinine clearance is effective and safe in patients with chronic gout, including those with renal impairment. Arthritis Rheum. Feb. 2011;63(2):412-21. [pmid: 21279998].
57 Tausche AK, Christoph M, Forkmann M, et al. As compared with allopurinol only febuxostat preserves vascular function in patients with chronic tophaceous gout. Ann Rheum Dis. 2013;72(3):2013-06.
58 Todd BA, Billups SJ, Delate T, et al. Assessment of the association between colchicine therapy and serious adverse events. Pharmacotherapy. Nov. 2012;32(11):974-80. [pmid: 23019065].
59 Vazquez-Mellado J, Morales EM, Pacheco-Tena C, et al. Relation between adverse events associated with allopurinol and renal function in patients with gout. Ann Rheum Dis. Oct. 2001;60(10):981-3. [pmid: 11557658].
60 Wang W, Bhole V, Krishnan E. Gout medications and the risk for incident coronary heart disease and stroke: The framingham heart study. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S507.
61 Wei L, Mackenzie IS, Chen Y, et al. Impact of allopurinol use on urate concentration and cardiovascular outcome. Br J Clin Pharmacol. Apr. 2011;71(4):600-7. [pmid: 21395653].
62 Werlen D, Gabay C, Vischer TL. Corticosteroid therapy for the treatment of acute attacks of crystal-induced arthritis: an effective alternative to nonsteroidal antiinflammatory drugs. Rev Rhum Engl Ed. Apr. 1996;63(4):248-54. [pmid: 8738443].
63 Whelton A, MacDonald PA, Hunt B, et al. The impact on renal function of quantitative serum urate reduction in gout patients. Arthritis and Rheumatism. 2011;63(10):2011-11.
64 Whelton A, Macdonald PA, Zhao L, et al. Renal function in gout: long-term treatment effects of febuxostat. J Clin Rheumatol. Jan. 2011;17(1):7-13. [pmid: 21169856].
65 Yu TF. The effect of allopurinol in primary and secondary gout. Arthritis Rheum. Oct. 1965;8(5):905-6. [pmid: 5323683].
66 Zhang Y, Neogi T, Chen C, et al. Low-dose aspirin use and recurrent gout attacks. Ann Rheum Dis. Feb. 1. 2014;73(2):385-90. [pmid: 23345599].

## Case reports (N=51)

1 Abodunde OA, LevakaVeera RR, Desai R, et al. Colchicine toxicity precipitated by interaction with sunitinib. J Clin Pharm Ther. Jun. 2013;38(3):243-5. [pmid: 23448320].
2 Ahmad S, Bhanji A, Pal S, et al. Irreversible sensorineural hearing loss: an unusual side effect of non-steroidal anti-inflammatory drugs. Int J Clin Pharmacol Ther. Aug. 2010;48(8):514-6. [pmid: 20650042].
3 Akintan AI, Nurpeisov V, Patel B, et al. An unusual approach to aggressive behavior in dementia patients. Journal of the American Geriatrics Society. April. SUPPL. 4. 2012;60:S134.
4 Avila Castellano R, Cimbollek S, Ortega Camarero M, et al. Successful approach of breakthrough reaction during desensitisation procedure of a fixed drug eruption to allopurinol. Allergy: European Journal of Allergy and Clinical Immunology. June. SUPPL. 94. 2011;66:605. [pmid: 21241315].
5 Bouquie R, Deslandes G, Renaud C, et al. Colchicine-related toxicity within therapeutic dose: Be careful to the interactions. Fundamental and Clinical Pharmacology. April. SUPPL. 1. 2011;25:22.
6 Cantarini L, Volpi N, Galeazzi M, et al. Colchicine myopathy and neuromyopathy: two cases with different characteristics. J Clin Rheumatol. Aug. 2010;16(5):229-32. [pmid: 20661070].
7 Carnovale C, Venegoni M, Clementi E. Allopurinol overuse in asymptomatic hyperuricemia: a teachable moment. JAMA Intern Med. Jul. 2014;174(7):1031-2. [pmid: 24798999].
8 Chen HW, Chen KC, Chen JS. Colchicine and NSAID combination causing acute kidney injury. J Coll Physicians Surg Pak. Nov. 2012;22(11):737-9. [pmid: 23146861].
9 Childs L, Dow C. Allopurinol-induced hepatomegaly. BMJ Case Reports. 2012. FULL TEXT LINK http://dx.doi.org/10.1136/bcr-2012-007283.
10 Dag E, Turkel Y, Gokce B. Colchicine-related polyneuropathy and multiple organ failure. ORIGINAL (NON-ENGLISH) TITLE. Kolsisin ile iliskili polinoropati ve multi-organ yetmezligi. Turk Noroloji Dergisi. 2013. 2013;19(2):69-71. FULL TEXT LINK http://dx.doi.org/10.4274/Tnd.04557.
11 Daoussis D, Antonopoulos I, Yiannopoulos G, et al. ACTH as first line treatment for acute gout in 181 hospitalized patients. Joint Bone Spine. May. 2013;80(3):291-4. PMID:. WOS:000320602500013. [pmid: 23195793].
12 Delrio FG, Park Y, Herzlich B, et al. Case report: diclofenac-induced rhabdomyolysis. Am J Med Sci. Aug. 1996;312(2):95-7. [pmid: 8701974].
13 Dupont P, Hunt I, Goldberg L, et al. Colchicine myoneuropathy in a renal transplant patient. Transpl Int. Jul. 2002;15(7):374-6. [pmid: 12122515].
14 Eyer-Silva Wde A, Salgado MC, Pinto JF, et al. Acute gouty arthritis as a manifestation of immune reconstitution inflammatory syndrome after initiation of antiretroviral therapy. Rev Inst Med Trop Sao Paulo. Aug. 2012;54(4):231-3. [pmid: 22850997].
15 Fam AG, Lewtas J, Stein J, et al. Desensitization to allopurinol in patients with gout and cutaneous reactions. Am J Med. Sep. 1992;93(3):299-302. [pmid: 1388001].
16 Fathallah N, Atig A, Slim R, et al. Allopurinol-induced hypersensitivity vasculitis and bicytopenia. Fundamental and Clinical Pharmacology. April. SUPPL. 1. 2011;25:37.
17 Findling JW, Beckstrom D, Rawsthorne L, et al. Indomethacin-induced hyperkalemia in three patients with gouty arthritis. JAMA. Sep. 5. 1980;244(10):1127-8. [pmid: 7411769].
18 Flores SM, Hidalgo LG, Topete RO. Erithrodermia as presentation of DRESS syndrome associated with allopurinol. A report of a case. ORIGINAL (NON-ENGLISH) TITLE. Eritrodermia como presentacion del sindrome DRESS asociado con alopurinol. Comunicacion de un caso. Dermatologia Revista Mexicana. March-April. 2010;54(2):104-7.
19 Fuessl HS. Uric acid 8.4 in an asymptomatic patient. Does he need medication?. MMW Fortschr Med. Jun. 21. O. Suppl 2. 2012;154:22. [pmid: 22916420].
20 Galler M, Folkert VW, Schlondorff D. Reversible acute renal insufficiency and hyperkalemia following indomethacin therapy. JAMA. Jul. 10. 1981;246(2):154-5. [pmid: 7017180].
21 Garrouste C, Philipponnet C, Kaysi S, et al. Severe colchicine intoxication in a renal transplant recipient on cyclosporine. Transplant Proc. Nov. 2012;44(9):2851-2. [pmid: 23146540].
22 Ghosh PS, Emslie-Smith AM, Dimberg EL. Colchicine-induced myoneuropathy mimicking polyradiculoneuropathy. Journal of Clinical Neuroscience. February. 2014;21(2):331-2. FULL TEXT LINK http://dx.doi.org/10.1016/j.jocn.2013.01.019. [pmid: 24071053].
23 Goldfarb E, Smyth CJ. Effects of allopurinol, a xanthine oxidase inhibitor, and sulfinpyrazone upon the urinary and serum urate concentrations in eight patients with tophaceous gout. Arthritis Rheum. Jun. 1966;9(3):414-23. [pmid: 5938056].
24 Gordon K, Miteva M, Torchia D, et al. Allopurinol-induced palisaded neutrophilic and granulomatous dermatitis. Cutan Ocul Toxicol. Dec. 2012;31(4):338-40. [pmid: 22250812].
25 Hande KR. Evaluation of a thiazide-allopurinol drug interaction. Am J Med Sci. Oct. 1986;292(4):213-6. [pmid: 3752167].
26 Hsu WC, Chen WH, Chang MT, et al. Colchicine-induced acute myopathy in a patient with concomitant use of simvastatin. Clin Neuropharmacol. Sep-Oct. 2002;25(5):266-8. [pmid: 12410059].
27 Ibie NC, Alper AB. She is all nulldressednull up: A case of allopurinol deadly complication. Journal of Investigative Medicine. February. 2014;62(2):504-5.
28 Justiniano M, Dold S, Espinoza LR. Rapid onset of muscle weakness (rhabdomyolysis) associated with the combined use of simvastatin and colchicine. J Clin Rheumatol. Oct. 2007;13(5):266-8. [pmid: 17921794].
29 Kamal T, Elnikety S, Mashaly H, et al. Acute compartment syndrome of the forearm as a rare complication of toxic epidermal necrolysis: a case report. J Med Case Rep. 2012;6:84. [pmid: 22433469].
30 Kang Y, Kim MJ, Jang HN, et al. Rhabdomyolysis associated with initiation of febuxostat therapy for hyperuricaemia in a patient with chronic kidney disease. J Clin Pharm Ther. Jun. 2014;39(3):328-30. [pmid: 24612195].
31 Kinyo A, Lakatos A, Varga A, et al. Allopurinol-induced hypersensitivity syndrome. Orv Hetil. Apr. 15. 2012;153(15):586-91. [pmid: 22472359].
32 Kobayashi S, Ogura M, Hosoya T. Acute neutropenia associated with initiation of febuxostat therapy for hyperuricaemia in patients with chronic kidney disease. J Clin Pharm Ther. Jun. 2013;38(3):258-61. [pmid: 23506426].
33 Kuritzky L, Panchal R. Gout: nonsteroidal anti-inflammatory drugs and colchicine to prevent painful flares during early urate-lowering therapy. J Pain Palliat Care Pharmacother. Dec. 2010;24(4):397-401. [pmid: 21133750].
34 Laurisch S, Jaedtke M, Demir R, et al. Allopurinol-induced hypersensitivity syndrome resulting in death. Med Klin (Munich). Apr. 2010;105(4):262-6. [pmid: 20455046].
35 Le Bellec ML, de la Gastine B, Mosquet B, et al. Colchicine intoxication in four elderly patients: How to prevent it?. Revue De Medecine Interne. Sep. 2009;30(9):783-8. PMID:. WOS:000271770100007. [pmid: 19362394].
36 Lee HJ, Kim HS, Park YM, et al. Fixed drug eruption due to allopurinol: positive oral provocation. Ann Dermatol. Dec. 2011;23(Suppl 3):S402-3. [pmid: 22346289].
37 Lockard O Jr., Harmon C, Nolph K, et al. Allergic reaction to allopurinol with cross-reactivity to oxypurinol. Ann Intern Med. Sep. 1976;85(3):333-5. [pmid: 134655].
38 Lupton G, Odom R. Severe allopurinol hypersensitivity syndrome. J Am Acad Dermatol. 1979;72:1361-8.
39 Marukawa Y, Oishi N, Mizukoshi E, et al. A case of subacute hepatic failure associated with benzbromarone. [in Japanese]. Acta Hepatol Jpn. 2004;24:354-9.
40 Morris I, Varughese G, Mattingly P. Colchicine in acute gout. BMJ. Nov. 29. 2003;327(7426):1275-6. [pmid: 14644973].
41 Ray SM, Hall MD, Stevens AB. Intractable epistaxis with febuxostat. Hospital Pharmacy. June. 2012;47(6):460-2. FULL TEXT LINK http://dx.doi.org/10.1310/hpj4706-460.
42 Roef MJ, van der Poel H, van der Laken CJ, et al. Colchicine must be stopped before imaging with [18F]-methylcholine PET/CT. Nucl Med Commun. Dec. 2010;31(12):1075-7. [pmid: 21089227].
43 Sarullo FM, Americo L, Di Franco A, et al. Rhabdomyolysis induced by co-administration of fluvastatin and colchicine. Monaldi Arch Chest Dis. Sep. 2010;74(3):147-9. [pmid: 21110512].
44 Sipila R, Skrifvars B, Tornroth T. Reversible non-oliguric impairment of renal function during azapropazone treatment. Scand J Rheumatol. 1986;15(1):23-6. [pmid: 3961430].
45 Teo WL, Pang SM, Koh HY. Allopurinol hypersensitivity syndrome with acute generalized exanthematous pustulosis manifestations. Cutan Ocul Toxicol. Sep. 2011;30(3):243-4. [pmid: 21345152].
46 Ting JY. Acute pancreatitis related to therapeutic dosing with colchicine: a case report. J Med Case Rep. 2007;1:64. [pmid: 17692130].
47 Tinoco P, Saraiva AA, De Oliveira GMV, et al. A case report: Stevens johnson syndrome related to allopurinol. International Archives of Otorhinolaryngology. 2014;18(1):2014-08.
48 Watanabe Y, Matsukura S, Isoda Y, et al. Case of toxic epidermal necrolysis induced by allopurinol with human herpesvirus-6 reactivation. Acta Dermato-Venereologica. 2013. 2013;93(6):731-2. FULL TEXT LINK http://dx.doi.org/10.2340/00015555-1610. [pmid: 23604033].
49 Wilbur K, Makowsky M. Colchicine myotoxicity: case reports and literature review. Pharmacotherapy. Dec. 2004;24(12):1784-92. [pmid: 15585444].
50 Wu JX. Clinical experience of direct moxibustion treatment for gouty arthritis. Zhongguo Zhen Jiu. Sep. 2014;34(9):851-2. [pmid: 25509729].
51 Zagler B, Kaneppele A, Pattis P, et al. Patient risk factors and adverse drug interactions in the treatment of acute gouty arthritis in the elderly: A case report. Cases Journal. 2009;2(4). FULL TEXT LINK http://dx.doi.org/10.1186/1757-1626-2-6602.

## Population not of interest (N=8)

1 Abbott KC, Kimmel PL, Dharnidharka V, et al. New-onset gout after kidney transplantation: incidence, risk factors and implications. Transplantation. Nov. 27. 2005;80(10):1383-91. [pmid: 16340779].
2 Fairbanks LD, Cameron JS, Venkat-Raman G, et al. Early treatment with allopurinol in familial juvenile hyerpuricaemic nephropathy (FJHN) ameliorates the long-term progression of renal disease. QJM. Sep. 2002;95(9):597-607. [pmid: 12205338].
3 Feig DI, Soletsky B, Johnson RJ. Effect of allopurinol on blood pressure of adolescents with newly diagnosed essential hypertension: a randomized trial. JAMA. Aug. 27. 2008;300(8):924-32. [pmid: 18728266].
4 Kao MP, Ang DS, Gandy SJ, et al. Allopurinol benefits left ventricular mass and endothelial dysfunction in chronic kidney disease. J Am Soc Nephrol. Jul. 2011;22(7):1382-9. [pmid: 21719783].
5 Munar MY, Singh H. Drug dosing adjustments in patients with chronic kidney disease. Am Fam Physician. May. 15. 2007;75(10):1487-96. [pmid: 17555141].
6 Shelmadine B, Bowden RG, Wilson RL, et al. The effects of lowering uric acid levels using allopurinol on markers of metabolic syndrome in end-stage renal disease patients: a pilot study. Anadolu Kardiyol Derg. Oct. 2009;9(5):385-9. [pmid: 19819789].
7 Solak Y, Atalay H, Alibasic H, et al. Colchicine toxicity in ESRD patients: Hype or reality?. NDT Plus. June. SUPPL. 3. 2010;3:iii516.
8 Talaat KM, el-Sheikh AR. The effect of mild hyperuricemia on urinary transforming growth factor beta and the progression of chronic kidney disease. Am J Nephrol. 2007;27(5):435-40. [pmid: 17622758].

## Gout diagnosis only (N=6)

1 Choi HK, Al-Arfaj AM, Eftekhari A, et al. Dual energy computed tomography in tophaceous gout. Ann Rheum Dis. Oct. 2009;68(10):1609-12. [pmid: 19066180].
2 Dalbeth N, Clark B, Gregory K, et al. Computed tomography measurement of tophus volume: comparison with physical measurement. Arthritis Rheum. Apr. 15. 2007;57(3):461-5. [pmid: 17394233].
3 Diaz M, Calvo E, Chalem M, et al. Usefulness of musculoskeletal high resolution ultrasonography (HRU) in routine clinical evaluation of nullreal worldnull patients with gout. Ann Rheum Dis. 2013;72(3):2013-06.
4 Diaz M, Calvo E, Chalem M, et al. Musculoskeletal high resolution ultrasonography assessment in real life outpatients with gout. Ann Rheum Dis. 2013;71(3):2012-06.
5 Kissin EY, Nishio J, Yang M, et al. Self-directed learning of basic musculoskeletal ultrasound among rheumatologists in the United States. Arthritis Care Res (Hoboken). Feb. 2010;62(2):155-60. [pmid: 20191513].
6 Pascual E, Batlle-Gualda E, Martinez A, et al. Synovial fluid analysis for diagnosis of intercritical gout. Ann Intern Med. 1999;131(10):756-9. [pmid: 10577299].

## Biologics not within scope of review (N=64)

1 Alten R, Bloch M, Bardin T, et al. Efficacy and safety of canakinumab vs triamcinolone acetonide in persistent or elderly gouty arthritis patients. Ann Rheum Dis. 2013;71(3):2012-06.
2 Alten R, So A, Kivitz A, et al. Efficacy of canakinumab on re-treatment in gouty arthritis patients with limited treatment options: 24-week results from-relieved and-relieved-II studies. Arthritis and Rheumatism. 2011;63(10):2011-11.
3 Avdoshin VP, Andriukhin MI, Annenkov AV, et al. Treatment and metaphylaxis of gout complicated by nephropathy and urolithiasis. Urologiia. Sep-Oct. 2012;(5):18-20. [pmid: 23342610].
4 Azevedo VF, Buiar PG, Giovanella LH, et al. Allopurinol, benzbromarone, or a combination in treating patients with gout: analysis of a series of outpatients. Int J Rheumatol. 2014;2014:263720. [pmid: 24719620].
5 Bach M, Park J, Ghosh P, et al. The treatment of acute gouty arthritis in complex hospitalized patients with Anakinra. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S64.
6 Bahrt K, Yeo A, Howson T, et al. Uric acid levels as a biomarker of efficacy and safety in patients treated with pegloticase: Lessons learned from us clinical experience. Ann Rheum Dis. 2013;72(3):2013-06.
7 Bahrt KM, Yeo AE, Howson TL, et al. Post-marketing safety surveillance data reveals patterns of use for pegloticase in refractory chronic gout. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S73-S4.
8 Bantia S, Harman L, Parker C, et al. Ulodesine (BCX4208) add-on therapy to allopurinol 300mg lowers hypoxanthine and xanthine plasma levels in a dose-dependent fashion: Results from a 12-week randomized controlled trial in patients with gout. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S698.
9 Bantia S, Parker C, Harman L, et al. Effect of BCX4208 add-on therapy to allopurinol 300 mg on plasma hypoxanthine and xanthine concentrations in gout patients. Ann Rheum Dis. 2013;71(3):2012-06.
10 Baraf H, Gutierrez-Urena S, Vazquez-Mellado J, et al. Progressive reduction in tophus burden with pegloticase therapy in patients with chronic gout refractory to conventional therapy. Zeitschrift fur Rheumatologie. September. SUPPL. 2. 2012;71:117.
11 Baraf H, Yood R, Sundy J, et al. Association of infusion reactions and serum urate level in pegloticase-treated patients with refractory chronic gout. Zeitschrift fur Rheumatologie. September. SUPPL. 2. 2012;71:114.
12 Baraf H, Yood R, Sundy J, et al. Understanding infusion reactions and their relationship to urate lowering in patients with refractory chronic gout (RCG): Pooled data from pegloticase trials. Ann Rheum Dis. 2013;71(3):2012-06.
13 Baraf H, Yood RA, Sundy JS, et al. Characterization and management of infusion reactions in refractory chronic gout (RCG) treated with pegloticase (PGL). Arthritis and Rheumatism. 2011;63(10):2011-11.
14 Baraf HSB, Yood RA, Sundy JS, et al. Serum uric acid as a biomarker for mitigation of infusion reactions in patients treated with pegloticase for refractory chronic gout. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S813-S4.
15 Barclay CA, Traballi CA. Evaluation of tenoxicam in rheumatology--clinical trial results in Argentina and Brazil. Eur J Rheumatol Inflamm. 1987;9(2):26-50. [pmid: 3329108].
16 Bardin T, Alten R, Schlesinger N, et al. Tophi spread, acute joints and flare frequency predict reflare in gouty arthritis: A spatio-temporal model. Ann Rheum Dis. 2013;71(3):2012-06.
17 Bardin T, So A, Alten R, et al. Efficacy and safety of canakinumab vs triamcinolone acetonide in patients with gouty arthritis unable to use nonsteroidal anti-inflammatory drugs and colchicine, and on stable urate lowering therapy (ULT) or unable to use ULT. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S811-S2.
18 Becker MA, Baraf HSB, Yood RA, et al. Clinical efficacy outcomes with up to 3 years of pegloticase treatment for refractory chronic gout. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S69.
19 Becker MA, Gonter NJ, Pope JE, et al. Complete tophus response in patients with chronic gout initiating pegloticase treatment. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S812.
20 Becker MA, Hollister AS, Terkeltaub R, et al. BCX4208 added to allopurinol increases response rates in patients with gout who fail to reach goal range serum uric acid on allopurinol alone: A randomized, double-blind, placebo-controlled trial. Ann Rheum Dis. 2013;71(3):2012-06.
21 Becker MA, Hollister AS, Terkeltaub R, et al. BCX4208 combined with allopurinol increases response rates in patients with gout who fail to reach goal range serum urate on allopurinol alone: A randomized, double-blind, placebo-controlled trial. Arthritis and Rheumatism. December. 2011;63(12):4046.
22 Calogiuri GF, Satriano F, Muratore L, et al. Therapeutic alternatives in a patient with DRESS syndrome induced by allopurinol. J Investig Allergol Clin Immunol. 2009;19(4):333-4. [pmid: 19639739].
23 Daymond TJ, Laws D, Templeton JS. A comparison of azapropazone and allopurinol in the treatment of chronic gout. Br J Clin Pharmacol. 1983;15:157.
24 Evans TI, Wheeler MT, Small RE, et al. A comprehensive investigation of inpatient intravenous colchicine use shows more education is needed. J Rheumatol. Jan. 1996;23(1):143-8. [pmid: 8838523].
25 Fitz-Patrick D, Drummond W, Pappas J, et al. Effects of a purine nucleoside phosphorylase inhibitor, BCX4208, on the serum uric acid concentrations in patients with gout. Arthritis and Rheumatism. 2010. SUPPL. 10. 2010;62:150. [pmid: 20039407].
26 Fraser RC, Davis RH, Walker FS. Comparative trial of azapropazone and indomethacin plus allopurinol in acute gout and hyperuricaemia. J R Coll Gen Pract. Sep. 1987;37(302):409-11. [pmid: 3330140].
27 Ganson NJ, Kelly SJ, Scarlett E, et al. Control of hyperuricemia in subjects with refractory gout, and induction of antibody against poly(ethylene glycol) (PEG), in a phase I trial of subcutaneous PEGylated urate oxidase. Arthritis Res Ther. 2006;8(1):R12. [pmid: 16356199].
28 Hagerty D, Kerr B, Shen Z, et al. Pharmacokinetics, efficacy and safety of lesinurad, a novel URAT1 inhibitor, in individuals with mild to moderate renal impairment. Arthritis and Rheumatism. 2011;63(10):2011-11.
29 Hara A, Mukae H, Hara S, et al. Drug-induced eosinophilic pneumonia with pulmonary alveolar hemorrhage caused by benzbromarone. Intern Med. 2010;49(5):435-8. [pmid: 20190479].
30 Hosoya T, Ohno I, Nomura S, et al. Effects of topiroxostat on the serum urate levels and urinary albumin excretion in hyperuricemic stage 3 chronic kidney disease patients with or without gout. Clin Exp Nephrol. 2014. Jan. 22. [pmid: 24448692].
31 Klumb EM, Pinheiro GRC, Ferrari A, et al. The treatment of acute gout arthritis. Double-blind randomized comparative study between nimesulid and indomethacin. Rev Brasil Med. 1996;53:540-6.
32 Kodithuwakku ND, Pan M, Zhu YL, et al. Anti-inflammatory and antinociceptive effects of Chinese medicine SQ gout capsules and its modulation of pro-inflammatory cytokines focusing on gout arthritis. J Ethnopharmacol. Dec. 12. 2013;150(3):1071-9. [pmid: 24161431].
33 Kudaeva FM, Eliseev MS, Barskova VG, et al. Comparison of the time to analgetic and anti-inflammatory effect in the treatment of gouty arthritis with nimesulide and sodium diclofenac. Terapevticheskii Arkhiv. 2007;79(5):35-40. [pmid: 17672073].
34 O'Duffy J. Oxypurinol therapy in allopurinol-sensitive patients [abstract]. Arthritis Rheum. 1993;36(suppl 9):S159.
35 Okuda C, Koyama H, Tsutsumi Z, et al. Serum CRP in patients with gout and effects of benzbromarone. Int J Clin Pharmacol Ther. Mar. 2011;49(3):191-7. [pmid: 21329621].
36 Perez-Ruiz F, Calabozo M, Fernandez-Lopez MJ, et al. Treatment of chronic gout in patients with renal function impairment: an open, randomized, actively controlled study. J Clin Rheumatol. Apr. 1999;5(2):49-55. [pmid: 19078356].
37 Perez-Ruiz F, Sundy J, Krishnan E, et al. Efficacy and safety of lesinurad (RDEA594), a novel URAT1 inhibitor, in combination with allopurinol in allopurinol-refractory gout patients: Results from a randomized, blinded, placebo-controlled, phase 2b extension study. Ann Rheum Dis. 2013;71(3):2012-06.
38 Radin A, Marbury T, Osgood G, et al. Safety and pharmacokinetics of subcutaneously administered rilonacept in patients with well-controlled end-stage renal disease (ESRD). J Clin Pharmacol. Jul. 2010;50(7):835-41. [pmid: 20035038].
39 Reardon JA, Stockman A, Darlington LG, et al. Double-blind trial of feprazone and phenylbutazone in acute gout. Curr Med Res Opin. 1980;6(7):445-8. [pmid: 6988172].
40 Reinders MK, Haagsma C, Jansen T, et al. A randomised controlled trial on the efficacy and tolerability with dose escalation of allopurinol 300-600 mg/day versus benzbromarone 100-200 mg/day in patients with gout. Annals of the Rheumatic Diseases. Jun. 2009;68(6):892-7. PMID:. WOS:000266917100022. [pmid: 18633127].
41 Reinders MK, van Roon EN, Houtman PM, et al. Biochemical effectiveness of allopurinol and allopurinol-probenecid in previously benzbromarone-treated gout patients. Clin Rheumatol. Sep. 2007;26(9):1459-65. [pmid: 17308859].
42 Reinders MK, van Roon EN, Jansen T, et al. Efficacy and tolerability of urate-lowering drugs in gout: a randomised controlled trial of benzbromarone versus probenecid after failure of allopurinol. Annals of the Rheumatic Diseases. Jan. 2009;68(1):51-6. PMID:. WOS:000261755800009. [pmid: 18250112].
43 Saha GC, Karpf DB, Choi YJ, et al. Arhalofenate, a potential novel treatment for hyperuricemia, with or without metabolic co-morbidities, in patients with gout: Meta-analysis of urate lowering in four phase 2 studies in type 2 diabetes. Arthritis and Rheumatism. 2011;63(10):2011-11.
44 Schiff MH, DiVittorio G, Tesser J, et al. The safety of anakinra in high-risk patients with active rheumatoid arthritis: six-month observations of patients with comorbid conditions. Arthritis Rheum. Jun. 2004;50(6):1752-60. [pmid: 15188350].
45 Schlesinger N, Sunkureddi P, Alten R, et al. The spread of tophaceous disease strongly predicts time to new flare in gouty arthritis. Ann Rheum Dis. 2013;71(3):2012-06.
46 Smyth CJ, Percy JS. Comparison of indomethacin and phenylbutazone in acute gout. Ann Rheum Dis. Jul. 1973;32(4):351-3. [pmid: 4726072].
47 So A, De Smedt T, Revaz S, et al. A pilot study of IL-1 inhibition by anakinra in acute gout. Arthritis Res Ther. 2007;9(2):R28. [pmid: 17352828].
48 Sturge RA, Scott JT, Hamilton EB, et al. Multicentre trial of naproxen and phenylbutazone in acute gout. Ann Rheum Dis. Feb. 1977;36(1):80-2. [pmid: 843115].
49 Sundy J, Perez-Ruiz F, Krishnan E, et al. Efficacy and safety of lesinurad (RDEA594), a novel uricosuric agent, given in combination with allopurinol in allopurinol-refractory gout patients: Preliminary results from the randomized, double-blind, placebo-controlled, phase 2B extension study. Arthritis and Rheumatism. 2011;63(10):2011-11.
50 Sundy JS, Becker MA, Baraf HS, et al. Reduction of plasma urate levels following treatment with multiple doses of pegloticase (polyethylene glycol-conjugated uricase) in patients with treatment-failure gout: results of a phase II randomized study. Arthritis Rheum. Sep. 2008;58(9):2882-91. [pmid: 18759308].
51 Sundy JS, Ganson NJ, Kelly SJ, et al. Pharmacokinetics and pharmacodynamics of intravenous PEGylated recombinant mammalian urate oxidase in patients with refractory gout. Arthritis Rheum. Mar. 2007;56(3):1021-8. [pmid: 17328081].
52 Takahashi S, Moriwaki Y, Yamamoto T, et al. Effects of combination treatment using anti-hyperuricaemic agents with fenofibrate and/or losartan on uric acid metabolism. Ann Rheum Dis. Jun. 2003;62(6):572-5. [pmid: 12759298].
53 Terkeltaub R, Sundy JS, Schumacher HR, et al. The interleukin 1 inhibitor rilonacept in treatment of chronic gouty arthritis: results of a placebo-controlled, monosequence crossover, non-randomised, single-blind pilot study. Ann Rheum Dis. Oct. 2009;68(10):1613-7. [pmid: 19635719].
54 Van Der Klauw MM, Houtman PM, Stricker BHC, et al. Hepatic injury caused by benzbromarone. J Hepatol. 1994;20:376-9. [pmid: 8014449].
55 WalterSack I, deVries JX, Ernst B, et al. Uric acid lowering effect of oxipurinol sodium in hyperuricemic patients - therapeutic equivalence to allopurinol. J Rheumatol Suppl. 1996;23:498-501.
56 Willburger RE, Mysler E, Derbot J, et al. Lumiracoxib 400 mg once daily is comparable to indomethacin 50 mg three times daily for the treatment of acute flares of gout. Rheumatology. (Oxford). Jul. 2007;46(7):1126-32. [pmid: 17478464].
57 Wurzner G, Gerster JC, Chiolero A, et al. Comparative effects of losartan and irbesartan on serum uric acid in hypertensive patients with hyperuricaemia and gout. J Hypertens. Oct. 2001;19(10):1855-60. [pmid: 11593107].
58 Xiao XY, Wang YF, Xu R. Stage-based treatment of integrative medicine on the quality of life in patients with gout. Zhongguo Zhong Xi Yi Jie He Za Zhi. May. 2012;32(5):620-3. [pmid: 22679721].
59 Xie CC, Lin NP, Zhou JX, et al. The Experimental Introduction of Professor Fu's Three-Step Therapy on Gouty Arthritis. 2012 Ieee International Conference on Bioinformatics and Biomedicine Workshops. New York. Ieee. 2012.
60 Yang BB, Baughman S, Sullivan JT. Pharmacokinetics of anakinra in subjects with different levels of renal function. Clin Pharmacol Ther. Jul. 2003;74(1):85-94. [pmid: 12844139].
61 Yang BL, Ding G. Observation of qigui tongfengshu granules in treatment of sixteen cases of gouty arthritis. Zhongguo Zhong Yao Za Zhi. Jan. 2013;38(2):276-7. [pmid: 23672056].
62 Yeh L, Kerr B, Shen Z, et al. RDEA594, a novel URAT1 inhibitor, shows significant additive urate lowering effects in combination with febuxostat in both healthy subjects and gout patients. Clinical Pharmacology and Therapeutics. February. SUPPL. 1. 2011;89:S92-S3.
63 Yeh LT, Shen Z, Yang J, et al. RDEA594, a novel URAT1 inhibitor, shows additive serum-urate-lowering effects in combination with xanthine oxidase inhibitor febuxostat. Drug Metabolism Reviews. May. SUPPL. 1. 2011;43:76.
64 Zhou M, Wang YF, Zhou R, et al. Treatment of gouty arthritis in different phases by a series of tongfeng granule: an efficacy observation. Zhongguo Zhong Xi Yi Jie He Za Zhi. Dec. 2013;33(12):1603-7. [pmid: 24517053].

## No outcomes of interest (N=11)

1 Bardin T, Flipo RM, Richette P, et al. Gouty patients with history of adverse reaction to allopurinol are not at higher risk of reaction to febuxostat. Arthritis Rheum. October. SUPPL. 10. 2014;66:S68-S9.
2 Carter JD, Patelli M, Anderson S, et al. An assessment of the response of chronic, occult, synovial-based inflammation of gout to serum urate lowering therapy. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S503.
3 Fam AG, Dunne SM, Iazzetta J, et al. Efficacy and safety of desensitization to allopurinol following cutaneous reactions. Arthritis Rheum. Jan. 2001;44(1):231-8. [pmid: 11212165].
4 Hung IF, Wu AK, Cheng VC, et al. Fatal interaction between clarithromycin and colchicine in patients with renal insufficiency: a retrospective study. Clin Infect Dis. Aug. 1. 2005;41(3):291-300. [pmid: 16007523].
5 Jennings C, Mackenzie IS, Flynn R, et al. Up-titration of allopurinol in the febuxostat vs. Allopurinol streamlined trial (FAST). Pharmacoepidemiology and Drug Safety. October. SUPPL. 1. 2013;22:424-5.
6 Pascual E, Sivera F. Time required for disappearance of urate crystals from synovial fluid after successful hypouricaemic treatment relates to the duration of gout. Ann Rheum Dis. Aug. 2007;66(8):1056-8. [pmid: 17223663].
7 Tausche AK, Christoph M, Forkmann M, et al. As compared to allopurinol, urate-lowering therapy with febuxostat has superior effects on oxidative stress and pulse wave velocity in patients with severe chronic tophaceous gout. Rheumatol Int. Jan. 2014;34(1):101-9. [pmid: 24026528].
8 Terkeltaub RA, Furst DE, Digiacinto JL, et al. Novel evidence-based colchicine dose-reduction algorithm to predict and prevent colchicine toxicity in the presence of cytochrome P450 3A4/P-glycoprotein inhibitors. Arthritis Rheum. Aug. 2011;63(8):2226-37. [pmid: 21480191].
9 Thiele RG, Schlesinger N. Ultrasonography shows disappearance of monosodium urate crystal deposition on hyaline cartilage after sustained normouricemia is achieved. Rheumatol Int. Feb. 2010;30(4):495-503. [pmid: 19543895].
10 Walz-LeBlanc BA, Reynolds WJ, MacFadden DK. Allopurinol sensitivity in a patient with chronic tophaceous gout: success of intravenous desensitization after failure of oral desensitization. Arthritis Rheum. Oct. 1991;34(10):1329-31. [pmid: 1930322].
11 Wluka AE, Ryan PF, Miller AM, et al. Post-cardiac transplantation gout: incidence of therapeutic complications. J Heart Lung Transplant. Oct. 2000;19(10):951-6. [pmid: 11044689].

## No intereventions of interest (N=2)

1 Kumar S, Ng J, Gow P. Benzbromarone therapy in management of refractory gout. N Z Med J. Jun. 24. 2005;118(1217):U1528. [pmid: 15980902].
2 Meyrier A. Desensitisation in a patient with chronic renal disease and severe allergy to allopurinol. Br Med J. Aug. 21. 1976;2(6033):458. [pmid: 953607].

## Duplicate data (N=33)

1 Becker M, MacDonald P, Hunt B, et al. Gout flare incidence in relation to average serum urate during the first year of urate-lowering therapy. Boston, Massachusetts. Presented at: the Meeting of the American College of Rheumatology. November 6-11 2007a.
2 Becker M, Schumacher HR Jr., MacDonald P, et al. Urate-lowering therapy (febuxostat [FEB] or allopurinol [ALLO]) in subjects with gout: interim results from the febuxostat comparative extension long-term study (EXCEL). Boston, Massachusetts. Presented at: the Meeting of the American College of Reumatology. November 6–11, 2007b.
3 Becker M, Schumacher HR Jr., Wortmann RL, et al. Febuxostat, a novel non-purine selective inhibitor of xanthine oxidase, therapy in allopurinol intolerant patients. San Antonio, Texas. Presented at: the Meeting of the American College of Rheumatology. October 16-21, 2004.
4 Becker MA, MacDonald P, Hunt B, et al. Febuxostat (FEB) vs. Allopurinol (ALLO) in treating the hyperuricemia of gout in diabetic patients. Pharmacotherapy. October. 2011;31(10):381e.
5 Becker MA, MacDonald PA, Hunt B, et al. Febuxostat (vs. allopurinol) in treating the hyperuricemia of gout in diabetic patients. Arthritis and Rheumatism. 2011;63(10):2011-11.
6 Becker MA, Pandya BJ, Young JR, et al. Serum uric acid testing patterns in gout patients: A need for improved monitoring. Arthritis and Rheumatism. 2011;63(10):2011-11.
7 Becker MA, Schumacher H, Wortmann RL, et al. A safety and efficacy clinical trial of a novel nun-purine selective inhibitor of xanthine oxidase, febuxostat in subjects with gout. Ann Rheum Dis. 2004;63:60.
8 Becker MA, Ye X, Akhras KS, et al. Comparing clinical characteristics and comorbidities of gout patients treated with allopurinol or febuxostat. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S771-S2.
9 Bongartz T, Zleik N, Clement M, et al. The risk of future attacks in patients with incident gout: A population-based. Annals of the Rheumatic Diseases. 2013;72(3):2013-06.
10 Chohan S, Becker M, MacDonald P, et al. Efficacy and Safety of Febuxostat and Allopurinol in Women with Gout, An Older Subset With Increased Comorbidity. J Rheumatol. Jun. 2011;38(6):1152. PMID:. WOS:000292534500085.
11 Choudhury M, Saleh A, Mollah F, et al. The effects of ascorbic acid supplementation on serum concentrations of uric acid: Results of a randomized controlled trial. International Journal of Rheumatic Diseases. September. SUPPL. 1. 2012;15:101.
12 Dalbeth N, Ames R, Gamble G, et al. Daily intake of skim milk powder enriched with glycomacropeptide and G600 milk fat extract may reduce frequency of gout flares; results from a randomized, controlled trial. Arthritis and Rheumatism. 2011;63(10):2011-11.
13 De Vera MA, Galo J. What are the effects of interventions targetting medication adherence in rheumatic diseases: A systematic review. Annals of the Rheumatic Diseases. 2014;73(2):2014-06.
14 Gibson T, Simmonds HA, Potter C, et al. A controlled study of the effect of long term allopurinol treatment on renal function in gout. Adv Exp Med Biol. 1980;122A:257-62. [pmid: 6999847].
15 Hill E, Higgs JB, Sky K, et al. Does starting allopurinol prolong acute treated gout?. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S730.
16 Kamatani N, Fujimori S, Hada T, et al. Placebo-Controlled Double-Blind Dose-Response Study of the Non-Purine-Selective Xanthine Oxidase Inhibitor Febuxostat (TMX-67) in Patients With Hyperuricemia (Including Gout Patients) in Japan: Late Phase 2 Clinical Study (vol 17, pg S35, 2011). J Clin Rheumatol. Sep. 2014;20(6):E2-E. PMID:. WOS:000341563000004.
17 Kamatani N, Fujimori S, Hada T, et al. Placebo-Controlled, Double-Blind Study of the Non-Purine-Selective Xanthine Oxidase Inhibitor Febuxostat (TMX-67) in Patients With Hyperuricemia Including Those With Gout in Japan; Phase 3 Clinical Study (vol 17, pg S19, 2011). J Clin Rheumatol. Sep. 2014;20(6):E1-E. PMID:. WOS:000341563000002. [pmid: 25756966].
18 Kamatani N, Fujimori S, Hada T, et al. An Allopurinol-Controlled, Multicenter, Randomized, Open-Label, Parallel Between-Group, Comparative Study of Febuxostat (TMX-67), a Non-Purine-Selective Inhibitor of Xanthine Oxidase, in Patients With Hyperuricemia Including Those With Gout in Japan: Phase 2 Exploratory Clinical Study (vol 17, pg S44, 2011). J Clin Rheumatol. Sep. 2014;20(6):E3-E. PMID:. WOS:000341563000005.
19 Khanna D, Khanna P, Hagerty D, et al. Patients that continue to flare despite apparent optimal urate lowering therapy. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S61.
20 Khanna D, Khanna PP, Storgard C, et al. Patients that continue to flare despite reaching EULAR/ ACR recommended serum urate target. Annals of the Rheumatic Diseases. 2013;72(3):2013-06.
21 Krishnan E, MacDonald PA, Hunt BJ, et al. Encore presentation febuxostat vs allopurinol in elderly gout subjects: Subgroup analysis of the confirms trial. Journal of the American Geriatrics Society. April. SUPPL. 1. 2011;59:S56.
22 Kuo CF, Yu KH, Luo SF, et al. Risk of end-stage renal disease associated with gout: A nationwide population study. Ann Rheum Dis. 2013;71(3):2012-06.
23 Schumacher HR, Becker M, MacDonald P, et al. Febuxostat versus Allopurinol in the treatment of gout in subjects 65 years of age or older. Barcelona, Spain. Presented at: Meeting of The European League Against Rheumatism. June 13-16, 2007.
24 Schumacher HR Jr., Becker M, Wortmann RL, et al. The FOCUS trial 48-month interim analysis: long-term clinical outcomes of treatment with febuxostat in subjects with gout in an ongoing phase 2, open-label extension study. Washington, DC. Presented at: the Meeting of the American College of Rheumatology. November 10-15, 2006.
25 Schumacher HR Jr., Becker M, Wortmann RL, et al. Magnetic resonance imaging of gouty tophi during treatment with febuxostat, a non-purine selective inhibitor of xanthine oxidase. San Antonio, Texas. Presented at: the Meeting of the American College of Rheumatology. October 16-21, 2004.
26 Schumacher HR, Berger MF, Li-Yu J, et al. Efficacy and tolerability of celecoxib in the treatment of moderate to extreme pain associated with acute gouty arthritis: a randomized controlled trial. Arthritis Rheum. 2010:563-4.
27 Schumacher HR Jr., Wortmann RL, Becker M, et al. A phase 2, long term open-label safety and efficacy study of febuxostat, a novel non-purine, selective inhibitor of xanthine oxidase. San Diego, California. Presented at: the Meeting of the American College of Rheumatology. November 13-17, 2005.
28 Stamp LK, Frampton C, O'Donnell JL, et al. Lack of effect of supplemental vitamin c on serum urate in patients with gout. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S60-S1.
29 Takahashi S, Moriwaki Y, Tsutsumi Z, et al. Effect of a combination therapy with losartan and anti-hyperuricemic agents on uric acid metabolism in gout patients with hypertension. J Rheumatol Suppl. 2001;28:M37.
30 Wason S, Lauterio T, Crockett S, et al. Colchicine, as assessed by target joint pain scores, is effective at 16 hours in patients with acute gout flares. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S812.
31 Wortmann RL, Becker M, Schumacher HR Jr., et al. Gout flare prophylaxis during management of chronic gout with febuxostat, a non-purine selective inhibitor of xanthine oxidase. Arthritis Rheum. 2004;50:801. 103.
32 Wortmann RL, Becker M, Schumacher HR Jr., et al. Effect of febuxostat or allopurinol on the clinical manifestations of gout: reduction in gout flares and tophus size over time in the EXCEL trial. Washington, DC. Presented at: the Meeting of the American College of Rheumatology. November 10-15, 2006.
33 Zhou L, Xu QF, Zhang WS. Comparative observation of the efficacy on acute gouty arthritis between acupuncture combined with infrared irradiation and western medicine. Zhongguo Zhen Jiu. Sep. 2011;31(9):787-9. [pmid: 21972623].

## Article not found (N=4)

1 Limited evidence supports use of NSAIDs for acute gout. 2014. [pmid: 2014974445]. FULL TEXT LINK http://dx.doi.org/10.1136/dtb.2014.12.0293.
2 Araujo M, Pinto CG. Cost-Effectiveness of Routine Testing for Hla-B*5801 in Caucasian Patients Newly Diagnosed with Gout in Portuguese Nhs Hospitals. Value in Health. Nov. 2014;17(7):A379-A. PMID:. WOS:000346917300309.
3 Escolano CV. Acupuncture for gouty arthritis: A concise report of a systematic and meta-analysis approach. ORIGINAL (NON-ENGLISH) TITLE. Acupuntura para la artritis gotosa: informe conciso de un metaanalisis sistematico. Revista Internacional de Acupuntura. July-September. 2013;7(3):99-100. FULL TEXT LINK http://dx.doi.org/10.1016/S1887-8369(13)70098-X.
4 Torre Gdl. A comparative, double-blind, parallel study with tenoxicam vs placebo in acute in acute gouty arthritis. Invest Med Int. 1987;14:92-7.