# Search Strategy

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 1/1/2010-4/23/2015

SEARCH STRATEGY:

“Gout”[Mesh] OR gout[tiab] OR gouty[tiab] OR toph*

==================================================

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 1/1/2010-4/23/2015

SEARCH STRATEGY:

Gout suppressants[mh]

NOT

“Gout”[Mesh] OR gout[tiab] OR gouty[tiab] OR toph*

=================================================

DATABASE SEARCHED & TIME PERIOD COVERED:

Embase – 1/1/2010-4/23/2015

SEARCH STRATEGY:

gout:de,ab,ti OR gouty:de,ab,ti OR toph*:de,ab,ti

AND

[humans]/lim

AND

[embase]/lim

=================================================

DATABASE SEARCHED & TIME PERIOD COVERED:

Web of Science Indexes=SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH – 1/1/2010-4/23/2015

SEARCH STRATEGY:

TS=(gout OR gouty OR toph*)

NOT

ts=(Aicardi-Goutieres)

===============================================

DATABASE SEARCHED & TIME PERIOD COVERED:

Cochrane Databases – 1/1/2010-4/23/2015

SEARCH STRATEGY:

‘gout OR gouty OR toph* in Title, Abstract, Keywords

===============================================

FORWARD SEARCHES ON THE FOLLOWING ARTICLE:

EULAR evidence based recommendations for gout. Part II: Management. Report of a task force of the EULAR standing committee for international clinical studies including therapeutics (ESCISIT)

By:Zhang, W; Doherty, M; Bardin, T;Pascual, E; Barskova, V; Conaghan, P; Gerster, J; Jacobs, J; Leeb, B; Liote, F

Annals Of The Rheumatic Diseases, Volume: 65, Issue: 10, Pages: 1312-1324

Published: OCT 2006

================================================

DATABASE SEARCHED & TIME PERIOD COVERED:

Web of Science – 1/1/2010-4/23/2015

SEARCH STRATEGY:

CITED AUTHOR: (zhang w*) AND CITED WORK: (ann rheum dis) AND CITED YEAR: (2006)

===============================================

DATABASE SEARCHED & TIME PERIOD COVERED:

SCOPUS – 1/1/2010-4/23/2015

SEARCH STRATEGY:

AUTHOR-NAME(zhang w*) AND TITLE-ABS-KEY(gout) AND PUBYEAR > 2005

Select citations to this article

===============================================

DATABASE SEARCHED & TIME PERIOD COVERED:

CLINICALTRIALS.GOV - Earliest-4/23/2015

SEARCH STRATEGY:

CONDITION = “Gout”

==============================================

MANUAL FILTERING IN ENDNOTE TO REMOVE DUPLICATES, ANIMAL-ONLY STUDIES, “GOUT” AS FRENCH FOR “TASTE,” “TOPHAT” (Re: GENETICS), HISTORICAL ACCOUNTS, AUTHORS NAMED “GOUT” OR “TOPH*

==============================================

CLINICALTRIALS.GOV

CONDITION = “Gout”

RECEIVED FROM: Earliest in database to 4/23/2015