# Abbreviations/Acronyms

3e: Evidence, Expertise, Exchange
ACR: American College of Rheumatology
ACP: American College of Physicians
ACTH: Adrenocorticotropic Hormone
AE(s): Adverse event(s)
AHRQ: Agency for Healthcare Research and Quality
ALL: Allopurinol
BMI: Body Mass Index
CI: Confidence interval
CT (Scan): Computerized tomography
CVD: Cardiovascular disease
DASH: Dietary Approaches to Stop Hypertension
DNTT: Danggui-Nian-Tong Tang
eGFR: Estimated glomerular filtration rate
EPC: Evidence-based Practice Center
FEB: Febuxostat
GC: Glucocorticoid
GI: Gastrointestinal
GMP: glycomacropeptide
HRQoL: Health Related Quality of Life
KQ: Key Question
MD: Mean difference
MSU: Monosodium urate
NHANES: National Health and Nutrition Examination Survey
Non-GI: Non-gastrointestinal
NSAIDS: Nonsteroidal anti-inflammatory drugs
OR: Odds Ratio
PCPs: Primary care physicians
PICOTS: Populations, Interventions, Comparators, Outcomes, and Timing
PLB: Placebo
RR: Relative risk
SCEPC: Southern California Evidence-based Practice Center
SMD: Standardized mean difference
SMP: Skim milk powder
SRs: Systematic Reviews
sUA: Serum urate
TCM: Traditional Chinese Medicine
TEP: Technical Expert Panel
UA: Uric acid
ULT: Urate Lowering Therapy
US: United States
VA: Veterans Administration
XOI: Xanthine oxidase inhibitor