# Results

## Introduction

This chapter presents the results of our systematic review. We first present the results of our literature searches and identify studies that met our inclusion criteria (referred to as “included studies”). We then discuss the findings from our analyses for each Key Question (KQ), starting with an overview of key points and then synthesizing the results. KQ 1 describes in detail all included studies by work settings and populations, intervention, and outcomes. A subset of included studies (i.e., studies with a concurrent control group) was eligible for KQ 2, which focuses on the effectiveness and harms of Total Worker Health^®^ (TWH) interventions.

For KQ 2, we present the results of included studies organized by outcome category: health and safety outcomes, intermediate outcomes, utilization outcomes (including occupational injury and illness surveillance outcomes), and harms. For each outcome, we briefly describe the population, work setting, and intervention characteristics of the studies reporting a specific outcome. We describe the results of all studies eligible for KQ 2, regardless of the risk of bias rating. However, as described in the Methods chapter, we graded the strength of evidence (SOE) only for outcomes reported by at least one study that we had rated as either low or medium risk of bias.

For KQ 3, we describe the components of effective interventions when we had least one study rated as low or medium risk of bias that showed benefit for an included outcome in KQ 2. We focus on components of interventions relating to the integration of occupational safety and health (OSH) and health promotion (HP).

The results of KQs 4 through 6 are based on all included studies. KQ 4 describes contextual factors that authors noted as potential modifiers of intervention effectiveness (e.g., work organization, social and economic factors, and others). Finally, KQ 5 and KQ 6 outline research gaps and future research needs (respectively) relevant to TWH interventions.

## Results of Literature Search and Screening

Searches of all sources identified a total of 1,532 potentially relevant citations. We included 24 studies described in 33 publications.9,10,25-55 Figure 2 describes the flow of literature through the screening process according to PRISMA (Preferred Reporting Items for Systematic Reviews and Meta-Analyses) categories.56 Appendix B provides a complete list of articles excluded at the full-text screening stage, with reasons for exclusion. Of the 24 included studies, 15 studies had a concurrent control group and were also eligible for KQ 2.^9,10,25,28,29,31-33,38,41,42,50,51,54,55^ Table 3 lists studies assessed for each KQ.

Figure 2 Disposition of articles for Total Worker Health interventions

ASP = Academic Search Premier; CT.gov = ClinicalTrials.gov; NIOSH = National Institute of Occupational Safety and Health; PICOTS = populations, interventions, comparators, outcomes, time frames, settings.

The PRISMA flowchart presents the yield of our literature retrieval process and the results of each stage of literature review, including title and abstract review, and full-text article review. We retrieved a total of 1,625 records through database searching and other sources, including MEDLINE, PsycINFO, the Cochrane Library, hand searches of other publications' reference lists, ClinicalTrials.gov, Academic Search Premier, and a bibliography of references sent by NIOSH. After removal of 93 duplicate records, we screened 1,532 titles and abstracts, and excluded 1,237 of these. We then reviewed 295 full-text articles for eligibility. Of these, we excluded 262 articles because of not being available in English, ineligible publication type, not being original research, ineligible study design, or ineligible PICOTS. The final yield included in the systematic review was 24 studies with 33 articles.

Table 3 Included studies, by KQ eligibility and KQ 2 outcomes

Author, Year, Study Design, Risk of Bias | KQ 1 | Outcomes Eligible for KQ 2^a^ | KQ 3 | KQ 4 | KQ 5 | KQ 6
Allen et al., 2003^38^ Nonrandomized controlled trial (NRCT), High | Y | Allergy severity Workers' compensation claims Short-term disability claims | N | Y | Y | Y
Barbeau et al., 2006^48^ Single-group pre/post study, NA | Y | NA | N | Y | Y | Y
Blackburn et al., 2009^30^ Single-group pre/post study, NA | Y | NA | N | Y | Y | Y
Boggild and Jeppesen, 2001^41^ Cohort study, high | Y | Alcohol consumption Cholesterol levels Exercise frequency Smoking cessation Harms | N | Y | Y | Y
Carr et al., 2015^54^ Randomized controlled trial (RCT), medium | Y | Occupational sedentary behavior Occupational physical activity behavior Weight Blood pressure Musculoskeletal discomfort | N | N | Y | Y
Caspi et al., 2013^46^ Single-group pre/post study, NA | Y | NA | N | Y | Y | Y
Coffeng et al., 2014^51-53^ RCT, medium | Y | Need for recovery after work Occupational stress and exhaustion Occupational physical activity behaviors Occupational sedentary behavior Overall physical activity level | N | Y | Y | Y
Eriksen et al, 2002^42^ RCT, high | Y | Subjective health complaints Job stress Harms | N | Y | Y | Y
Hammer et al., 2015^55^ RCT, medium | Y | Quality of life Blood pressure Safety participation and compliance scores | N | N | Y | Y
Hodges et al., 2004^37^ Single-group pre/post study, NA | Y | NA | N | Y | Y | Y
Maes et al., 1998^28^ NRCT, high | Y | Cardiovascular disease (CVD) risk score General stress | N | Y | Y | Y
Maniscalco et al., 1999^47^ Single-group pre/post study, NA | Y | NA | N | Y | Y | Y
Nieuwenhuijsen et al., 2004^36^ Single-group pre/post study, NA | Y | NA | N | Y | Y | Y
Okechukwu et al., 2009^25^ RCT, high | Y | Smoking cessation | Y | Y | Y | Y
Olson et al., 2015^43^ Single-group pre/post study, NA | Y | NA | N | Y | Y | Y
Olson et al., 2009^44,45^ Single-group pre/post study, NA | Y | NA | N | Y | Y | Y
Palumbo et al., 2012^29^ RCT, high | Y | Quality of life General stress Job stress Functional status | N | Y | Y | Y
Porru et al., 1993^49^ Single-group pre/post study, NA | Y | NA | N | Y | Y | Y
Sorensen et al, 1998^9,39,40^ RCT, high | Y | Healthy eating behavior Self-reported workplace hazard exposure Smoking cessation | N | Y | Y | Y
Sorensen et al., 2003^10,26,27^ RCT, high | Y | Healthy eating behavior Worksite hazardous substance exposure prevention ratings Smoking cessation | Y | Y | Y | Y
Sorensen et al., 2005^33-35^ RCT, medium | Y | Healthy eating behavior Overall physical activity level | Y | Y | Y | Y
Sorensen et al., 2007^32^ RCT, medium | Y | Healthy eating behavior Smoking cessation | Y | Y | Y | Y
Tveito and Eriksen, 2009^31^ RCT, high | Y | Quality of life Subjective health complaints | N | Y | Y | Y
von Thiele Schwarz et al., 2015^50^ RCT, high | Y | Self-rated health^b^ | N | Y | Y | Y

CVD = cardiovascular disease; KQ = Key Question; N = no; NA = not applicable; NRCT = nonrandomized controlled trial; RCT = randomized controlled trial; Y = yes.

a Other outcomes assessed in these studies are listed in Table 6 in KQ 1.

b Self-rated health was assessed using a single item where participants were asked to rate their current health status on a five-point scale that ranged from “very good” (1) to “very poor” (5).

Table 6 Outcomes evaluated in Total Worker Health interventions

Author(s), Year Study Name Industry | Final Health and Safety Outcomes | Intermediate Health Outcomes | Utilization and Other Outcomes
Allen et al., 2003^38^ International's Allergy Project Manufacturing | Allergy symptom severity | Use of allergy medications, knowledge related to coping with severe allergy symptoms | Productivity, absenteeism, WC claims, short-term disability claims
Barbeau et al., 2006^48^ MassBUILT Pilot Construction | NR | Smoking cessation, other measures of cigarette use | NR
Blackburn et al., 2009^30^ Sustainable Farm Families Project Agriculture | NR | BMI, cholesterol levels, blood glucose, blood pressure | Participation in intervention
Boggild and Jeppesen, 2001^41^ Health care | NR | Physical activity, prevalence of smoking, weekly alcohol consumption, cholesterol levels | Changes in shift schedules according to ergonomic criteria (e.g., regularity, predictability, and periodicity) Employee perceptions of schedules
Carr et al., 2015^54^ Not reported | Musculoskeletal discomfort | Blood pressure, heart rate, weight, body composition, waist circumference, occupational time spent sedentary and physically active | Productivity, process evaluation to assess helpfulness to employee
Caspi et al., 2013^46^ Health care | Musculoskeletal pain, work interference due to pain | Physical activity, multiple measures of safe (and unsafe) patient handling | Measures of unit safety practices, coworker support and supervisor support
Coffeng et al., 2014^51-53^ Vitality in Practice (VIP) in Insurance Project Finance | NR | Need for recovery after work, multiple measures of physical activity at and outside of work (e.g., stair climbing, active commuting, leisure activities, sports, sedentary time at work), work-related stress, exhaustion | NR
Eriksen et al., 2002^42^ Transportation and warehousing | Subjective health complaints, job stress | NR | Sick leave (self-reported), worker perception of intervention
Hammer et al., 2015^55^ Safety and Health Improvement Program (SHIP) Construction | QOL (physical health composite score on the SF-12) | Blood pressure (reported as mean arterial blood pressure), safety compliance and safety-participation behaviors | Supervisor rating of various process measures (e.g., morale, work climate, team communication), measures of supervisor learning (via quizzes)
Hodges et al., 2004^37^ City of North Little Rock Employee Health and Wellness Program Multiple industries | NR | NR | WC expenditures, utilization of heath care services, HP program participation, employee and employer satisfaction with intervention
Maes et al., 1998^28^ Brabantia Project Manufacturing | General stress, job stress | CVD risk score^a^ | Quality of work (e.g., psychological demands, control, ergonomic conditions, social support), absenteeism
Maniscalco et al., 1999^47^ Lafayette OBUWP Oil and gas extraction | NR | Cholesterol levels, level of fitness and nutrition (based on an HRA survey) | Work-related injuries based on an employer surveillance database, estimated cost savings related to medical and lost productivity costs associated with injuries, intervention participation
Nieuwenhuijse, 2004^36^ Work Site Health Risk Project Health care | Pain, difficulty sitting | Composite measure of behavior change (reported as “positive, no change, or negative change”) based on survey responses to multiple measures of health and safety behavior (e.g., taking mini posture breaks at work, engaging in regular exercise) | Multivariate analysis conducted to identify factors associated with positive behavioral change
Okechukwu et al., 2009^25^ MassBUILT Construction | NR | Smoking cessation, other measures of cigarette use | NR
Olson et al., 2009;^44^ Wipfli et al., 2013^45^ SHIFT Pilot Study Transportation and warehousing | Overall health state (EQ-5D) | Multiple body measurements including weight, BMI, and waist-to-hip ratio; multiple dietary behaviors; physical activity level; work safety behaviors including number of hard breaks, percentage time over-speed and seat belt use; cholesterol levels; fasting blood glucose; blood pressure; multiple measures of fitness such as 6-minute walk test; measures of self-efficacy related to diet and exercise | Measures of organizational safety climate
Olson et al., 2015^43^ Community of Practice and Safety Support Health care | Subjective well-being, depression symptoms, QOL (SF-12), psychosocial stress, physical pain | Multiple measures of dietary behavior, blood pressure, cholesterol levels, blood glucose, multiple body measurements (e.g., BMI, percentage body fat); multiple measures of fitness (e.g., grip strength, flexibility). counts of specific safety behaviors (e.g., use of new lift/transfer tool) | Intervention participation
Palumbo et al., 2012^29^ Health care | QOL (SF-36), general stress, job stress, functional status | Multiple measures of flexibility (e.g., functional reach test, sit-and-reach test, and others) | Absenteeism
Porru et al., 1993^49^ Manufacturing | NR | Blood lead levels, knowledge of lead toxicology and strategies for preventing lead-related diseases | Changes in worksite conditions associated with lead exposures
Sorensen et al., 1998;^9^ Sorensen et al., 1996;^39^ Sorensen et al., 1995^40^ WellWorks Manufacturing | NR | Smoking cessation, multiple measures of dietary behavior, self-reported workplace hazardous exposures | NR
Sorensen et al., 2003;^10^ LaMontagne et al., 2005;^26^ Hunt et al., 2005^27^ WellWorks-2 Manufacturing | NR | Smoking cessation, fruit and vegetable consumption | Measures of worksite participation and awareness of intervention, measures of worksite exposure prevention activity
Sorensen et al,, 2005;^33^ Hunt et al., 2007;^34^ Barbeau et al., 2004^35^ Healthy Directions-Small Business Manufacturing | NR | Physical activity, multiple measures of dietary behavior, multivitamin use | NR
Sorensen et al., 2007^32^ Tools for Health Construction | NR | Smoking cessation, other measures of tobacco use, fruit and vegetable consumption | NR
Tveito and Eriksen, 2009^31^ Health care | Subjective health complaints. QOL (SF-36) | Coping | Sick leave, work quality (psychological demands, control/decision latitude), employee perception of intervention
von Thiele Schwarz et al., 2015^50^ Health care | Change in self-reported current health status^b^ | NR | Absenteeism, workability, productivity, measures of integration developed by the investigators^c^

BMI = body mass index; CVD = cardiovascular disease; EQ-5D = EuroQOL five dimensions questionnaire; HRA = health risk appraisal; NR = not reported; OBUWP = Offshore Business Unit Wellness Program; QOL = quality of life; SF-12 = Medical Outcomes Study Short Form (12 items); SF-36 = Medical Outcomes Study Short Form (36 items); SHIP = Safety and Health Improvement Program; VIP = Vitality in Practice; WC = workers' compensation.

a The study investigators calculated the 8-year risk of CVD based on the Framingham risk score; variables included worker age, total cholesterol level, systolic blood pressure, and smoking status.

b The investigators assessed self-rated health using a single item; participants rated their current health status on a five-point scale (“very good” [1] to “very poor” [5]).

c Measures of integration were developed by the study investigators and focused on assessing the degree of integration associated with HP, OSH, and quality improvement processes; items included measures of employee involvement and exposure and assessment of the manager's attitude and actions related to the intervention.

## Key Question 1 Characteristics of Studies Evaluating Total Worker Health Interventions

We included 24 studies described in 33 publications that assessed integrated interventions; 12 of the studies were randomized controlled trials (RCTs),9,10,25-27,29,31-35,39,40,42,50-55 2 were nonrandomized controlled trials (NRCTs),28,38 1 was a prospective cohort study,41 and 9 were single group pre/post studies.30,36,37,43-49

Across the 24 included studies, heterogeneity was substantial with respect to the work settings and populations, the intervention types, and the outcomes evaluated. Detailed information extracted from all included studies is available from the Systematic Review Data Repository™ (SRDR), available on the Web at www.srdr.ahrq.gov.

### Key Points: Work Settings and Populations

- The majority of studies enrolled workers from the manufacturing, construction, and health care and social assistance industries.
- Workers from the manufacturing and construction industry were predominantly male and included a mix of blue-collar production workers and white-collar workers. Workers from the health care and social assistance industry were overwhelmingly female nurses.
- The mean age of enrolled workers across most included studies was between 30 and 50 years of age; only one study evaluated a younger workforce (mean <30 years of age) and only one study evaluated an older workforce (mean >50 years of age).
- Few studies described the baseline health status or comorbidity of included populations.

### Key Points: Interventions and Comparators

- All 24 studies assessed an intervention designed to simultaneously reduce work-related illness and injury and promote overall health and well-being. Eight included studies assessed an intervention that involved strategic coordination across organizational departments responsible for OSH and HP, and 16 included studies involved worker participation in the development, design, planning, or implementation of the intervention. Six studies involved both strategic integration and worker participation.
- Most studies assessed complex multicomponent interventions; three studies assessed a single-component intervention.
- Of the 24 included studies, one assessed the effectiveness of integration alone (without added OSH or HP content). Twelve studies assessed interventions that included new, comprehensive OSH and HP components not previously available to workers. Six studies included mostly HP content that was tailored to the specific needs of workers (often by highlighting the potential synergistic toxicity of work hazards and health behavior), and five studies assessed interventions that focused mostly on reducing OSH hazards but also included content aimed at promoting overall health and well-being.
- Of the 24 studies, 15 included concurrent control groups, most of which received no intervention. Two studies compared an integrated intervention with an HP-only intervention.

### Key Points: Outcomes

- Overall, included studies evaluated diverse outcomes. Few studies assessed the same outcomes in similar populations of workers.
- Approximately half of studies evaluated at least one final health outcome such as general physical or mental health (e.g., quality of life, functional status), subjective health complaints, and stress.
- Commonly reported intermediate health outcomes were cholesterol levels, blood pressure, and a range of health behaviors including measures of physical activity, smoking, and dietary behaviors. Job stress and changes in safe work behaviors were commonly reported OSH intermediate outcomes.
- Few studies evaluated work-related injuries or illnesses.
- Several studies assessed outcomes that we did not include in KQ 2 (effectiveness and harms of TWH integrations); the most common were measures of absenteeism, productivity, and economic evaluation outcomes.

### Detailed Synthesis

#### Work Settings and Populations

Table 4 describes the characteristics of work settings and populations evaluated across included studies. The included studies primarily enrolled workers based on their occupation (e.g., farmers, truckers), affiliation with a specific training program or union, work setting (e.g., hospitals, factories), specific geographic location. (e.g., municipal workers in a specific city), or combinations of these factors.

Table 4 Characteristics of work settings and populations

Author(s), Year Study Name | Industry Worksite(s) (N worksites; N workers) Country (states) | Occupational Group(s) | Mean Age^a^ (SD), Years | % Female | % Non-white
Allen et al., 2003^38^ International's Allergy Project | Manufacturing Worksites producing medium- and heavy-duty trucks and diesel engines (7; 519) United States (Illinois, Indiana) | Blue-collar production workers and while-collar workers (% across worksites not reported) | 43–46 (NR) | 31 | NR
Barbeau et al., 2006^48^ MassBUILT Pilot | Construction Building trade apprentice training program (1; 337) United States (Massachusetts) | Apprentice iron workers | 30 (8) | 3 | 21
Blackburn et al., 2009^30^ Sustainable Farm Families Project | Agriculture Communities in Southeastern Australia (NA; 128) Australia | Farmers (cropping and grazing) | 47 (8.8) | 45 | NR
Boggild and Jeppesen, 2001^41^ | Health care and social assistance Inpatient wards (7) in one regional hospital (1; 172) Denmark | Nurses and nursing aides | 35–42 (NR) | NR | NR
Carr et al., 2015^54^ | Not reported Private company (1; 60) United States (Iowa) | Sedentary desk job workers at a private company^b^ | 45 (11) | 70 | 4–15
Caspi et al., 2013^57^ | Health care and social assistance Inpatient wards (7) in 2 teaching hospitals (2; 374) United States (Massachusetts) | Nursing staff (advanced practice nurses, nurse leaders, and patient care associates) | 41 (12) | 90 | 21
Coffeng et al., 2014^51-53^ | Finance Departments of a financial service provider (NR: 412) The Netherlands | Office employees with mainly desk jobs | 38–44 (9.2–10.5) | 38–45 | NR
Eriksen et al., 2002^42^ | Transportation Post office or postal terminal (31; 860) Norway | Postal service employees (office clerks and blue-collar workers) | 37–39 (NR) | 59–64 | NR
Hammer et al., 2015^55^ | Multiple industries Workers employed by a municipal public works department (NR; 292) United States (NR) | Construction and utility workers including electricians, plumbers, carpenters, heavy equipment operators, sidewalk repair persons, and others | 45 (9.6) | 10 | 21
Hodges et al., 2004^37^ City of North Little Rock Employee Health and Wellness Program | Multiple industries Various worksites employing municipal works in one city (NR; 900) United States (Arkansas) | Municipal employees (multiple) | NR | NR | NR
Maes et al., 1998^28^ Brabantia Project | Manufacturing Producer of household goods (3; 264) The Netherlands | Blue-collar production workers | 39–41 (10.4–10.5) | NR | NR
Maniscalco et al., 1999^58^ Lafayette OBUWP | Oil and gas extraction Offshore crude oil exploration facility (1; 147) United States (Louisiana) | Production operators, platform repairmen (mechanical, electrical, and automation) | 42 (NR) | 10 | NR
Nieuwenhuijse, 2004^36^ Work Site Health Risk Project | Health care and social service Administrative office of a health maintenance organization (1; 40) United States (Michigan) | Administrative support and clerical workers, management, and data entry/computer programmers | 36 (range: 19–65) | 77 | NR
Okechukwu et al., 2009^25^ MassBUILT | Construction Building trade apprentice training program (10; 1,213) United States (Massachusetts) | Apprentice training participants (boilermakers; bricklayers; electricians; hoisting and portable engineers; ironworkers; painters; plumbers; pipefitters; and others) | 28–29 (6.7–6.9) | 4–6 | 15–18
Olson et al., 2009,^44^ Wipfli et al., 2013^45^ SHIFT Pilot Study | Transportation Carrier companies (4;29) United States (Pacific Northwest) | Truck drivers | 48 (10) | 21 | 3
Olson et al., 2015^43^ COMPASS | Health care and service Home care workers residing near Portland, Oregon (NA; 16) United States (Oregon) | Home care workers | 58 (8) | 94 | 33
Palumbo et al., 2012^29^ | Health care and service Hospital (academic medical center) (1; 14) United States (Vermont) | Registered nurses, licensed practical nurses on hospital wards requiring patient lifting | ≥ 49^c^ | 100 | NR
Porru et al., 1993^49^ | Manufacturing Small factories (bronze and brass foundries, lead shot production facilities, and pylon painting factory) (7; 50) Italy | Production workers with exposure to lead | 39 (range: 21–58) | NR | NR
Sorensen et al., 1998;^9^ Sorensen et al., 1996;^39^ Sorensen et al., 1995^40^ WellWorks | Manufacturing Worksites producing industrial, chemical, and other products; textile dyeing; firefighting; and newspapers (24; 2,658) United States (Massachusetts) | Blue-collar production workers, firefighters, textile dying machine operators^d^ | (%s) <35: 27 35-50: 51 >50: 23 | 24 | <4
Sorensen et al., 2003;^10^ LaMontagne et al., 2005;^26^ Hunt et al., 2005^27^ WellWorks-2 | Manufacturing Worksites associated with probable use of hazardous chemicals (15; 9,019) United States (Massachusetts) | Blue-collar (hourly) and white-collar (salaried) workers | (%s) Under 31: 12–16 31–40: 27–33 41–50: 28–32 51–60: 19–24 61–70: 4–5 71 or older: 0–1 | 34–43 | 15–22
Sorensen et al., 2005;^33^ Hunt et al., 2007;^34^ Barbeau et al., 2004^35^ Healthy Directions-Small Business | Manufacturing Worksites producing medical equipment, dog food, specialty pumps, textiles, and electronics; and laundry and printing service providers (26; 1,740) United States (Massachusetts) | Blue-collar workers (83–84%) and managers (16–18%) | 43–44 (NR) | 25–44 | 18–25
Sorensen et al., 2007^32^ Tools for Health | Construction Workers with membership in the Laborers' International Union of North America (NA; 674) United States (multiple states) | General laborers, concrete workers, heavy construction workers, demolition workers, jackhammer | 40–41 (9.5–9.7) | 5–6 | 30–37
Tveito and Eriksen, 2009^31^ | Health care and social service One nursing home for older people (1; 40) Norway | Nursing auxiliaries, nurses, assistants, other helping staff | NR | 100 | NR
von Thiele Schwarz et al., 2015^50^ | Health care and social service Inpatient units (12) in one county hospital (1; 312) Sweden | Registered nurses, assistant nurses, others with direct patient care | 45–47 (9.2–12.1) | 91–96 | NR

COMPASS = Community of Practice and Safety Support; N = number (of participants or worksites); NA = not applicable: NR = not reported; OBUWP = Offshore Business Unit Wellness Program; SD = standard deviation.

a When only the mean age per study arm (e.g., intervention and control groups) is provided, we present that as a range across groups.

b Employees with the following were excluded: acute illness or injury, self-reported cognitive impairments, psychosis or other severe psychological illness; self-reported chronic conditions (e.g., heart disease or cancer); workers who had a height-adjustable workstation; workers with BMI less than 25 kg/m^2^; and workers who reported sitting less than 75 percent of a typical work day.

c Mean age not reported; however, study enrolled nurses ages 49 years or older.

d More than half of the 24 worksites in the WellWorks study were described as comprising a majority of blue-collar workers, ranging from 52 percent of the workers at the high-volume battery manufacturing worksite to 98 percent of workers at the firefighting worksite; the investigators did not describe nonblue-collar workers in detail.

##### Geographic Setting

Sixteen of the 24 included studies were conducted in the United States.9,10,25,29,32,33,36-38,43,44,46-48,51,54 Six of these studies were conducted in Massachusetts;9,10,25,33,48,59 7 were conducted in various other states, including Vermont,29 Illinois/Indiana,38 Iowa,54Arkansas,37 Louisiana,47 Michigan,36 Pacific Northwest,44 and Oregon.43 One study enrolled construction and utility workers employed by a municipal public works department but did not describe the trial setting by state or city.55 Finally, one study enrolled workers from multiple states based on their affiliation with a labor union.32 Of the studies conducted outside the United States, 4 were set in Scandinavian countries (Norway, Denmark, Sweden),31,41,42,50 2 were set in The Netherlands,28,51 and 1 study each was set in Italy49 and Australia.30

##### Work Setting

The majority of studies included workers from the health care and social assistance, manufacturing, and construction industries. The degree to which studies described characteristics of worksites (e.g., types of workplace exposures or union representation) varied across included studies.

Seven studies enrolled workers from the health care and social assistance industry. Six of these focused on worksites providing direct patient care, including five set in worksites where workers are centralized (four in a hospital29,41,46,50 and one in a nursing home for the elderly31), and one study enrolled home care workers who were dispersed within a specific geographic area (near Portland, Oregon).43 Finally, one study enrolled administrative office workers employed at a health maintenance organization.36

Six studies enrolled workers from the manufacturing industry;9,10,28,33,38,49 all included multiple worksites (ranging from 3 to 26). Three studies described the potential occupational exposures associated with included worksites such as adhesives and abrasives,10 chemicals and textile dyes,9 and lead.49 Two studies described the extent of unionization across worksites; in one study, 5 of the 12 worksites randomized to the intervention were described as unionized,9 and the other study included worksites that varied in terms of the extent of unionization (5 percent to 80 percent of workers were unionized across 5 sites).38

Four studies enrolled workers from the construction industry. Two recruited workers from apprentice training programs affiliated with a labor union,25,48 and one recruited construction laborers employed at various worksites across the United States who are members of the Laborer's International Union of North America.32 One study enrolled both construction and utility workers employed in a municipal public works department.55

Four studies enrolled workers from various other industries, including finance,51 transportation and warehousing,42,44 agriculture,30 and oil and gas extraction;47 and one enrolled workers from various industries employed as municipal workers.37 One study enrolled sedentary office workers from a company employing >1,200 workers but did not describe any further details about the industry or work setting.54

##### Occupational Groups

Six studies enrolled health care workers who provide direct patient care.29,31,41,43,46,50 Five primarily enrolled skilled nurses, four of which also enrolled a minority of other occupational groups such as nursing aides or other staff involved with patient care;31,41,46,60 and one study enrolled home care workers.43

Three studies enrolled office workers from various industries. including administrative office workers employed at a health maintenance organization,36 office workers with mainly desk jobs in a financial institution,51 and sedentary office workers from a large private company in the Midwest (1,200 employees).54

Across the six studies set in manufacturing worksites, three enrolled a majority of blue-collar production workers,9,28,33 two enrolled blue- and white-collar workers (but did not report specific details),10,38 and one did not describe the specific occupational groups (but focused on workers who were exposed to lead).49

Four studies primarily enrolled construction workers; two recruited workers from apprentice training programs from various occupational groups, including iron workers25,48 boilermakers, bricklayers, ironworkers, and electricians, among others;25 one enrolled construction laborers,32 (e.g., general laborers, concrete workers, demolition workers and others); and one enrolled both construction and utility workers employed in a municipal public works department.55

Other studies focused on a range of occupational groups, including truck drivers.44 postal workers,42 farmers,30 blue-collar production workers employed at an offshore drilling site,47 and municipal workers in a variety of occupations.37

##### Other Population Characteristics

Across the 22 studies that reported on age, the mean age of enrolled workers ranged from 30 and 50 years of age (Table 4). Only 1 study evaluated a younger workforce (mean <30 years of age),25 and 2 studies evaluated an older workforce (mean >50 years of age);29,43 2 studies did not report on the age of enrolled workers.31,37 Across the 20 studies that reported the sex, 12 enrolled a majority of male workers and 8 enrolled a majority of female workers (Table 4); 4 studies did not describe the sex of enrolled workers.25,37,41,49

Studies set in the health care and service industry enrolled populations that were overwhelmingly female,29,31,36,43,46,50 with mean ages ranging from 35 to 47 years of age in four studies;36,41,46,50 two studies enrolled older populations, one enrolled home care workers with a mean age of 58 years,43 and the other recruited nurses ages 49 years or older.29 In the six studies set in the manufacturing industry, the mean age of workers ranged from 30 to 50 years of age; in the four studies that reported the sex of workers, enrolled populations were predominantly male.9,10,33,38 In the four studies focused on construction workers, populations were predominantly male, and the mean ages of enrolled workers ranged from 28 to 45 years of age.25,32,48

Eleven included studies described the race of enrolled workers, and all enrolled a majority of white participants; only two studies enrolled populations that were made up of more than 25 percent nonwhite workers.32,43 Across the four studies that described the ethnicity of workers, all included a minority of Hispanic workers, ranging from 2 to 5 percent in three studies,48,55,57 and 9 percent to 11 percent across arms in one study enrolling workers from manufacturing worksites that employ multiethnic populations.33

Five studies described the income of enrolled workers using various metrics; all five enrolled construction or manufacturing workers from worksites in the United States (four were published between 2003 and 2009,25,32,33,48 and one was published in 2015^48^).

Four studies described the baseline health status or comorbidity of included populations beyond specific factors related to the primary outcomes of the study (e.g., baseline body mass index [BMI] or smoking status). One study enrolled a population of home care workers with a high rate of depression (50 percent), anxiety (31 percent), and musculoskeletal complaints at baseline (>90 percent).43 One study enrolling manufacturing workers reported on the average number of comorbidities (mean=2).38 The third study enrolled administrative office workers; 15 percent of participants reported “great difficulty sitting” and 55 percent reported some kind of pain during the past 6 months.36 Finally, one study enrolled sedentary office workers with a BMI ≤25 (mean 33.0 to 34.5 across study arms).54

#### Interventions

Table 5 describes the characteristics of interventions evaluated across included studies, including the approach to integration and a summary of the specific components or content of the intervention.

Table 5 Characteristics of Total Worker Health interventions

Author(s), Year Study Name Industry Study Design (N Worksites; N Workers) | Approach to Integration | Complexity: Summary of Integrated Intervention Content
Allen et al., 2003^38^ International's Allergy Project Manufacturing NRCT (7; 519) | Organizational integration: Collaboration between OSH and HP staff to develop the intervention Integrated objective: Reducing unnecessary use of sedating allergy medications may improve overall worker health, reduce work injuries, and improve productivity | Multicomponent: Employee education about the appropriate medical treatment for allergies (via workplace newsletter, billboards, electronic alerts, and brochures); employees provided with an onsite consultation with an allergist
Barbeau et al., 2006^48^ MassBUILT Pilot Construction Pre/post (1;337) | Worker participation: Intervention developed based on worker input and collaboration with union representatives Integrated objective: Smoking cessation intervention highlights the additive and synergistic effects of hazardous workplace exposures and smoking | Multicomponent: Worksite tobacco cessation educational module taught by industrial hygienist highlighting synergistic effects of toxic exposures among ironworkers who smoke; included group behavioral counseling sessions and access to nicotine replacement therapy; workplace posters and newsletter articles reinforced intervention messages
Blackburn et al., 2009^30^ Sustainable Farm Families Project Agriculture Pre/post (NR; 128) | Integrated objective only: Intervention promoted safe farm work practices and healthy lifestyle behaviors | Multicomponent: Workshop series developed specifically for farmers focused on safe farming practices and promotion of overall health (e.g., education about safe work practices; health risk assessment and medical referrals if appropriate; supermarket tours, and other activities)
Boggild and Jeppesen, 2001^41^ Health care cohort (1; 172) | Worker participation: Worker collaboration with study investigators to guide intervention implementation Integrated objective: Investigators hypothesized that improvements in shift-work scheduling would reduce risk factors for heart disease (by facilitating healthy behaviors, decreasing stress, and improving sleep) | Single component: Modification of shift-work scheduling (e.g., promote more regular and predictable schedules, provide days off after night shifts, minimize weekend work, and rotate day/evening and night shifts).
Carr et al., 2015^54^ Not reported RCT (1; 60) | Integrated objective only: Investigators hypothesized that an integrated OSH and HP intervention aimed at sedentary office workers would result in increased occupational physical activity, improved risk factors for CVD, and decreased musculoskeletal discomfort compared with an OSH-only intervention. | Multicomponent: 30-minute face-to-face consultation aimed at optimizing workstation ergonomics; access to a portable elliptical machine placed under their desk for 16 weeks; provision of an iPod Touch to track daily pedaling behaviors; email reminders and pedaling goal sheet to promote increased activity during the intervention
Caspi et al., 2013^46^ Health care Pre/post (2; 374) | Worker participation: Workers collaborated with study investigators to guide intervention implementation. Integrated objective: Intervention aimed to reduce musculoskeletal disorders by simultaneously promoting safe patient handling and promoting physical activity. | Multicomponent: Workplace audit of hospital unit safety features; development of guidelines to improve coworker collaboration when moving patients; worksite posters and prompts to promote stretching and strength training breaks; monthly mentoring sessions provided to workers focused on safe patient handling, education, and information on worksite fitness resources
Coffeng et al., 2014^51-53^ Finance RCT (NR; 412) | Worker participation: Program resulted from a needs assessment (questionnaire and focus groups) conducted in the target population; employees received training to be team leaders and conducted group motivational interviewing sessions. Integrated objective: Investigators hypothesized that a combined intervention focused on work environment and group motivational interviewing would reduce work hazards and increase physical activity. | Multicomponent: Social environment intervention focused on a series of group motivational interviewing delivered by team leaders (employees who received training) aimed at increasing physical activity and relaxation; physical work environment intervention included multiple modifications aimed at creating a more relaxing environment and promoting physical activity (e.g., posters, plants, open office area with exercise balls, lounge area, and other changes).
Eriksen et al., 2002^42^ Transportation and warehousing RCT (31; 860) | Worker participation: Workers collaborated with study investigators to reduce occupational hazards. Integrated objective: Intervention focused on reducing occupational hazards and promoting healthy behaviors. | Multicomponent: Worksite evaluation (conducted by investigators) to identify potential work hazards (e.g., heavy lifts, repetitive motions); workers collaborated with investigators to reduce occupational hazards; to be educated about stress, coping, health, and nutrition; to engage in formal physical activity program (including exercise and strength training relevant to the work situation).
Hammer et al., 2015^55^ Construction^a^ RCT (NR; 292) | Worker participation: Worker participation in a facilitated team effectiveness session aimed at encouraging supportive behaviors related to safety, health, and work–life balance Integrated objective: Intervention focused on reducing risk factors for CVD (lowering blood pressure) by improving work–life stress and promoting safe work practices. | Multicomponent: Computer-based supervisor training focused on family and safety supportive behavior (e.g., emotional support, family-supportive role modeling, safety communications, and other topics); supervisor behavior tracking (self-monitored and tracked via software on an iPod Touch); 4-hour facilitated team effectiveness session (including supervisors and employees) to improve team planning and problem solving and to encourage supportive behaviors related to safety, health, and work–life balance
Hodges et al., 2004^37^ City of North Little Rock Employee Health and Wellness Program Multiple industries Pre/post (NR; 900) | Organizational integration and worker participation: Coordination across multiple organizational departments to implement intervention; an employee health and wellness steering committee gave feedback on programs and services Integrated objective: Intervention focused on providing comprehensive occupational medicine, primary care, and HP services. | Multicomponent: Provision of preplacement physicals for potential employees, free employee physicals, establishment of services to manage occupational injuries and workers' compensation cases, creation of comprehensive HP programing (e.g., health risk screening, educational classes), primary care services designed to reduce health care costs for workers and their families
Maes et al., 1998^28^ Brabantia Project Manufacturing NRCT (3; 264) | Organizational integration and worker participation: Formation of a joint management–staff advisory committee that consulted with workers to design and implement the intervention Integrated Objective: Intervention aimed at improving work conditions and reducing risk factors for CVD. | Multicomponent: Intervention focused on multiple improvements in work conditions (e.g., reorganization of the production line to improve ergonomic conditions), provision of onsite exercise facilities and lunchtime exercise sessions, smoking policy in cafeteria, healthy food and nutrition information in cafeteria, health fairs, health risk screenings and referrals to medical providers for high-risk factors^b^
Maniscalco et al., 1999^47^ Lafayette OBUWP Oil and gas extraction Pre/post (1; 147) | Organizational integration and worker participation: Intervention developed by managers, supervisors, and employees based on review of safety statistics; implementation guided by a committee that included employees and representatives from OSH and HP departments Integrated Objective: Intervention aimed at reducing occupational injury and improving levels of physical activity | Multicomponent: Establishment of an annual Back Power educational program during mandatory safety training (e.g., demonstrations of back exercises tor preventing injury), provision of onshore and offshore fitness facilities, group-based nutritional and smoking cessation program, annual subsidy for membership to local fitness facility, annual health risk appraisal
Nieuwenhuijse, 2004^36^ Work Site Health Risk Project Health care Pre/post (1; 40) | Worker participation: Workers participated in a Wellness Ergonomics Team that addressed ergonomic concerns and promotion of healthy behavior. Integrated objective: Intervention focused on reducing repetitive strain injuries and promoting healthy eating. | Multicomponent: Workshops focused on “at-risk” (for injury/strain) body areas and included tips for improving ergonomics, workplace posters and booklets promoted proper posture and preventive activities, assessments of work stations to identify and implement low-cost ergonomic solutions (e.g., keyboard or chair height), organization of healthy potluck lunches, modification of workplace vending machines to provide healthier options
Okechukwu et al., 2009^25^ MassBUILT Construction RCT (10;1,213) | Worker participation: Intervention developed based on worker input and union collaboration Integrated objective: Smoking cessation intervention highlights the additive and synergistic effects of hazardous work exposures and smoking. | Multicomponent: Tobacco cessation educational module highlighting synergistic effects of workplace exposures and cigarette smoking, posters displayed in worksites reinforced key concepts in the educational modules, group behavioral counseling sessions aimed at promoting healthy behavior, free nicotine replacement patches available to smokers
Olson et al., 2009;^44^ Wipfli et al., 2013^45^ SHIFT Pilot Study Transportation Pre/post (4; 29) | Integrated objective only: Intervention focused on losing weight and promoting safe driving behaviors. | Multicomponent: Self-paced computer training on trucking safety, group weight loss goals in a competition (with other teams of workers), biweekly individual feedback on personal weight loss goals, self-paced computer training on exercise and diet, motivational interviewing phone sessions with a health coach
Olson et al., 2015^43^ Community of Practice and Safety Support Health care Pre/post (NR; 16) | Worker participation: Workers participated as team leaders during monthly meetings addressing OSH concerns and HP. Integrated objective: Intervention focused on injury prevention and promotion of healthy behaviors | Multicomponent: Monthly meetings focused on HP (e.g., healthy eating, functional fitness, mental health education, and body relaxation exercises) as well as OSH topics (e.g., back posture, back strain prevention, and use of tools and communication for hazard correction)
Palumbo et al., 2012^29^ Health care RCT (1; 14) | Integrated objective only: Investigators hypothesized that the intervention would promote well-being and reduce work-related stress and absenteeism. | Single component: Tai chi classes aimed at reducing work-related musculoskeletal injuries and job stress and promoting physical activity and stress reduction in older nurses
Porru et al., 1993^49^ Manufacturing Pre/post (7; 50) | Integrated objective only: Intervention aimed at reducing work exposure to lead and promoting healthy behaviors | Multicomponent: Worksite inspections (e.g., cleanliness, potential for harmful exposures, availability/use of exhaust ventilation, and personal protection equipment [PPE]); educational meetings with workers focused on lead toxicology, proper safety practices, and the effect of tobacco and alcohol use in increasing lead absorption
Sorensen et al., 1998^9^; Sorensen et al., 1996^39^, Sorensen et al., 1995^40^; WellWorks Manufacturing RCT (24; 2,658) | Organizational Integration and worker participation: Joint worker–management participation in intervention planning and implementation (with study investigators) Integrated objective: Intervention aimed at reducing occupational exposures and promoting healthy behaviors. | Multicomponent: Worksite assessments by industrial hygienist with recommendations to employers, worksite environmental changes to increase availability of healthy foods (and decrease smoking), health education programs for employees related to nutrition and smoking cessation
Sorensen et al., 2003;^10^ LaMontagne et al., 2005;^26^ Hunt et al., 2005^27^ WellWorks-2 Manufacturing RCT (15; 9,019) | Organizational integration and worker participation: Formation of employee–management advisory boards (including representatives from workers, management, other departments, and health and safety representatives) that participated in planning, promoting, and implementing the intervention Integrated objective: Intervention aimed at reducing occupational exposures and improving health behaviors. | Multicomponent: Worksite hazard assessment by industrial hygienist (with feedback to employers); group educational sessions; educational materials; demonstrations and displays; consultations with management on tobacco control policies, food catering, and cafeteria policies; messages concerning smoking or nutrition and the interplay with occupational exposures; demonstration and displays; health risk self-assessment with feedback
Sorensen et al., 2005;^33^ Hunt et al., 2007;^34^ Barbeau et al., 2004^35^ Healthy Directions-Small Business Manufacturing RCT (26; 1,740) | Organizational integration and worker participation: Formation of employee advisory boards (composed of workers, management, and OSH representatives) to participate with investigators in the intervention planning and implementation Integrated objective: Intervention aimed at reducing occupational exposures and improving health behaviors. | Multicomponent: Worksite hazard assessment by industrial hygienist (with feedback to employers), promotion of worksite policies aimed at tobacco control and promoting healthy eating, group educational sessions (on physical activity, healthy eating, and smoking cessation), health fairs and other activities/written materials available to employees aimed at promoting healthy behaviors
Sorensen et al., 2007^32^ Tools for Health Construction RCT (NR; 674) | Worker participation: Intervention was developed based on worker input and union collaboration. Integrated objective: Intervention content focused on the synergies of hazardous work exposures (or conditions) and health behaviors. | Multicomponent: Baseline health survey with tailored feedback, one-on-one motivational interviewing focused on tobacco use and diet, provision of nicotine replacement therapy and counseling to participants interested in quitting tobacco, investigators creased and mailed tip sheets that reinforced messages and addressed synergy between work hazards and health behavior
Tveito and Eriksen, 2009^31^ Health care RCT (1; 40) | Worker participation: Workers gave input on ways to minimize work hazards identified during a workplace examination (by study investigators). Integrated objective: Intervention aimed at reducing work hazards (injuries and stress) and improving overall physical and mental health. | Multicomponent: Workplace examination (by study investigators) to identify potential work hazards; workers provided input on ways to manage work stress; onsite aerobic dance classes; educational sessions on stress, coping, and healthy lifestyle behaviors
von Thiele Schwarz et al., 2015^50^ Health care RCT (1; 312) | Organizational integration only: Integration of OSH and HP program management into staff quality improvement meetings | Single component: Integration of OSH and HP programs (and administrative functions) into an ongoing employee participatory continuous improvement system; OSH and HP issues were addressed and recorded in meeting minutes along with other quality improvement issues

BMI = body mass index; CVD = cardiovascular disease; HP = health promotion; mg/L = milligrams per liter; mm Hg = millimeters of mercury; N = number (of participants or worksites); NR = not reported; NRCT = nonrandomized controlled trial; OBUWP = Offshore Business Unit Wellness Program; OSH = occupational safety and health; PPE = personal protection equipment; RCT = randomized controlled trial.

a Also included utility workers.55

b High-risk criteria for referral to a general practitioner included the following: serum cholesterol level of 250 mg/L or higher; diastolic blood pressure 105 mm Hg or higher; systolic blood pressure 160 mm Hg or higher; BMI 30 or higher; or smoking 1 or more cigarettes per day.28

##### Approach to Integration

We developed inclusion and exclusion criteria for study interventions (as discussed in the Methods section); during data abstraction, we identified factors that have been highlighted as “indicators of integrated approaches.”11 All included studies assessed an integrated approach to reducing work-related injuries or illness and promoting overall health among workers. Included studies also used the following approaches to integration: (1) organizational integration (e.g., strategic coordination across organizational departments responsible for OSH, HP, and others) and (2) worker participation in the development, design, planning, or implementation of the intervention. Most included studies evaluated interventions that used more than one approach to integration.

###### Organizational Integration

Eight included studies evaluated an intervention that involved strategic coordination across organizational departments (or staff) responsible for decision making related to health protection and HP.9,10,28,33,37,38,47,50 Most focused on developing a comprehensive program to promote worker health and safety informed by staff from various departments (e.g., human resources, managers, OSH representatives, HP representatives, and others). One study assessed the effectiveness of integration alone (with no additional OSH or HP content or components); in this study, OSH and HP functions were integrated into ongoing staff meetings (focused on quality improvement).50

###### Worker Participation

Seventeen studies evaluated an intervention that involved worker participation in the development, design, planning, or implementation of the intervention.9,10,25,28,31-33,36,37,41,42,46-48,51,55 The type and degree of participation varied across included studies.

Six studies included worker participation on a committee with other organizational representatives (e.g., managers, human resource representatives, OSH and HP representatives) responsible for the design and implementation of the intervention9,10,33,37,47 or in consultation with such committees.28 Four studies evaluated an intervention that was designed based on input (or prior research) from members of a specific occupational group (e.g., related to culture, potential occupational hazards, or work experience) and implemented in collaboration with support from employees,51 union members,32 or apprenticeship program leaders.25,48

Finally, seven studies assessed an intervention that involved worker participation or collaboration with study investigators (but not other organizational representatives) related to a key feature of the intervention.31,36,41-43,46 In two of these studies, workers gave input or guidance on intervention implementation only,41,46 and in five studies workers participated with study investigators to develop strategies to reduce occupational hazards (e.g., work stress, work–life stress, or injuries)31,42,55 or develop ongoing meetings or workshops among groups of workers that addressed both OSH concerns and HP (e.g., through education and social support).36,43

###### Organizational Integration and Worker Participation

Six studies evaluated an intervention that featured both organizational integration and worker participation in the development, design, planning, or implementation of the intervention.9,10,28,33,37,47

###### Integrated Objective Only

Five included studies assessed an intervention that simultaneously addressed the prevention of work-related illness and injury and the promotion of overall health; these interventions were designed by investigators based on the potential work hazards and risk factors for chronic disease in a specific occupational group.29,30,44,49,54 None of these studies explicitly describes whether the intervention was designed (or implemented) based on input from employees or representatives across organizational departments responsible for OSH or HP decisionmaking.

##### Intervention Complexity and Content

Most studies evaluated complex multicomponent intervention “bundles” that included multiple components aimed at improving work safety and promoting health (generally involving changes at the worksite as well as content targeted at individual workers) (Table 5).9,10,26-28,30-40,42-47,51,54,55 Three interventions involved a single-component integrated intervention.29,41,50

The specific intervention content across included studies varied significantly. Only 1 study assessed the effectiveness of organizational integration alone (with no new added OSH or HP components).50 Six studies focused primarily on providing a new HP initiative that was tailored to the potential work hazards of an occupational group (or highlighted the potential synergistic effects of workplace exposures and health behavior),25,29,32,38,41,48 and 5 studies focused primarily on reducing occupational injuries, illnesses, or exposures (including work–life stress and job stress) and also included other components aimed at promoting healthy behavior.36,46,49,51,55 The remaining 12 studies assessed interventions that introduced new comprehensive OSH and HP programs not previously available to workers prior to the intervention.9,10,28,30,31,33,37,42-44,47,54

Interventions varied in terms of whether they were directed at the individual worker or worksite (or both). The majority of interventions included an educational or training component aimed at individual workers (e.g., workshops, educational materials, individual counseling, behavioral training). Nine studies assessed an intervention that included a worksite inspection (or audit of safety practices) to identify potential work hazards;9,10,28,31,33,36,42,46,61 in most cases, inspections were conducted by study investigators who used the inspection either to provide recommendations to employers (related to adopting proactive policies to reduce hazardous exposures)9,10 or to determine the specific work hazards (or ergonomic concerns) to address with workers.31,42 Four studies assessed an intervention that primarily focused on improving work organization, ergonomics, or the physical work environment; one was aimed at improving manufacturing ergonomic conditions,28 one assessed an ergonomic workstation intervention,54 one assessed modifications to shift-work schedules,41 and one included multiple changes to the physical work environment to create a more relaxing space and promote physical activity.51

##### Incentives

Several studies included incentives to promote participation in the intervention. Some of the incentives for participating included health-related items or services such as water bottles, stress relievers,28,37 or chair massages;51 raffles for cash,25,44,45,48 or other prizes;28,44,45,51 contests;10,26,27,33-35 and cash payments for participation in43 or completion of a program or survey.47,54,55

#### Comparators

Fifteen included studies had a concurrent control group; four 10,35,51,55 (all RCTs) compared an integrated intervention with an active comparator, and all others compared an integrated intervention with no intervention (or usual work practice). In one RCT, the integrated intervention was compared with an HP-only intervention,10 and in another RCT the integrated intervention was compared with an OSH-only intervention.54 Two RCTs compared four arms, including a comprehensive integrated intervention (aimed at reducing occupational hazards and promoting physical activity), two active-comparator arms that included one or more components of the comprehensive intervention, and a no-intervention control group.35,51

#### Outcomes

Table 6 summarizes the types of outcomes evaluated across included studies. Overall, studies included heterogeneous outcomes; few studies measured the same outcomes in similar populations of workers.

Of the 24 included studies, 12 measured a final health or safety outcome; commonly evaluated outcomes included measures of quality of life, self-reported somatic complaints, and stress (including job stress). Eighteen studies measured an intermediate outcome; these included a diverse range of biomarkers associated with cardiovascular risk (cholesterol and glucose levels), measures of smoking cessation, and dietary habits, among others.

Outcomes directly related to OSH were less commonly measured compared with outcomes traditionally associated with HP. Across the 24 included studies, 10 measured changes in job stress, work safety practices, ergonomic behavior, or self-reported exposure to hazardous chemicals.9,28,29,36,42-44,46,51,55 Two studies measured changes in occupational physical activity and sedentary behavior.51,54

One study evaluated rates of health care utilization37 (e.g., primary care visits, use of occupational medicine services), and two studies reported rates of occupational injuries based on an employer database or incidence of workers' compensation claims.38,47

No study prespecified harms of the intervention as outcomes to be evaluated; two studies surveyed participants about potential adverse effects of the interventions (results are discussed in KQ 2).41,43

Studies also evaluated a range of other outcomes that we did not include for KQ 2; these outcomes included worker productivity and absenteeism, decision latitude (i.e., the ability to make work-related decisions), and employee satisfaction with the intervention. Studies assessing absenteeism defined or measured absenteeism using different metrics or over various lengths of time.28,29,31,38,42,50 Three studies evaluated economic outcomes. One reported time lost costs,29 one evaluated costs associated with treatment for occupational injuries and insurance rate increases,37 and one calculated return on investment and net cost savings for all lost workday injuries and for only back injuries.47

## Key Question 2 Effectiveness and Harms of Total Worker Health Interventions

Evidence for the effectiveness and harms of TWH interventions consisted of 12 RCTs, 2 NRCTs, and 1 prospective cohort study.9,10,25,28,29,31-33,38,41,42,50,51,54,55 We rated 5 RCTs as medium risk of bias32,33,51,54,55 and the other 10 studies as high risk of bias.

We rated studies as high risk of bias primarily because of a high risk of selection bias. Most studies had high overall attrition (ranging from 14 percent to 45 percent); many studies had differential attrition across study arms. In general, studies rated high risk of bias did not use any statistical methods to address missing data. Other common areas of bias included baseline differences between groups that the investigators did not address in their analyses.

The results of all studies synthesized for KQ 2 are described below by outcome category. We report results of studies rated medium risk of bias first (for each eligible outcome) and then results of studies rated high risk of bias. We also note the SOE grades (high, moderate, low, or insufficient) where relevant.

### Key Points

- The 15 KQ 2 studies were heterogeneous; few studies of TWH interventions assessed the same outcomes among similar populations of workers.
- TWH interventions were effective for improving rates of self-reported 7-day smoking abstinence over 22 to 26 weeks compared with no intervention (low SOE).
- TWH interventions were effective for improving fruit and vegetable consumption over 26 to 104 weeks compared with no intervention (low SOE).
- TWH interventions were effective for reducing sedentary activity at work over 16 to 52 weeks compared with any comparator (low SOE).
- Evidence was insufficient to assess the effectiveness of integrated interventions for improving the following outcomes: quality of life, stress, blood pressure, weight, overall and work-specific levels of physical activity, consumption of red meat, safety behaviors, and safety compliance.

### Health and Safety Outcomes

#### Quality of Life and Functional Status

Three studies reported on quality of life or functional status (Table 7). One RCT (N=116) rated medium risk of bias assessed improvement in quality of life among construction and utility workers using the SF-12.^55^ Groups of workers were randomized to an intervention designed to improve work–life stress and safety behaviors (via supervisor behavior training and employee work groups) or no intervention. At 52 weeks, there was no difference between groups on the SF-12 physical health component composite scores.55

Table 7 Results of quality of life and functional status outcomes

Author, Year, Study Design Risk of Bias | Arm (N) Outcome Timing (Weeks) | Quality of Life Outcomes Results | Functional Status Outcome Results
Hammer, et.al., 2015^55^ RCT Medium | G1: Integrated intervention (NR) G2: No intervention (NR) Total N=264 52 | SF-12 physical health component summary score Difference between groups on post-intervention score (SE): = -0.32 (0.82); p=0.69 | NR
Palumbo et al., 2012^29^ RCT High | G1: Tai chi (7) G2: No intervention (7) 15 | SF-36 General Health Score Mean change from baseline (SD) GI: +0.6 (7) G2: -4.0 (4.2) p=0.33 SF-36 Mental Health Score Mean change from baseline (SD) G1: +2.5 (9.3) G2: -7.0 (9.1) p=0.62 | WLQ, Mean change from baseline (SD) Overall score: G1: -3.1 (1.2) G2: -0.8 (1.4) p=0.03 Physical demands Subscale: G1: -10.4 (11.7) G2: -2.5 (8.1) p=0.14 Mental demands Subscale: G1: -11.1 (10.1) G2: 0 (6.6) p=0.03
Tveito and Eriksen, 2009^31^ RCT High | GI: Integrated intervention (19) G2: No intervention (21) 36 | SF-36 General Health Score Mean score (95% CI) G1: Baseline: 42.3 (95% CI, 37.8 to 46.8) Post-test: 49.4 (95% CI, 43.5 to 55.3 G2: Baseline: 45.7 (95% CI, 41.7 to 49.7) Post-test: 44.7 (95% CI, 38.1 to 51.2) p=0.27 (difference between G1 and G2 post-tests) SF-36 Mental Health Score Mean score (95% CI) G1: Baseline: 47.3 (95% CI, 42.7 to 51.9) Post-test: 52.9 (95% CI, 48.4 to 57.3) G2: Baseline: 45.7 (95% CI, 41.7 to 49.7) Post-test: 49.8 (95% CI, 45.9 to 53.7) p=0.98 (difference between G1 and G2 post-tests) | NR

CI = confidence interval; G = group; N = number of participants analyzed; NR = not reported; RCT = randomized controlled trial; SD = standard deviation; SE = standard error; SF-12 = Medical Outcomes Study Short Form (12 items); SF-36 = Medical Outcomes Study Short Form (36 items); WLQ = Work Limitations Questionnaire.

Two small RCTs (both high risk of bias) assessed improvements in quality of life among health care workers using the SF-36; both compared an integrated intervention with no intervention.29,31 One (N=15) evaluated a single-component intervention (tai chi classes) aimed at improving stress and reducing risk of musculoskeletal injuries among older nurses (ages 49 years or older).29 The other study (N=21) assessed a multicomponent intervention featuring employee participation in addressing work hazards and promoting physical exercise and stress management among nursing staff in a nursing home for the elderly.31 Neither study found that the intervention significantly improved quality of life as measured by the SF-36 general health and mental health scores (Table 7).

The RCT evaluating tai chi among older nurses also assessed improvements in work-specific physical and psychological function measured by the Work Limitations Questionnaire (WLQ) (Table 7).29 The WLQ measures the degree to which health problems interfere with the ability to perform job roles.62 At 15 weeks, nurses receiving the intervention experienced an improvement in overall work limitations compared with nurses receiving no intervention.29 The intervention was not associated with improvements in physical demands but was associated with improvements in mental demand, as measured by the two WLQ subscales.

#### Stress (General and Work Specific)

Three studies reported on a measure of stress (Table 8). One RCT (N=412) rated medium risk of bias enrolled office workers employed at a financial institution in the Netherlands; departments were randomized to one of the following four groups: (1) no intervention control group, (2) social environment intervention, (3) physical environment intervention, and (4) combined social and physical environment intervention.51 At 52 weeks, workers in the combined intervention group experienced greater reduction in exhaustion measured by the Oldenburg Burnout Inventory than the control group63 (Table 8). There was no difference between the control group and any of the three active comparator arms on the following outcomes: need for recovery after work, detachment after work, and relaxation after work.

Table 8 Results of general and work-specific stress outcomes

Author, Year, Study Name Study Design Risk of Bias | Arm (N) Outcome Timing (Weeks) | Stress Outcome Results
Coffeng, et al., 2014^51^ RCT Medium | G1: Combined social and physical environment intervention (92) G2: Social environment intervention (118) G3: Physical environment intervention (96) G4: No intervention (106) 52 | Difference between active comparator and control group, beta coefficient (95% CI)^a^: Need for recovery^b^: G1 vs. G4: -6.8 (-14 to 0.4); p=0.07 G2 vs. G4: -2.3 (-8.7 to 4.2); p=0.49 G3 vs. G4: -4.2 (-11 to 2.7); p=0.23 Work-related stress Exhaustion^c^: G1 vs. G4: -0.2 (-0.3 to -0.1); p<0.01 G2 vs. G4: -0.1 (-0.1 to 0.0); p=0.13 G3 vs. G4: -0.1 (-0.2 to 0.0); p=0.23 Detachment after work^d^: G1 vs. G4: 0.0 (-0.3 to 0.3); p=0.85 G2 vs. G4: 0.1 (-0.1 to 0.4); p=0.35 G3 vs. G4: 0.2 (-0.1 to 0.5); p=0.16 Relaxation after work^d^: G1 vs. G4: 0.1 (-0.2 to 0.4); p=0.55 G2 vs. G4: 0.1 (-0.1 to 0.4); p=0.25 G3 vs. G4: 0.2 (-0.1 to 0.5); p=0.12
Maes et al., 1998^28^ The Brabantia Project NRCT High | G1: Integrated intervention (113) G2: No intervention (113) 156 | Symptom Checklist-90 Mean change from baseline: G1: -0.01 G2: 0 p-value: NS
Palumbo et al., 2012^29^ RCT High | G1: Tai chi (7) G2: No intervention (7) 15 | General stress: PSS, mean change from baseline (SD) G1: -2.8 (2.4) G2: -1.4 (3.9) p=0.42 Work-specific stress: NSS, mean change from baseline (SD) G1: -6.1 (14.2) G2: -1.6 (2.4) p=0.89

CI = confidence interval; G = group; N = number of workers; NRCT = nonrandomized controlled trial; NS = not significant; NSS = Nursing Stress Scale; PSS = Perceived Stress Scale; RAND-36 = 36-Item Short Form Survey from the RAND Medical Outcomes Study; RCT = randomized controlled trial; SD = standard deviation; vs. = versus.

a Outcomes are adjusted for age, gender, education, marital status, general health (measured with a single item, “In general, how would you rate your health?” on a 5-point scale (1 = poor to 5 = excellent) from the Dutch validated version of the RAND-36), job demands, supervisor support, and corresponding baseline measure of the outcome variable. A negative beta indicates a decrease in the outcome measure.51

b Assessed using the Need for Recovery after Work scale (score of 0 to 100 with higher scores reflecting greater need). Beta scores used as measures of intervention effect, with negative scores reflecting [underlined: lower need for recovery] compared with no intervention group.51

c Measured using the Oldenburg Burnout Inventory (score of 1 to 4 ranging from “totally agree” to “don't agree”).51

d Measured using the Recovery Experience Questionnaire (score of 1 to 7 ranging from “never” to “always”)51

Two studies rated high risk of bias measured changes in levels of stress, one RCT29 and one NRCT.28 The tai chi intervention (described above) assessed general levels of psychological stress with the Perceived Stress Scale (PSS),64 and work-specific stress was assessed with the Nursing Stress Scale (NSS).65 At 15 weeks, the intervention group did not experience lower PSS scores or NSS scores compared with the control group (Table 8).29

The NRCT enrolled Dutch manufacturing worksites and assigned worksites to a multicomponent integrated intervention aimed at improving work conditions and promoting physical activity or no intervention.28 General levels of stress were assessed with the Symptom Checklist-90 (SCL-90); at 3 years, levels of stress did not differ between workers employed at intervention sites and those at control sites (Table 8).28

#### Allergy Symptoms

No study rated as low or medium risk of bias assessed improvements in allergy symptoms.

One NRCT (high risk of bias) assessed a multicomponent intervention involving organizational integration between OSH and HP staff to promote appropriate use of allergy medications compared with no intervention.38 At 28 weeks, self-reported allergy severity did not differ between workers employed at intervention worksites and those at control worksites (change from baseline, intervention: range -1.2 to 2.8; control=-0.09; p= not significant per authors).38

#### Subjective Health Complaints and Self-Rated Health Status

Four studies measured self-reported health complaints (including musculoskeletal complaints). One RCT (N=54) rated medium risk of bias assessed self-reported musculoskeletal discomfort in a population of sedentary office workers using the Standardized Nordic Musculoskeletal Symptom Questionnaire.54,66 Enrolled workers were randomized to an ergonomic workstation optimization intervention or an integrated intervention that included the same ergonomic intervention plus access to a seated activity permissive workstation. At 16 weeks, there was no difference between groups on self-reported low back pain (p=0.94), neck pain (p=0.68), or shoulder pain (p=0.34) (data not presented by authors).54

Two RCTs (both high risk of bias) assessed subjective health complaints using the Subjective Health Complaints (SHC) Inventory.31,42 The SHC Inventory assesses subjective health complaints across five subscales: musculoskeletal pain, pseudoneurology, gastrointestinal problems, allergy, and influenza.67 One RCT (N=40) enrolled staff at a nursing home in Norway;31 the other RCT (N=860) enrolled Norwegian postal service workers.42 Both evaluated a similar multicomponent integrated intervention that included worker participation in addressing potential work hazards, promoting physical exercise, and managing stress; one compared the intervention with no intervention31 and the other compared the integrated intervention with three arms (an aerobic activity intervention, a stress management intervention, and a no-intervention control group).42 At 52 weeks, SHC subscales did not improve among workers receiving the integrated intervention compared with workers in a control group in either study.31,42 However, in the study enrolling postal workers, the intervention group reported fewer neck complaints than the control group (8 percent versus 48 percent, respectively; p=0.023) at 52 weeks; reports of complaints specific to the upper back or lower back did not differ between the intervention and control group.31

One RCT (N=312) (high risk of bias) compared organizational integration of OSH and HP functions with no integration. The study enrolled inpatient staff at a Swedish hospital; responsibility for OSH and HP activities was incorporated into ongoing quality improvement meetings.50 The investigators assessed self-rated health using a single item; participants rated their current health status on a five-point scale (“very good” [1] to “very poor” [5]). Change from baseline in self-rated health did not differ between the integrated intervention and control groups at 52 or 104 weeks (p=0.72).50

### Intermediate Outcomes

#### Smoking Cessation

Five studies assessed rates of smoking cessation (Table 9). One RCT rated medium risk of bias (N=188) enrolled unionized construction laborers and compared a multicomponent intervention designed in collaboration with union representatives with no intervention.32 More workers at intervention worksites reported 7-day abstinence at 26 weeks (for any tobacco use and for smoking) and made more smoking quit attempts than workers at control sites (Table 9).

Table 9 Results of smoking-related outcomes

Author, Year, Study Name Study Design Risk of Bias | Arm (N)^a^ Outcome Timing (Weeks)^b^ | Smoking Cessation Outcomes Results | Other Smoking Outcomes Results
Okechukwu et al., 2009^25^ MassBUILT RCT High | G1: Integrated intervention (251) G2: No intervention (239) 22, 43 | % of baseline smokers reporting 7-day abstinence at 22 weeks: G1: 26% G2: 17% p=0.014 % of baseline smokers reporting 6-month abstinence at 43 weeks: G1: 9% G2: 7% p=0.48 | Cut down by at least ½ pack smoked daily at 43 weeks: OR, 3.13 (95% CI, 1.55 to 6.31) % of baseline smokers who made at least one quit attempt at 43 weeks: OR, 1.31 (95% CI, 0.88 to 1.96) % of workers reporting a decrease in the number of days smoked at 43 weeks: OR, 1.18 (95% CI, 0.62 to 2.25)
Sorensen et al., 1998^9,39,40^ WellWorks RCT High | GI: Integrated Intervention (NR) G2: No intervention (NR) Overall N: 549^c^ 104 | % of baseline smokers reporting 6-month abstinence, overall sample: G1: 15% G2: 9% p=0.123 % of baseline smokers reporting 6-month abstinence, subgroup of skilled and unskilled laborers (N=NR): G1: 17.9% G2: 9.0% p=NS % of baseline smokers reporting 6-month abstinence, subgroup of office workers (N=NR): G1: 2.5% G2: 5.1% p=NS % of baseline smokers reporting 6-month abstinence, subgroup of professionals and managers (N=NR): G1: 14.2% G2: 18.6% p=NS | Not reported
Sorensen et al., 2003^10,26,27^ WellWorks-2 RCT High | G1: Integrated intervention (436) G2: HP alone (389) 104 | % of baseline smokers reporting 6-month abstinence, overall sample: G1: 11.3% G2: 7.5% p=0.17 % of baseline smokers reporting 6-month abstinence, subgroup of hourly workers (N=684): G1: 11.8% G2: 5.9% p=0.04 % of baseline smokers reporting 6-month abstinence, subgroup of salaried workers (N=141): G1: 9.9 % G2: 12.7% p=0.63 | Not reported
Sorensen et al., 2007^32^ Tools for Health RCT Medium | G1: Integrated intervention (any tobacco use, N=134; smokers, N=101) G2: No intervention (any tobacco use, N=113; smokers, N=87) 26 | % of baseline smokers reporting 7-day abstinence: G1: 19% G2: 8% p=0.03 % of baseline tobacco users reporting 7-day abstinence (any tobacco use): G1: 19% G2: 7% p=0.005 | % of baseline smokers who made at least one smoking quit attempt: G1: 53% G2: 35% p=0.03
Boggild and Jeppesen, 2001^41^ Cohort study High | G1: Improvements in shift work (26) G2: No intervention (60) 24 | % of workers who smoked at baseline: G1: 27% G2: 27% Median change from baseline (IQR): G1: 0 (0) G2: 0 (0) p=NS | Not reported

CI = confidence interval; G = group; IQR = interquartile range; N = number of participants analyzed; NR = not reported; NS = not significant (p-value not reported by authors); OR = odds ratio; RCT = randomized controlled trial.

a N here is for the subgroup of smokers (unless otherwise stated).

b Unless otherwise specified, this is the timing of outcome assessment in relationship to the baseline survey.

c This was the number of smokers who responded to baseline and followup assessments; the study reports that in the cohort of participants who responded to both baseline and followup assessments, 23% were smokers.9

Four RCTs rated high risk of bias assessed rates of smoking cessation. Three evaluated a multicomponent integrated intervention involving organizational integration and employee participation, two enrolled manufacturing workers,9,10 and one enrolled building trade apprentice training program participants.25 One RCT (N=825) compared an integrated intervention with an HP-only intervention; the 6-month abstinence rate did not differ between intervention and control groups at 2 years.10 In a subgroup of hourly workers, more workers at intervention worksites reported 6-month abstinence than those employed at control worksites.10 Two RCTs compared an integrated intervention with no intervention.9,25 One found a reduced 7-day abstinence rate at intervention worksites compared with control worksites at 22 weeks.25 Both RCTs also measured 6-month abstinence rates at longer outcome timings (43 to 104 weeks); there was no difference in 6-month abstinence rates between intervention and control groups in either study (Table 9).

The cohort study of Danish inpatient nurses found that improving shift-work scheduling was not associated with lower rates of smoking over 24 weeks (measured as the percentage of employees who reported smoking).41

#### Alcohol Consumption

No included studies rated medium or low risk of bias assessed changes in alcohol consumption.

The cohort study of Danish nurses (high risk of bias) described above assessed the effect of improving shift-work scheduling on alcohol intake. The median alcohol consumption per week did not differ between the intervention and control groups at 24 weeks (median change from baseline =0 in both groups; p=not significant per authors).41

#### Healthy Eating

Four RCTs (all from the same research team) measured outcomes related to healthy eating behaviors among U.S. manufacturing or construction workers (Table 10); two RCTs were rated medium risk of bias32,33 and two high risk of bias.9,10

Table 10 Results of healthy eating outcomes

Author, Year, Study Name Study Design Risk of Bias | Arm (N) Outcome Timing (Weeks) | Consumption of Fruit and Vegetable Outcomes Results | Other Healthy Eating Outcomes Results
Sorensen et al., 1998^9,39,40^ WellWorks RCT High | GI: Integrated intervention (NR) G2: No intervention (NR) Overall N=2,386 104 | Servings per day, mean change from baseline: G1: 0.22 G2: 0.09 p=0.04 | Daily fiber intake (grams per 1,000 kcal), mean change from baseline, overall sample: G1: 0.58 G2: 3.39 p=0.08 Subgroup of skilled and unskilled laborers: G1: 0.89 G2: 0.36 p=0.012 Subgroup of office workers: G1: 0.11 G2: 0.29 p=NS Subgroup of professionals and managers: G1: 0.47 G2: 0.57 p=NS Number of kcal consumed as fat, % change from baseline, overall sample: G1: -3.36 G2: -1.55 p=0.01
Sorensen et al., 2003^10,26,27^ WellWorks-2 RCT High | G1: Integrated intervention (2,413) G2: HP alone (2,214) 104 | Servings per day, mean change from baseline: G1: - 0.10 G2: +0.05 p=0.24 | NR
Sorensen et al., 2005^33-35^ Healthy Directions-Small Business Study RCT Medium | G1: Integrated intervention (NR) G2: No intervention (NR) Overall N=3,092^a^ 78^b^ | % of participants consuming 5 or more servings of fruits and vegetables per day, mean change from baseline, overall sample: G1: +5.4% G2: +1.7% p=0.41 Subgroup of managers: G1: -5.5% G2: +3.6% p=0.048 Subgroup of workers: G1: +7.5% G2: +1.1% p=0.048 | % of participants consuming 3 or fewer servings of red meat per week, mean change from baseline: G1: +4.1% G2: +3.0% p=0.72
Sorensen et al., 2007^32^ Tools for Health RCT Medium | G1: Integrated intervention (298) G2: No intervention (280) 26 | Servings per day, mean change from baseline: G1: +1.52 (SD=3.89) G2: -0.09 (SD=3.31) p<0.0001 | NR

G = group; kcal = kilocalorie; N = number of participants analyzed; NR = not reported; NS = not significant; RCT = randomized controlled trial; SD = standard deviation.

a Per the authors, 974 workers responded to both the baseline and followup survey. This “embedded cohort” is included in the overall analysis but results are not reported separately for this group.33

b 18 months.33

Two RCTs rated medium risk of bias assessed a multicomponent intervention aimed at improving healthy eating by highlighting the potential adverse effect of work conditions (or exposures) and health behavior.32,33 One (N=3,092) enrolled manufacturing worksites and randomized worksites to an integrated intervention or no intervention.33 At 78 weeks, there was no difference between groups in fruit and vegetable consumption; however, in a subgroup analysis based on job type, hourly workers at intervention worksites increased consumption of fruit and vegetables more than workers at control sites (managers at intervention sites decreased consumption of fruit and vegetable from baseline to followup) (Table 10).33 The other RCT (N=578) enrolled unionized construction workers and randomized workers to an integrated intervention (the intervention primarily delivered via phone calls and published educational materials) or no intervention;32 at 26 weeks, there was no difference between groups in fruit and vegetable consumption.

Two RCTs rated high risk of bias enrolled manufacturing workers;9,10 both assessed multicomponent interventions that included organizational integration and employee participation. One compared an integrated intervention with an HP-only intervention;10 fruit and vegetable consumption did not differ between the intervention and HP-control groups at 104 weeks.10 The other RCT compared an integrated intervention with no intervention; at 104 weeks, workers at intervention sites increased intake of fruit and vegetables and decreased intake of red meat compared with workers at control sites.9 Workers at intervention and control sites did not differ in the change from baseline fiber intake. However, in a subgroup analysis based on job type, skilled and unskilled laborers at intervention sites increased fiber consumption more than laborers at control sites; there was no significant difference for other groups of workers (office workers, professionals, and managers).9

#### Physical Activity

Four studies measured changes in physical activity (Table 11); three were RCTs rated medium risk of bias.33,51 One RCT (N=3,092) randomized manufacturing worksites to a multicomponent integrated intervention or no intervention.33 The mean change from baseline in the percentage of employees who exercised 2.5 hours or more per week did not differ between intervention and control worksites in the overall sample; in a subgroup analysis based on job type, workers at intervention worksites increased levels of physical activity, while managers at intervention worksites decreased levels of physical activity (Table 11). The second RCT enrolled Dutch office workers employed at a financial institution; departments were randomized to one of the following four arms: (1) no intervention control group, (2) social environment intervention, (3) physical environment intervention, and (4) combined social and physical environment intervention.51 At 52 weeks, there was no difference between any of the active comparators and the control group on any measure of overall physical activity (nonwork specific) (Table 11).51 Workers in the physical environment intervention increased the frequency of stair climbing at work and decreased sedentary activity at work compared with the control group; there was no difference between the other two active comparators (social environmental intervention and combined social and physical environmental intervention) and the control group on any measure of work-specific physical activity or sedentary behavior outcome (Table 11). The third RCT (N=60) randomized sedentary office workers to a workstation optimization intervention (ergonomic assessment, education and prompts to promote breaks and posture variation) plus access to a seated activity permissive workstation or the workstation optimization intervention alone.54 At 16 weeks, there was no difference between groups on the following outcome measures: total occupational physical activity, percentage of work time sedentary, and percentage of work time spent in moderate or vigorous physical activity (Table 11). Workers randomized to the integrated intervention increased the average percentage of the work day spent in light-intensity physical activity compared with the ergonomic intervention alone (difference between groups in mean change from baseline=1.1 percent; p=0.04); however, workers in the ergonomic intervention group experienced a decrease in time spent in light activity (-0.4 percent) compared with a small increase in the intervention group (0.7 percent).55

Table 11 Results of physical activity outcomes

Author, Year, Study Name Study Design Risk of Bias | Arm (N) Outcome Timing (Weeks) | General Physical Activity Outcome Results | Work-Specific Physical Activity Outcome Results
Carr et al., 2015^54^ RCT Medium | G1: Integrated intervention (30) G2: OSH-only intervention (30) 16 | NR | Mean change from baseline (95% CI): Total occupational physical activity (average counts/work day)^a^: G1: 9752 (1, 067 to 18,436) G2: -142 (-10,623 to 10,339) Between group difference p=0.14 Work time sedentary (% of work day): G1: -2.0 (-4.4 to 0.3) G2: -0.4 (-1.1 to 0.2) Between group difference p=0.08 Work time in light intensity physical activity (% of work day): G1: 0.7 (-0.2 to 1.7) G2: -0.4 (-1.1 to 0.2) Between group difference p=0.04 Work time in moderate intensity physical activity (% of work day): G1: 1.1 (-1.1 to 3.2) G2: 0.07 (-0.7 to 0.8) Between group difference p=0.38 Work time in vigorous intensity physical activity (% of work day): G1: 0.3 (0.0 to 0.5) G2: 0.0 (-0.3 to 0.3) Between group difference p=0.44
Coffeng, et al., 2014^51^ RCT Medium | G1: Integrated intervention (social and physical environment intervention) (92) G2: Social environment intervention (118) G3: Physical environment intervention (96) G4: No intervention (106) 52 | Difference between active comparator and control group, beta coefficient (95% CI; p-value)^b^: Light physical activity: G1 vs. G4: -37.3 (-396.8 to 322.2), p=0.84 G2 vs. G4: -322.5 (-665.5 to 20.5), p=0.07 G3 vs. G4: -217.1 (-573.6 to 139.4); p=0.23 Moderate physical activity: G1 vs. G4: 54.8 (-58.1 to 171.8); p=0.36 G2 vs. G4: 63.1 (-48.9 to 175.2), p=0.27 G3 vs. G4: 6.8 (-108.1 to 121.7), p=0.90 Vigorous physical activity: G1 vs. G4: -38.5 (-88.0 to 11.0), p=0.13 G2 vs. G4: -11.6 (-59.3 to 36.2), p=0.64 G3 vs. G4: -4.6 (-53.2 to 44.0), p=0.86 Leisure activities c: G1 vs. G4: -41.5 (-155.9 to 72.8), p=0.48 G2 vs. G4: 33.5 (-76.9 to 144.0), p-0.55 G3 vs. G4: -28.0 (-141.1 to 85.2), p=0.63 Sport activities c: G1 vs. G4: -18.9 (-77.1 to 39.3), p=0.52 G2 vs. G4: 30.4 (-22.0 to 82.7), p=0.25 G3 vs. G4: 3.6 (-51.2 to 58.6), p=0.83 | Difference between active comparator and control group, beta coefficient (95% CI), p-value): Stair climbing at work (number of times participants took the stairs during a usual workday): G1 vs. G4: 0.5 (-0.0 to 1.1), p=0.05 G2 vs. G4: -0.1 (-0.6 to 0.4), p=0.63 G3 vs. G4: 1.0 (0.5 to 1.5), p <0.01 Active commuting^c^ (minutes per week): G1 vs. G4: 142.0 (-5.5 to 289.6), p=0.06 G2 vs. G4: -8.3 (-150.0 to 133.4), p=0.91 G3 vs. G4: 91.9 (-53.8 to 237.5), p=0.22 Sedentary behavior at work (minutes per day): G1 vs. G4: -33.8 (-90.3 to 22.7), p=0.24 G2 vs. G4: -29.8 (-80.3 to 20.8), p=0.28 G3 vs. G4: -57.9 (-111.7 to 4.2), p=0.03
Sorensen et al., 2005^33-35^ Healthy Directions-Small Business Study RCT Medium | G1: Integrated intervention (NR) G2: No intervention (NR) Overall N=3,092^d^ 78 | Change from baseline in the percentage of participants who exercise ≥2.5 hours per week, overall sample: G1: +5.4% G2: -0.9 % p=0.23 Subgroup of managers: G1: -2.0 % G2: +3.7 % p=0.09 Subgroup of workers: G1: +7.1 % G2: -2.1 % p=0.09 | NR
Boggild and Jeppesen, 2001^41^ Cohort study High | G1: Improvements in shift work (26) G2: No intervention (60) 24 | No exercise at baseline (%): G1: 12% G2: 7% Median change from baseline (IQR): G1: 0 (1) G2: 0 (0) p=NS | NR

CI = confidence interval; G = group; N = number of participants analyzed; NR = not reported; NS = nonsignificant; OSH = occupational safety and health; RAND-36 = 36-Item Short Form Survey from the RAND Medical Outcomes Study; RCT = randomized controlled trial.

a Measured via an ankle-worn accelerometer; this is the sum of all activity counts accumulated on valid accelerometer wear days. Days participants wore the monitor for <12 hours were excluded from the analysis.54

b All outcomes below are adjusted for age, gender, education, marital status, general health (measured with a single item, “In general, how would you rate your health?” on a 5-point scale [1 = poor to 5 = excellent] from the Dutch validated version of the RAND-36), job demands, supervisor support, and corresponding baseline measure of the outcome variable. A negative beta indicates a decrease in the outcome.51

c Physical activity levels were measured using the Short Questionnaire to Assess Health-enhancing Physical Activity Questionnaire. Active commuting refers to walking or cycling to and from work. Leisure activities include walking, cycling, gardening, chores, and sports. Employees were asked to report the frequency (times per week), duration of activities (in minutes), and self-reported intensity (light, moderate, or vigorous).

d Per the authors, 974 workers responded to both the baseline and followup survey. This “embedded cohort” is included in the overall analysis, but results are not reported separately for this group.33

The cohort study of Danish nurses (high risk of bias) assessed the effect of improving shift-work scheduling (e.g., increased shift regularity) on outcomes associated with cardiovascular disease (CVD) risk over 24 weeks.41 The mean change from baseline in the percentages of workers who reported not exercising did not differ between the intervention and control groups (Table 11).

#### Cholesterol

No included study rated low or medium risk of bias measured changes in cholesterol levels.

The Danish nurses' cohort study assessed the effect of improving shift-work scheduling on cholesterol levels over 24 weeks.41 Workers in the intervention group had significantly lower low density lipoprotein (median change from baseline, mmol/L=-0.2 versus 0.1; p=0.001) and total cholesterol levels (median change from baseline, mmol/L=-0.1 versus 0.0; p=0.003) than workers in the control group; the groups did not differ in high density lipoprotein levels (mean change from baseline, mmol/L=0.1 versus -0.1; p=0.18).41

#### Blood Pressure

Two RCTs rated medium risk of bias assessed changes in blood pressure.54,55 One (N=116) enrolled construction and utility workers and randomized work groups to an integrated intervention aimed at improving work–life stress (via supervisor behavior training and employee work groups) or no intervention.55 Blood pressure was measured via three consecutive readings during one visit; the authors report only the mean arterial blood pressure (MAP) (defined as 1/3 systolic blood pressure + 2/3 diastolic blood pressure) based on the average of the three readings. The baseline MAP was 95.45 mmHg; the number of workers who had hypertension or who were treated with blood pressure medication is not reported. At 52 weeks, there was a small statistically significant improvement in MAP in the intervention group compared with controls (change in MAP=-2.15 mm Hg; SE=1.03; p=0.038).55 The second RCT (N=54) randomized sedentary office workers to an ergonomic workstation optimization intervention alone or an integrated intervention that included the same ergonomic intervention plus access to a seated activity permissive workstation.54 At 16 weeks, there was no difference between groups in systolic blood pressure (p=0.90) or diastolic blood pressure (p=0.48).54

#### Cardiovascular Disease Risk Scores

No included study rated low or medium risk of bias assessed changes in a CVD risk score.

One NRCT (N=264) rated high risk of bias of Dutch manufacturing workers (described above) assigned worksites to a multicomponent integrated intervention or no intervention.28 At 1 year, the intervention group experienced a small but statistically significant decrease in CVD risk score compared with the control group (change from baseline, intervention=-0.002 versus control: 0.007; p=0.01); the difference was not sustained at 2 years. At 2 years, both groups experienced a small overall increase in CVD risk from baseline (intervention=0.008 versus control=0.01); the between-group difference is small and the authors did not report a measure of variance for this observation.28

#### Hazardous Work Exposures

No included study rated low or medium risk of bias measured hazardous work exposures.

Two RCTs (high risk of bias) reported on outcomes related to hazardous work exposures.9,10 Both studies enrolled manufacturing workers and evaluated multicomponent integrated interventions that included organizational integration and employee participation. One RCT (N=2,386) assessed self-reported exposures to carcinogenic substances after the intervention;9 the intervention and control sites did not differ in the incidence of self-reported hazardous exposures (quantitative data were not provided). The other RCT (N=825) involved pre- and post-intervention worksite assessments conducted by an industrial hygienist;10 potential exposure to hazardous processes was assessed with a nonvalidated rating scheme. The investigators reported no differential loss of higher hazard processes between intervention and control worksites and found no statistically significant differences for any specific work conditions between intervention and control sites.

#### Safety Compliance and Safety Behaviors

One RCT (N=116) rated medium risk of bias assessed changes in safety participation and safety compliance among construction and utility workers.55 Participants were randomized to an intervention aimed at improving work–life stress (via supervisor behavior training and employee work groups) or no intervention. Safety compliance and safety participation were measured via self-report on items such as “I use the correct safety procedures” and “I voluntarily carry out tasks or activities that help to improve workplace safety”; the full range of questions was not described by the authors.55 Responses were rated on a 5-point scale and computed as a mean response (higher scores=higher levels of safety and compliance). There was no difference between groups in mean safety participation scores (0.14; SE=0.09; p=0.014) or mean safety compliance scores (-0.02; SE=0.08;p=0.83).55

#### Weight

One RCT (N=60) rated medium risk of bias randomized sedentary office workers to an ergonomic workstation optimization intervention alone or an integrated intervention that included the same ergonomic intervention plus access to a seated activity permissive workstation.54 There was no difference between groups in the weight change from baseline to followup at 16 weeks (p=0.80).54

### Utilization Outcomes and Occupational Injury and Illness Surveillance Outcomes

#### Workers' Compensation Claims and Short-Term Disability Claims

No included study rated low or medium risk of bias assessed rates of health care utilization or occupational injury and illness surveillance outcomes.

One NRCT (N= 519) rated high risk of bias enrolled workers at U.S. automotive manufacturing worksites.38 Worksites were assigned to a multicomponent intervention developed through collaboration between OSH and HP programs to promote appropriate medical treatment for allergies, or to no intervention. The study measured rates of workers' compensation claims and short-term disability claims via the employer's disability database. The percentages of participants at who had one or more workers' compensation claims and short-term disability claims at 28 weeks did not differ between intervention and control sites (p-value not significant per authors for both outcomes).

### Harms

No included study rated low or medium risk of bias reported on potential harms of interventions.

Two studies (both high risk of bias) reported potential harms; in both cases, harms were not prespecified. The Danish nurses cohort study of shift-work scheduling (N=172) surveyed participants in the intervention group about potential adverse effects of the intervention.41 The intervention group judged the new schedule as having had a worse impact on family life (compared with the preintervention schedule) at 52 weeks.41 The authors did not report quantitative results (e.g., measure of variance or p-value for the difference between groups); in addition, whether the effect of shift work on family life was measured in the comparison group was unclear. One RCT (N=860) enrolling Norwegian postal workers assessed potential harms in a four-arm study that compared an integrated intervention with aerobic exercise alone, stress management alone, and no intervention.42 The authors asked participants whether the interventions had any influence on “health, work environment, work situation, physical fitness, muscle pain, ability to deal with stress, and knowledge of how to maintain good health,” which they reported as a three-category scale (better, unchanged, worse). They reported no subjective negative effects of the intervention at either 12 or 52 weeks after the intervention (but did not present any quantitative results).42

## Key Question 3 Characteristics of Effective Integrated Interventions

KQ 3 describes characteristics of effective integrated interventions; it is intended to provide information about the interventions that show benefit for improving worker health for employers that may want to implement an evidence-based integrated intervention and for researchers who want to evaluate integrated interventions. We limited this question to those interventions effective for improving any outcome eligible for KQ 2 for which we found at least low SOE for benefit. Because of heterogeneity across included studies (in terms of populations, interventions, outcomes) and methodological limitations we were only able to make SOE conclusions for three outcomes: increased smoking cessation (measured by 7-day abstinence rates) over 22 to 26 weeks, increased fruit and vegetable consumption over 26 to 104 weeks, and decreased sedentary activity at work over 16 to 52 weeks. The applicability of these conclusions is very limited; conclusions for smoking cessation and fruit and vegetable consumption outcomes are based on four studies enrolling U.S. blue-collar manufacturing and construction workers.9,25,32,33 Our conclusions related to sedentary activity at work are based on two studies enrolling office workers, one in the United Sates54 and one in The Netherlands.51 The results for these outcomes are discussed in KQ 2, and SOE assessments are shown in Appendix D.

To address this question, we focused on describing characteristics of interventions that relate to two main domains. The first addressed the approach to integration, or the way in which the intervention simultaneously addresses health protection and HP (e.g., strategic coordination across organizational departments or worker input into the design or implementation of the intervention). The second focused on the specific content of the intervention, that is, (1) OSH components (e.g., administrative controls to improve or remove work hazards or individual education related to work hazards) and (2) components related to HP (e.g., environmental changes or individual education to promote healthy behavior).

### Key Points

- Effective interventions were heterogeneous. We were not able to separate out individual components from the overall type (or “bundles”) of interventions that showed efficacy for outcomes eligible for KQ 2.
- Most effective interventions were informed by worker participation in the development, design, planning, or implementation of the intervention (or in more than one of these steps).
- All effective interventions included comprehensive program content that highlighted the potential additive or synergistic risks of hazardous workplace exposures and health behavior.
- Most interventions tailored intervention components or materials to cultural or social aspects of the worker population (e.g., to workers with low literacy skills or workers for whom English was not their first language).
- All effective interventions are multicomponent, complex interventions that reinforce messages about health and safety through multiple levels of influence or multiple modes of delivery (or both) over time.

### Detailed Synthesis

#### Approach to Integration

In five of six studies contributing to our SOE grades, interventions were informed by worker participation in the development, design, planning, or implementation of the intervention. Two studies set in manufacturing worksites9,33 involved the creation of a joint-worker-management employee advisory board (EAB) comprising workers, production managers, and representatives from health and safety and human resources departments who planned and implemented the intervention in partnership with the study investigators. EAB members gave input on specific components; for example, policies aimed at reducing hazardous occupational exposure were cowritten by the study investigators and workplace managers. Production managers included in planning activities helped to ensure that workers could alter their work schedules to participate in intervention activities.33 In three studies, the intervention was designed based on input (or prior research) from members of the targeted occupational group (e.g., related to culture, potential occupational exposures, or work experience);25,32,51 and in two of these studies, the intervention was also implemented in collaboration with union members or support from apprenticeship program leaders.25,32

In four studies, interventions were designed to simultaneously address OSH and HP concerns by highlighting the potential additive or synergistic risks of hazardous workplace exposures and health behavior, either through interventions delivered at the worksite (manufacturing worksites)9,25,33 or via telephone-based interviewing and counseling combined with written educational materials provided to individual construction workers.32 The two studies enrolling office workers focused on increasing physical activity at work to address hazards associated with sedentary work, one focused on ergonomic hazards54 and the other focused mostly on decreasing work stress and burnout.51

All four studies set in a manufacturing worksite tailored intervention components to cultural or social aspects of the worker population (aside from the specific work-related hazards); for example, designing written materials so that they were accessible to workers with low literacy skills33 and ensuring that surveys and other written materials were available in multiple languages for workers whose first language was not English,32,33 or developing curricula that resonated with the workers' occupational culture.25

Given the limited number of studies contributing to our SOE grades (six studies) and the heterogeneity of interventions, we had insufficient evidence to determine whether certain strategies of integration directly contributed to the efficacy of an intervention or whether certain strategies are more or less effective for certain outcomes or subgroups of workers.

#### Complexity and Content of Interventions

All six interventions were multicomponent, complex interventions that delivered content through multiple levels of influence or multiple modes of delivery (or both) over time. For example, three studies conducted at a manufacturing worksite created multiple opportunities for workers to participate in worksite-based activities at the individual level (e.g., behavioral self-assessments with feedback, interaction with table-top displays and demonstrations).9,25,33 One also included intervention components aimed at modifying the work environment to improve worker health and safety (e.g., adoption of new catering policies that promoted healthy eating and inclusion of an industrial hygiene assessment and feedback to worksites aimed at improving worker safety).33 In one study focused on construction workers, one-to-one motivational interviewing counseling sessions (via telephone) were conducted over time; a mailed report with individual feedback and written educational materials was provided at baseline and was periodically reinforced by sending “tip sheets” during the intervention.32 Two studies included an individual health assessment (survey) with tailored feedback based on responses.32,33

All interventions included HP or OSH components (or both) that were new and not previously available to workers. Three studies primarily provided HP content that highlighted OSH concerns,25,32,54 and three offered comprehensive HP and OSH components at the worksite.9,33,51

We did not find any direct evidence to determine whether specific components added benefit. That is, no study rated as medium or low risk of bias directly compared the delivery of an intervention having a specific component with the same intervention but lacking that specific component. Separating out individual components from the overall type (or “bundles”) of interventions that showed efficacy for outcomes eligible for KQ 2 was not possible.

## Key Question 4 Contextual Factors

KQ 4 asks “What contextual factors have been identified as potential modifiers of effectiveness in studies of integrated interventions?” Such factors can be quite diverse: (1) the legal-regulatory environment (e.g., state laws with respect to union representation); (2) employer characteristics, policies, or benefits (e.g., availability of health insurance coverage or paid sick leave); (3) work organization (e.g., shift work); and (4) social or economic factors (e.g., income or availability of community resources to support or promote health).

To address this question, we abstracted relevant data from all 24 included studies when investigators reported them. We included factors that were noted in the articles' results (e.g., whether the intervention was more or less effective at worksites that differed by a specific contextual factor) and issues that investigators may have discussed that could have potentially modified the effectiveness of interventions.

### Key Points

- Few studies identified contextual factors that could have played a role in modifying the effectiveness of interventions.
- Work organization factors and union membership status were the two most commonly mentioned contextual factors. Other factors noted by at least one study included the following: presence of another (concurrent) intervention implemented during the study period, health insurance status (of the workers), availability of adequate resources to address employee concerns, support from higher management, and company downsizing.

### Detailed Synthesis

Of the 24 included studies, 8 addressed contextual factors. Table 12 summarizes relevant contextual factors for specific occupational groups, settings, and key health and safety outcomes. These factors varied by study population and work setting. In general, they related to the following:

- health insurance status and access to primary care services
- work organization factors
- company downsizing
- availability of resources
- support from higher management
- union membership status, including ongoing union contract negotiations
- other ongoing OSH interventions

Table 12 Characteristics of studies describing contextual factors

Author(s), Year Study Name Study Design Unit of Intervention (N Worksites; N Workers) | Source Population Country | Outcomes | Contextual Factors
Allen et al., 2003^38^ International's Allergy Project NRCT Worksite (7; 519) | Heavy manufacturer of medium- and heavy-duty trucks and diesel engines United States | Allergy symptoms, use of allergy medications, knowledge related to coping with severe allergy symptoms, productivity; absenteeism, rates of workers' compensation claims, and short-term disability claims | Health insurance status Union membership (including contract negotiations)
Barbeau et al., 2006^48^ MassBUILT Pilot SG Pre/post Worker (1; 337) | Ironworker apprentices United States | Smoking cessation; other measures of cigarette use | Union membership
Boggild and Jeppesen, 2001^41^ Cohort Worker (1; 101) | Nurses and nursing aides Denmark | Cholesterol levels, physical activity, prevalence of smoking, weekly alcohol intake, shift-work schedule changes, employee perceptions of schedules | Staffing levels, human resource policies related to overtime
Carr et al., 2015 54 RCT Worker (1; 60) | Sedentary desk job workers at a private company United States | Musculoskeletal discomfort, blood pressure, heart rate, weight, body composition, waist circumference, occupational time spent sedentary and physically active, productivity, process evaluation to assess helpfulness to employee | Availability of resources to address employee concerns related to work–life stress
Coffeng et al., 2014^51^ RCT Worksite and worker (NR; 412) | Officer workers with primarily desk jobs employed by a financial service provider The Netherlands | Need for recovery after work, multiple measures of physical activity at and outside of work (e.g., stair climbing, active commuting, leisure activities, sports, sedentary time at work), work-related stress, exhaustion | Support from higher management
Eriksen et al., 2002^42^ RCT Worker (31; 860) | Post office or postal terminal workers Norway | Subjective health complaints, sick leave, job stress, worker perception of intervention | Company downsizing
Olson et al., 2009^44^, Wipfli, 2013^45^ SHIFT Pilot Study Pre/post Worker (4; 29) | Truck drivers United States | Measures of well-being, weight, BMI, waist-to-hip ratio, multiple dietary behaviors, physical activity level, safe driving behaviors, cholesterol levels, fasting blood glucose, blood pressure, multiple measures of fitness such as 6-minute walk test, measures of self-efficacy related to diet and exercise, workplace safety climate | Work organization factors, other concurrent worksite OSH interventions
Sorensen et al., 1998^9,39,40^ WellWorks RCT Worksite (24; 2,386) | Manufacturers of industrial, chemical, and other products; textile dyeing; firefighting; and newspapers United States | Smoking cessation, multiple measures of dietary behavior, workplace hazard exposures | Union membership

BMI = body mass index; N = number; NRCT = nonrandomized controlled trial; OSH = occupational safety and health; RCT = randomized controlled trials.

Access to health care was identified as a potential modifier of an intervention aimed at improving the appropriate treatment of allergies among manufacturing workers (improving symptoms and reducing use of sedating medications).38 The authors noted that 13 percent of participants were enrolled in a health maintenance organization, but did not document the health insurance status of other participants. According to the investigators, the overall low participation rate in the intervention was perhaps related to the fact that a change from a sedating to a nonsedating allergy medication required a physician's office visit and a prescription (and potentially a copayment for both); at the time of the study, nonsedating allergy medication had not become available over the counter.38 Primary care physicians were not involved in the design or implementation of the intervention; the authors speculated that coordination with prescribing health care providers might have improved participation and modified the effectiveness of the intervention.38

Work organization factors were also noted as potential modifiers of intervention effectiveness in two studies.41,44 In the study to improve shift-work schedules in a Danish hospital, staff shortages and changes in overtime policies during the intervention period were noted as factors that may have reduced study participation.41 A new policy for handling of overtime work among nurses was put into effect during the intervention period; before the new agreement, overtime work was not paid, but the new policy paid overtime. The authors observed that this policy change reduced work hours for nurses (and meant extra work for the existing staff); it also led to more scheduling changes than expected (unrelated to the goals of the intervention).41 A study of teams of truck drivers noted that work schedules may have limited participation and effectiveness of the intervention.43 The authors noted that isolation among drivers and changes in driving routes during the intervention may have led to low levels of communication within teams, which then may have limited the effectiveness of the intervention.43

Company downsizing during the intervention was identified as a potential moderating factor in a multisite study of Norwegian postal workers.42 The workers were told during the intervention that the number of post offices would be reduced considerably (from 2,300 to 1,400). One focus of the integrated intervention was on stress management and improving subjective health complaints; the authors speculated that company downsizing may have introduced turmoil and instability in the workplace.42 In one study, the post-interview surveys were conducted among supervisors who completed training on work–life balance; supervisors found it difficult to provide resources to manage conflicts because of budget and staffing constraints.55 The authors did not comment on whether this was felt to diminish the effectiveness of the intervention.

Support and commitment from higher management were noted as potential factors important to intervention success by authors of a study enrolling office workers employed by a Norwegian financial service provider.51 The intervention focused on modifications to the work environment to reduce the need for work recovery and promote physical activity and relaxation. Post-intervention surveys found that employees and supervisors rated support by the financial service provider and their managers as relatively low. The authors commented that support and commitment from higher management are necessary for successful interventions.51

Union membership was considered to be a moderating factor in three studies enrolling U.S. manufacturing workers.9,38,48 In one study, union concentration varied significantly by worksite; the authors noted that contract renewal negotiations were ongoing (at the time of the study) and may have reduced responses to surveys among people with chronic health conditions.38 In another study, 5 of 12 worksites were unionized; union representatives served on EABs responsible for the intervention planning and implementation at worksites randomized to the integrated intervention.9 This practice may have led to differences in participation and intervention effectiveness across worksites. Finally, support of the intervention by apprenticeship program leaders may have played a role in successful intervention implementation.48 However, the authors noted that apprentice program leaders granted the study team 1 hour for the “toxics and tobacco” curriculum module instead of the requested 5 hours because of a concern that replacing instructions on other important health and safety issues with the tobacco-related curriculum would endanger the apprentices on the job. The authors did not comment on whether the shortened curriculum might have affected rates of smoking cessation at intervention sites.48

One study enrolling truck drivers identified another concurrent OSH policy change as a potential modifier of effectiveness.57 One company implemented a mechanical speed-governing intervention for some trucks near the onset of the intervention; reduction in over-speed (driving over a preset speed criterion) may have been partially attributable to the effects of speed governing (and not the integrated intervention).57

## Key Question 5 Evidence Gaps

In this KQ, we describe important research gaps identified in the conduct of this review. We consider “research gap” to mean a topic area for which missing or inadequate information limited our ability to reach a conclusion on the effectiveness of TWH interventions. We outline research gaps below by work settings and populations, interventions, comparators, and deficiencies in methods (including issues that related to the design and reporting of studies). We consider work settings and populations together since most studies recruit workers from specific worksites and who are at risk of similar work-related illnesses and injuries (and potentially similar in terms of demographics or risk factors for chronic diseases). The evidence gaps outlined here are those we considered most relevant to work settings and populations in the United States.

### Work Settings and Populations Studied

#### Geographic Setting

Included studies focused on worksites in select geographic areas. Our SOE grades primarily apply to blue-collar workers in the Northeast region of the United States (Massachusetts). No studies enrolled workers from states in the Southwest and only one study each was conducted in a Southeastern or Western state (Arkansas and Oregon, respectively). Only one study enrolled a population across different states (construction workers affiliated with the Laborers' International Union of North America (LIUNA).32

#### Industries and Occupational Groups

Our SOE grades primarily apply to U.S. blue-collar workers employed in the manufacturing and construction industries and sedentary office workers. In many cases, studies only reported on the characteristics of the industry or worksite from which populations were recruited, and did not always describe the range of occupations of enrolled workers. We noted the following gaps that relate to the industry or occupational groups included in studies of TWH interventions:

- No studies enrolled workers from these industry sectors: wholesale and retail trade; utilities (electricity, water, gas); information (publishing, broadcasting, telecommunications, etc.); real estate; professional, scientific, and technical services; educational services; arts, entertainment, and recreation; or accommodation and food services.
- The service sector as a whole (e.g., retail, transportation, communications industries, health care) is underrepresented in included studies when considering the prevalence of work-related injuries among workers in this sector. According to the U.S. Bureau of Labor Statistics (BLS), the service sector accounted for 65.5 percent of all private industry occupational illness cases in 2012 (the most recent data available).68 However, a majority of included studies enrolled workers from goods-producing industries, which accounted for 34.3 percent of all private industry occupational illness cases in 2012.^68^
- Only two included studies enrolled workers from the transportation and warehousing industry.42,44 No included study enrolled air, rail, water, or ground transit transportation workers. Health care was represented but studies primarily focused on select occupational groups (e.g., registered nurses).
- Few studies enrolled workers from the natural resources and mining sector (one studied workers in agriculture30 and one in offshore oil drilling47). No studies enrolled workers in forestry and logging, fishing and hunting, or the onshore mining industries (coal, metal and nonmetal).
- In terms of specific occupational groups, only four studies enrolled office and administrative support workers (the occupational group with the largest employment in the United States). The following occupations were not represented in included studies: sales and related occupations (the second largest major occupation group in the United States);69 food preparation and serving workers (the third largest major occupation group in the United States);69 and workers in education and training, a large U.S. occupational sector.

#### Populations and Subgroups Studied

The demographics of workers enrolled in included studies were often not well described (aside from factors specific to the work setting or potential work hazards). We noted the following gaps that relate to major demographic features and baseline health of workers enrolled included trials:

- No study enrolled populations of workers who were very young or very old (the mean age of workers enrolled across included studies ranged from 30 to 50 years of age). According to the BLS, workers 45 to 54 years of age had the highest number of days-away-from-work cases in 2013 and workers 65 years of age or older had a greater number of median days away from work than younger workers.70
- Women were underrepresented in industries other than those typically conducted in a health care setting. According to the BLS, injuries and illnesses among men accounted for only 61 percent of all nonfatal injury and illness cases in 2013.^70^
- No study addressed differences in outcomes among subgroups of workers defined by age, sex, race, ethnicity, comorbidity, or income.
- People who work part time (regardless of their occupation) were often excluded from studies.

### Interventions

Studies evaluated quite diverse interventions; the type and level of integration involved in interventions varied substantially. TWH is currently defined as “policies, programs, and practices that integrate protection from work-related safety and health hazards with promotion of injury and illness prevention efforts to advance worker well-being.”71 Previous definitions have highlighted the integration of OSH and HP specifically.11 Included studies did not use standard language regarding the nature or extent of integration; we found no direct evidence about whether certain policies or practices of integration are more or less effective than others. Sorensen and colleagues identified a core set of indicators of the implementation of integrated approaches to OSH and HP to help facilitate what is meant by “integrated strategies.”11,33 Often, these indicators were not well described across included studies. We identified the following gaps that relate to TWH interventions:

- Few studies assessed single-component interventions aimed at improving the work environment or work structure with the associated goals of improving OSH and promoting overall well-being.
- A minority of included studies (eight studies) evaluated an intervention that clearly involved organizational integration; that is, multiple departments within the work setting were involved with planning, implementing, and managing the intervention (e.g., OSH department, HP programs, and sometimes others).
- We found no studies that directly assessed whether specific combinations (or specific types) of program content were more or less effective than other combinations. Studies differed in terms of the degree to which program content focused on OSH concerns versus promotion of overall health and well-being.
- We could not assess whether strategies were more or less effective based on their complexity (single versus multicomponent) or level of influence (e.g., environmental or administrative controls, individual worker education, or both). Most studies assessed complex heterogeneous interventions that targeted both the worker and worksite.

### Comparators

In general, studies were not designed to directly assess the effectiveness of integration alone (compared with no integration). Most studies compared an integrated intervention that included new OSH or HP components (or both) with no intervention. The effects of the added HP or OSH component (or both) offered to the intervention group could not be separated from the effects of integration.

Among studies that compared an intervention to no intervention (or usual workplace programs), studies often failed to describe the OSH or other health-related programs, policies, and benefits already in place and available to workers.

### Outcomes

Although we considered a wide range of outcomes for this review, we were only able to rate the strength of evidence for three: smoking cessation, fruit and vegetable consumption and sedentary work behavior. We identified the following gaps in terms of the outcomes measured in included studies:

- We were not able to assess the strength of evidence related to any OSH outcome (e.g., rates of occupational injuries or illnesses). Few studies with a concurrent control group measured outcomes important to OSH. Whether integrated interventions improve workplace safety (compared evidence-based OSH programs or policies that are not considered integrated) is unclear.
- We did not find many of the outcomes listed in our inclusion criteria for KQ 2 (effectiveness and harms of interventions) reported in included studies, including the following: incidence of injuries or chronic diseases (e.g., diabetes, CVD); morbidity related to injuries, illnesses, or chronic disease (including work-related injuries and illnesses); depression or anxiety; changes in BMI; and measures of health care utilization (hospitalizations, emergency department visits, or outpatient clinic visits).
- Very few studies reported on the following outcomes: validated measures of quality of life or functional status; stress (job or general stress); rates of workers' compensation claims, short-term disability claims, and alcohol use.
- No included studies prespecified harms as an outcome of interest. We looked for evidence on the following potential harms of interventions but did not find any: increased barriers to reporting work-related injuries or illnesses, increased work stress, employee concerns about the privacy of health information, discrimination, and victim-blaming.

### Deficiencies in Methods

Of the 24 included studies, 12 had a pre-post design; because of the inherent risk of bias in pre-post studies, we did not include them in our assessment of the benefits and harms of TWH interventions. Among the 15 included studies eligible for KQ 2 (i.e., those with a concurrent control group), many had methodological limitations including the following:

- Among RCTs, we found inadequate reporting of randomization and allocation concealment. Most RCTs randomized at the worksite (or group) level; the number of worksites randomized was often small. In one case, two worksites were reported to be “randomized” and we called this a nonrandomized controlled trial.28
- Often, studies did not adequately describe the flow of participants, particularly those that randomized or assigned interventions at the worksite level. Most studies measured outcomes based on survey responses before and after an intervention; response rates to the baseline surveys among eligible workers were sometimes low or not reported, and this practice contributed to selection bias.
- Overall attrition was high in several studies (14 percent to 54 percent in studies rated high risk of bias). Some studies did not provide sufficient data to calculate differential attrition between study arms. For the 10 studies that had very high overall attrition (>20 percent), high differential attrition (>15 percent), or both, only two employed methods to address missing data; one used last observation carried forward42 and the other used software to impute missing data.55 Most trials did nothing to address missing data (i.e., analyzed only completers).
- Statistical analyses did not often address important baseline differences between intervention and control groups; in some cases, important demographic information was not provided in order to assess whether there were baseline differences between groups.
- Several studies had small sample sizes, thus lacked power for determining intended effects.
- Investigators sometimes did not provide information on their statistical methods; also, authors did not always provide measures of variance (e.g., confidence intervals) for outcomes. This limited our ability to assess the precision of outcomes across studies.
- In several studies, contamination of the control arms compromised internal validity, for example, due to another worksite policy or program initiated during the intervention period that could have influenced outcomes measured in the study.
- In some cases, the length of followup may not have been adequate to assess the stability of findings over time. Only seven studies measured outcomes at or beyond 1 year. Our SOE grades (based on four studies) relate to outcome timings over 22 to 104 weeks.

## Key Question 6 Future Research Needs

In this chapter, we make specific recommendations for future research focused on TWH interventions. These suggestions are based only on our evidence synthesis and are the research gaps outlined in KQ 5. These suggestions are intended to inform the Pathways to Prevention Workshop19 on TWH; the workshop panel will consider these research needs in order to develop a summary of the current state of the science and future research needs related to TWH interventions.

Below, we make specific recommendations following the PICOTS framework laid out in KQ 5. We recommended specific research designs for the most important evidence gaps that relate to works setting and populations, interventions, comparators, outcomes, and study designs and deficiencies in methods.

### Work Settings and Populations Studied

#### Geographic Setting

- Targeted regions of the country with a high burden of both occupational injuries and illnesses and chronic diseases should be a priority.
- Future research could target specific worksites in diverse regions of the United States that differ in terms of State government policy on economic development and labor, which can influence where employers locate and the attention they give to worker safety. There is geographic variation across the United States in terms of fatal occupational injury rates (higher in the Western and Southern regions, in rural areas, and in less wealthy states).72 States in the South and Midwest also have higher rates of risk factors for chronic disease, such as smoking, compared with other regions.73

#### Industries and Occupational Groups

- The applicability of interventions that were effective for reducing smoking and improving fruit and vegetable consumption is limited. Most included studies were published more than 10 years ago; current practice in terms of the availability of smoking cessation programs (at the worksite and via the health care setting) is likely to have improved over time. Future studies should consider similar interventions in other groups of workers (e.g., other blue-collar workers) or different settings to help clarify (1) the SOE for these interventions and (2) the applicability across various work settings and populations.
- Future studies should consider focusing on populations of workers in the service sector, such as retail, transportation, communications industries, and health care, given the high burden of occupational injuries in these populations.
- Occupational groups representing a large proportion of the U.S. workforce should also be a focus of future research (office and administrative support workers, sales and related occupations, and food preparation and serving workers). TWH interventions could have different outcomes depending on the industry setting and occupational groups enrolled.
- Future studies could enroll workers from a range of work settings (who receive a similar intervention, for example) in order to understand what factors related to the work setting modify the benefits (and potential harms) of TWH interventions. This approach might include recruiting worksites that differ by size, ownership of the enterprise (e.g., whether private or public sector), work organization (e.g., full- versus part-time job patterns), and unionization.

### Populations and Subgroups Studied

- The National Institute for Occupational Safety and Health (NIOSH) lists changing workforce demographics (e.g., older workers, workers with disabilities, and others) as one of the issues relevant to advancing worker well-being through TWH;7 future studies should consider targeting these populations to assess whether TWH interventions are effective in improving health outcomes that are unique to these groups of workers.
- Future studies could assess whether there are differences in outcomes among subgroups of workers defined by occupation, age, sex, race, ethnicity, comorbidity, or income (when appropriate). It is not clear whether certain categories of workers would benefit more than others from TWH. Workers with more resources (e.g., comprehensive health care insurance, access to wellness programs, sufficient income to afford gym memberships) may have less interest in TWH interventions. Identifying categories of workers for whom TWH is most effective, and under what conditions, should be a priority for future research.
- Future studies could enroll populations that are likely to have specific concerns related to work–life balance (e.g., single parents, caregivers of young children or elderly parents). Benefits, programs, and policies important to work–life balance (e.g., family and medical leave, paid time off, work–life programs) are noted by NIOSH as issues relevant to advancing worker well-being through TWH but were not addressed in the included studies.7

### Interventions

- Traditionally, OSH interventions focus on activities defined by a “hierarchy of control,” in which identified hazards are controlled through elimination (physically removing the hazard), substitution (replacing the hazard), engineering controls (isolating people from the hazard), administrative controls (changing the way people work), or personal protection equipment.74 Studies of TWH interventions should describe how the promotion of overall health and well-being fits into this framework and describe clearly where the synergy lies in terms of improvements in worker health.
- Future studies should clearly describe the specific approach used to integrate OSH and HP programs or policies. Investigators should lay out a framework for how the integrated intervention addressed both OSH and overall health.
- Authors of future studies might refer to research that has outlined indicators and metrics for “integration” and describe which of these integrated metrics were accomplished by the intervention under study.11,12 Future research could build on this work and develop a taxonomy for TWH interventions that investigators could use to categorize and compare intervention types.
- The interventions we identified as effective suggest that employee participation is an important element in TWH interventions. Future studies should determine the most effective form of worker participation. It is unclear, for example, how the involvement of union representatives compares with “rank-and-file” worker participation in planning committees.
- Studies should evaluate interventions targeted at improvements in work organization. Work schedules and staffing (e.g., shift work, work hours), for example, have been highlighted as an issue relevant to TWH.7 Few studies have assessed whether specific integrated strategies that modify the work organization improve worker health more than those focusing primarily on providing education, training, or behavioral counseling to individual workers.

### Comparators

- An established body of literature supports the efficacy of worksite wellness interventions on smoking and other important outcomes;75 similarly, evidence-based policies, programs, and practices focused on the prevention of occupational illness and injuries are available for specific industries and occupations.76 Future studies should aim to directly assess the effectiveness of integration itself; in other words, this aspect of TWH interventions should be isolated from the effects of a new or improved OSH or HP program or policy. Studies should directly compare an integrated approach with a program that has similar OSH and HP elements available but does not deliberately coordinate them.
- In addition, investigators should clearly describe what OSH programs, HP programs, and health benefits (e.g., insurance, sick leave) are already in place and available to workers outside of the intervention being evaluated.

### Outcomes

- Future studies should consider the feasibility of measuring a broader range of OSH outcomes. To understand whether a TWH approach prevents occupational illness and injury and promotes overall health, researchers need to examine indicators of improved safety.
- Future studies should also consider direct measures of worker health if possible; for example, they could use validated measures of health status, functional status, and wellness. Researchers should measure the incidence or morbidity associated with chronic diseases when feasible, particularly in populations of workers at higher risk of chronic conditions (e.g., older workers).
- Research teams should also choose intermediate outcomes carefully. These outcomes should be based on strong evidence for linkages to final health outcomes and for relevance to a particular population of workers. For example, rates of smoking might be prioritized in some populations because of (1) a high prevalence of smoking among a particular group of workers, (2) potential synergistic adverse effects related to a specific job hazard, and (3) a strong connection to CVD risk (regardless of factors related to OSH). Intermediate outcomes that have an unclear relationship to final health outcomes or OSH outcomes should receive less focus; these might include, for example, measures of cholesterol in otherwise healthy populations of workers who are young and have a low prevalence of other CVD risk factors.
- Future studies should consider assessing harms or potential unintended consequences of interventions at the individual worker and organizational levels. For example, studies could assess whether there was a concern about not giving adequate time or resources to OSH programs in studies of integrated interventions (among managers or OSH personnel). At the individual worker level, potential harms might vary by work setting or occupation; these might include increased barriers to reporting work-related injuries or illnesses, increased work stress, or concerns about the confidentiality of health information in the workplace.

### Deficiencies in Methods

Future studies could address methodological limitations related to TWH interventions by considering the following:

- Worksite randomized trials should follow the recommendations for reporting outlined in the CONSORT statement extension to cluster randomized trials77 or the Ottawa Statement on the ethical design and conduct of cluster randomized trials.78 In particular, authors should provide a clear flow diagram to show the flow of participants from group assignments through the final analysis.
- Authors should consider whether the sample size (of worksites and workers) is likely to be sufficient to show a difference for the outcome being studied.
- RCTs are not always feasible due to barriers associated with studying populations of workers. Well-designed prospective cohort studies (or nonrandomized trials) with a concurrent control group would inform the strength of evidence related to TWH interventions. Studies without a control group are unlikely to contribute significantly to an understanding of the strength of evidence supporting TWH interventions (because of the inherent bias in the design); these designs should be avoided.
- For outcome measures by surveys, authors should describe the demographics (including occupational groups) of workers who respond and do not respond to surveys when feasible, so that this can be taken into consideration when assessing the potential risk of selection bias in studies.
- Authors should plan for high attrition (and differential attrition) and use methods to address missing data when necessary; approaches such as imputation of missing data should be considered, based on the potential reasons for missing data and the outcomes under study.
- Studies should address baseline differences between groups (when they are present) using appropriate statistical methods.
- Studies should report confidence intervals (or other measures of variance) for all outcomes they evaluate so that the precision around outcome measures is clear.
- Finally, in reporting their studies, authors should highlight whether other (concurrent) OSH programs, HP programs, or health benefits were in place or were implemented during the intervention in question; this will enable them to assess bias associated with contamination.