# References

1 Leigh JP, Markowitz SB, Fahs M, et al. Occupational injury and illness in the United States. Estimates of costs, morbidity, and mortality. Arch Intern Med. Jul. 28. 1997;157(14):1557-68. [pmid: 9236557].
2 Dembe AE. The social consequences of occupational injuries and illnesses. Am J Ind Med. Oct. 2001;40(4):403-17. [pmid: 11598991].
3 Bureau of Labor Statistics. Employer-Reported Workplace Injury and Illness Summary. Washington, DC. Bureau of Labor Statistics, U.S. Department of Labor. 2013. 4. December. 2014. www.bls.gov/. 16 December, 2014.
4 Mokdad AH, Marks JS, Stroup DF, et al. Actual causes of death in the United States, 2000. JAMA. Mar. 10. 2004;291(10):1238-45. [pmid: 15010446].
5 Hymel PA, Loeppke RR, Baase CM, et al. Workplace health protection and promotion: a new pathway for a healthier--and safer--workforce. J Occup Environ Med. Jun. 2011;53(6):695-702. [pmid: 21654443].
6 World Health Organization. Jakarta Statement on Healthy Workplaces. Geneva, Switzerland. World Health Organization. 1997. www.who.int/healthpromotion/conferences/previous/jakarta/statements/workplaces/en/. May 6, 2015.
7 Centers for Disease Control and Prevention. Total Worker Health. Atlanta, GA. Centers for Disease Control and Prevention. 2015. November. 6. http://www.cdc.gov/niosh/twh/. November 16, 2015.
8 National Institute for Occupational Safety and Health (NIOSH). Research Compendium: The NIOSH Total Worker Health™ Program: Seminal Research Papers. Publication No. 2012-146. Washington, DC. U.S. Department of Health and Human Services PHS, Centers for Disease Control and Prevention, National Institute for Occupational Safety and Health, DHHS (NIOSH). May. 2012.
9 Sorensen G, Stoddard A, Hunt MK, et al. The effects of a health promotion-health protection intervention on behavior change: the WellWorks Study. Am J Public Health. Nov. 1998;88(11):1685-90. [pmid: 9807537].
10 Sorensen G, Stoddard AM, LaMontagne AD, et al. A comprehensive worksite cancer prevention intervention: behavior change results from a randomized controlled trial (United States). J Public Health Policy. 2003;24(1):5-25. [pmid: 12760241].
11 Sorensen G, McLellan D, Dennerlein JT, et al. Integration of health protection and health promotion: rationale, indicators, and metrics. J Occup Environ Med. Dec. 2013;55(12 Suppl):S12-8. [pmid: 24284762].
12 Williams JA, Nelson CC, Caban-Martinez AJ, et al. Validation of a new metric for assessing the integration of health protection and health promotion in a sample of small-and medium-sized employer groups. J Occup Environ Med. Sep. 2015;57(9):1017-21. [pmid: 26340291].
13 McLellan D, Harden E, Markkanen P, et al. SafeWell Practice Guidelines: An Integrated Approach to Worker Health Version 2.0. Dana-Farber Cancer Institute, Inc Boston, MA. Harvard School of Public Health Center for Work, Health and Well-being. September. 2012. http://centerforworkhealth.sph.harvard.edu/resources/safewell-resources.
14 Center for the Promotion of Health in the New England Workplace, Healthy Workplace Participatory Program. CPH-NEW Healthy Workplace Participatory Program. Lowell, MA. UMASS Lowell. 2015. www.uml.edu/Research/Centers/CPH-NEW/Healthy-Work-Participatory-Program/default.aspx. 27 July 2015.
15 Commission on Health and Safety and Workers Compensation. The Whole Worker. Guidelines for Integrating Occupational Health and Safety with Workplace Wellness Programs. Commission on Health and Safety and Workers' Compensation. Oakland, CA. 2010. www.dir.ca.gov/chswc/WOSHTEP/Publications/WOSHTEP_TheWholeWorker.pdf.
16 Institute of Medicine. Integrating Employee Health: A Model Program for NASA. Washington, DC. National Academy of Sciences. 2005. September. 4. 2013. http://iom.nationalacademies.org/Reports/2005/Integrating-Employee-Health-A-Model-Program-for-NASA.aspx. 27 July 2015.
17 Pronk NP. Integrated worker health protection and promotion programs: overview and perspectives on health and economic outcomes. J Occup Environ Med. Dec. 2013;55(12 Suppl):S30-7. [pmid: 24284747].
18 Anger WK, Elliot DL, Bodner T, et al. Effectiveness of total worker health interventions. J Occup Health Psychol. Apr. 2015;20(2):226-47. [pmid: 25528687].
19 National Institutes of Health. Pathways to Prevention Program. Bethesda, MD. Division of Program Coordination, Planning, and Strategic Initiatives, National Institutes of Health. 2015. February. 26. 2015. https://prevention.nih.gov/programs-events/pathways-to-prevention. March 8, 2015.
20 United Nations Development Programme (UNDP). Human Development Report 2014 - Sustaining Human Progress: Reducing Vulnerabilities and Building Resilience. UNDP. 2014. http://hdr.undp.org/en/2014-report.
21 Systematic Review Data Repository. Accessed at http://srdr.ahrq.gov/. June 30, 2015.
22 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Agency for Healthcare Research and Quality. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD. January. 2014. Chapters available at: www.effectivehealthcare.ahrq.gov.
23 Berkman ND, Lohr KN, Ansari MT, et al. Grading the strength of a body of evidence when assessing health care interventions: an EPC update. J Clin Epidemiol. 2014. Dec. 20. [pmid: 25721570].
24 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-207. [pmid: 21463926].
25 Okechukwu CA, Krieger N, Sorensen G, et al. MassBuilt: effectiveness of an apprenticeship site-based smoking cessation intervention for unionized building trades workers. Cancer Causes Control. Aug. 2009;20(6):887-94. [pmid: 19301135].
26 Lamontagne AD, Stoddard AM, Youngstrom RA, et al. Improving the prevention and control of hazardous substance exposures: a randomized controlled trial in manufacturing worksites. Am J Ind Med. Oct. 2005;48(4):282-92. [pmid: 16142731].
27 Hunt MK, Lederman R, Stoddard AM, et al. Process evaluation of an integrated health promotion/occupational health model in WellWorks-2. Health Educ Behav. Feb. 2005;32(1):10-26. [pmid: 15642751].
28 Maes S, Verhoeven C, Kittel F, et al. Effects of a Dutch work-site wellness-health program: the Brabantia Project. Am J Public Health. Jul. 1998;88(7):1037-41. [pmid: 9663150].
29 Palumbo MV, Wu G, Shaner-McRae H, et al. Tai Chi for older nurses: a workplace wellness pilot study. Appl Nurs Res. Feb. 2012;25(1):54-9. [pmid: 20974089].
30 Blackburn J, Brumby S, Willder S, et al. Intervening to improve health indicators among Australian farm families. J Agromedicine. 2009;14(3):345-56. [pmid: 19657884].
31 Tveito TH, Eriksen HR. Integrated health programme: a workplace randomized controlled trial. J Adv Nurs. Jan. 2009;65(1):110-9. [pmid: 19032505].
32 Sorensen G, Barbeau EM, Stoddard AM, et al. Tools for health: the efficacy of a tailored intervention targeted for construction laborers. Cancer Causes Control. Feb. 2007;18(1):51-9. [pmid: 17186421].
33 Sorensen G, Barbeau E, Stoddard AM, et al. Promoting behavior change among working-class, multiethnic workers: results of the healthy directions--small business study. Am J Public Health. Aug. 2005;95(8):1389-95. [pmid: 16006422].
34 Hunt MK, Barbeau EM, Lederman R, et al. Process evaluation results from the Healthy Directions-Small Business study. Health Educ Behav. Feb. 2007;34(1):90-107. [pmid: 16740502].
35 Barbeau E, Roelofs C, Youngstrom R, et al. Assessment of occupational safety and health programs in small businesses. Am J Ind Med. Apr. 2004;45(4):371-9. [pmid: 15029570].
36 Nieuwenhuijsen ER. Health behavior change among office workers: an exploratory study to prevent repetitive strain injuries. Work. 2004;23(3):215-24. [pmid: 15579930].
37 Hodges LC, Harper TS, Hall-Barrow J, et al. Reducing overall health care costs for a city municipality: a real life community based learning model. AAOHN J. Jun. 2004;52(6):247-53. [pmid: 15219111].
38 Allen HM Jr., Borden St, Pikelny DB, et al. An intervention to promote appropriate management of allergies in a heavy manufacturing workforce: evaluating health and productivity outcomes. J Occup Environ Med. Sep. 2003;45(9):956-72. [pmid: 14506339].
39 Sorensen G, Stoddard A, Ockene JK, et al. Worker participation in an integrated health promotion/health protection program: results from the WellWorks project. Health Educ Q. May. 1996;23(2):191-203. [pmid: 8744872].
40 Sorensen G, Himmelstein JS, Hunt MK, et al. A model for worksite cancer prevention: integration of health protection and health promotion in the WellWorks Project. Am J Health Promot. Sep-Oct. 1995;10(1):55-62. [pmid: 10155659].
41 Boggild H, Jeppesen HJ. Intervention in shift scheduling and changes in biomarkers of heart disease in hospital wards. Scand J Work Environ Health. Apr. 2001;27(2):87-96. [pmid: 11409601].
42 Eriksen HR, Ihlebaek C, Mikkelsen A, et al. Improving subjective health at the worksite: a randomized controlled trial of stress management training, physical exercise and an integrated health programme. Occup Med (Lond). Oct. 2002;52(7):383-91. [pmid: 12422025].
43 Olson R, Wright RR, Elliot DL, et al. The COMPASS pilot study: a total worker Health intervention for home care workers. J Occup Environ Med. Apr. 2015;57(4):406-16. [pmid: 25654631].
44 Olson R, Anger WK, Elliot DL, et al. A new health promotion model for lone workers: results of the Safety & Health Involvement For Truckers (SHIFT) pilot study. J Occup Environ Med. Nov. 2009;51(11):1233-46. [pmid: 19858740].
45 Wipfli B, Olson R, Koren M. Weight-loss maintenance among SHIFT pilot study participants 30-months after intervention. J Occup Environ Med. Jan. 2013;55(1):1-3. [pmid: 23291953].
46 Caspi CE, Dennerlein JT, Kenwood C, et al. Results of a pilot intervention to improve health and safety for health care workers. J Occup Environ Med. Dec. 2013;55(12):1449-55. [pmid: 24270297].
47 Maniscalco P, Lane R, Welke M, et al. Decreased rate of back injuries through a wellness program for offshore petroleum employees. J Occup Environ Med. Sep. 1999;41(9):813-20. [pmid: 10491798].
48 Barbeau EM, Li Y, Calderon P, et al. Results of a union-based smoking cessation intervention for apprentice iron workers (United States). Cancer Causes Control. Feb. 2006;17(1):53-61. [pmid: 16411053].
49 Porru S, Donato F, Apostoli P, et al. The utility of health education among lead workers: the experience of one program. Am J Ind Med. Mar. 1993;23(3):473-81. [pmid: 8503465].
50 von Thiele Schwarz U, Augustsson H, Hasson H, et al. Promoting employee health by integrating health protection, health promotion, and continuous improvement: a longitudinal quasi-experimental intervention study. J Occup Environ Med. Feb. 2015;57(2):217-25. [pmid: 25654524].
51 Coffeng JK, Boot CR, Duijts SF, et al. Effectiveness of a worksite social &amp; physical environment intervention on need for recovery, physical activity and relaxation; results of a randomized controlled trial. PLoS One. 2014;9(12):e114860. [pmid: 25542039].
52 Coffeng JK, Hendriksen IJ, Duijts SF, et al. The development of the Be Active &amp; Relax “Vitality in Practice” (VIP) project and design of an RCT to reduce the need for recovery in office employees. BMC Public Health. 2012;12:592. [pmid: 22852835].
53 Coffeng JK, Hendriksen IJ, van Mechelen W, et al. Process evaluation of a worksite social and physical environmental intervention. J Occup Environ Med. Dec. 2013;55(12):1409-20. [pmid: 24270291].
54 Carr LJ, Leonhard C, Tucker S, et al. Total Worker Health Intervention increases activity of sedentary workers. Am J Prev Med. 2015. Jul. 31. [pmid: 26260492].
55 Hammer LB, Truxillo DM, Bodner T, et al. Effects of a workplace intervention targeting psychosocial risk factors on safety and health outcomes. BioMed Research International. 2015;2015:12.
56 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA Statement. Open Med. 2009;3(3):21.
57 Olson R, Elliot D, Hess J, et al. The COMmunity of Practice And Safety Support (COMPASS) Total Worker Health study among home care workers: study protocol for a randomized controlled trial. Trials. 2014;15:411. [pmid: 25348013].
58 Strzelczyk JJ, Damilakis J, Marx MV, et al. Facts and controversies about radiation exposure, part 2: low-level exposures and cancer risk. J Am Coll Radiol. Jan. 2007;4(1):32-9. [pmid: 17412222].
59 Hunt MK, Harley AE, Stoddard AM, et al. Elements of external validity of tools for health: an intervention for construction laborers. Am J Health Promot. May-Jun. 2010;24(5):e11-20. [pmid: 20569107].
60 Vyth EL, Steenhuis IH, Heymans MW, et al. Influence of placement of a nutrition logo on cafeteria menu items on lunchtime food Choices at Dutch work sites. J Am Diet Assoc. Jan. 2011;111(1):131-6. [pmid: 21185975].
61 Barbeau EM, Wallace L, Lederman R, et al. Recruiting small manufacturing worksites that employ multiethnic, low-wage workforces into a cancer prevention research trial. Prev Chronic Dis. Jul. 2004;1(3):A04. [pmid: 15670425].
62 Lerner D, Amick BC 3rd, Rogers WH, et al. The Work Limitations Questionnaire. Med Care. Jan. 2001;39(1):72-85. [pmid: 11176545].
63 Demerouti E, Bakker AB. The Oldenburg Burnout Inventory: a good alternative to measure burnout and engagement. Handbook of stress and burnout in health care. Hauppauge, NY. Nova Science. 2008.
64 Cohen S, Kamarck T, Mermelstein R. A global measure of perceived stress. J Health Soc Behav. Dec. 1983;24(4):385-96. [pmid: 6668417].
65 Gray-Toft P, Anderson J. The Nursing Stress Scale: development of an instrument. J Behav Assess. 1981. 03. 01. 1981;3(1):11-23.
66 Kuorinka I, Jonsson B, Kilbom A, et al. Standardised Nordic questionnaires for the analysis of musculoskeletal symptoms. Appl Ergon. Sep. 1987;18(3):233-7. [pmid: 15676628].
67 Eriksen HR, Ihlebaek C, Ursin H. A scoring system for subjective health complaints (SHC). Scand J Public Health. Mar. 1999;27(1):63-72. [pmid: 10847674].
68 Bureau of Labor Statistics. Occupational Injuries and Illnesses (Annual) News Release. 11/07/2013 News Release: Workplace Injuries and Illnesses-2012. Washington, DC. U.S. Department of Labor, Bureau of Labor Statistics. 2013. November. 7. www.bls.gov/. 10 August 2015.
69 Bureau of Labor Statistics. Employment by Major Occupational Group. Washington, DC. Bureau of Labor Statistics, U.S. Department of Labor. 2012. 19. December. 2013. http://www.bls.gov/. 10 August, 2015.
70 Bureau of Labor Statistics. Nonfatal Occupational Injuries and Illnesses Requiring Days Away From Work, 2013. For release December 16, 2014. USDL-14-2246. Washington, DC. U.S. Department of Labor, Bureau of Labor Statistics. 2014. December. 16. www.bls.gov/. 10 August 2015.
71 Centers for Disease Control and Prevention. Total Worker Health™. Atlanta, GA. CDC. 2013. August. 20. www.cdc.gov/niosh/twh/. December 16, 2014.
72 Loomis D, Schulman MD, Bailer AJ, et al. Political economy of US states and rates of fatal occupational injury. Am J Public Health. Aug. 2009;99(8):1400-8. [pmid: 19542025].
73 Jamal A, Agaku IT, O'Connor E, et al. Current cigarette smoking among adults--United States, 2005-2013. MMWR Morb Mortal Wkly Rep. Nov. 28. 2014;63(47):1108-12. [pmid: 25426653].
74 National Institute for Occupational Safety and Health (NIOSH) NIOSH, Hierarchy of Controls. Washington, DC. Centers for Disease Control and Prevention. 2015. January. 13. www.cdc.gov/niosh/topics/hierarchy/. 10 August 2015.
75 Community Preventive Services Task Force. Recommendations for worksite-based interventions to improve workers' health. Am J Prev Med. Feb. 2010;38(2S):S232-6. [pmid: 20117609].
76 Centers for Disease Control and Prevention. Subjects of Interest to Total Worker Health™. Atlanta, GA. Centers for Disease Control and Prevention. 10 August 2015.
77 Schulz KF, Altman DG, Moher D, et al. CONSORT 2010 statement: updated guidelines for reporting parallel group randomised trials. BMJ. 2010;340:c332. [pmid: 20332509].
78 Taljaard M, Weijer C, Grimshaw JM, et al. The Ottawa Statement on the ethical design and conduct of cluster randomised trials: precis for researchers and research ethics committees. BMJ. 2013;346:f2838. [pmid: 23661113].
79 Elliot DL, Goldberg L, Kuehl KS, et al. The PHLAME (Promoting Healthy Lifestyles: Alternative Models' Effects) firefighter study: outcomes of two models of behavior change. J Occup Environ Med. Feb. 2007;49(2):204-13. [pmid: 17293760].
80 Pronk NP, Katz AS, Lowry M, et al. Reducing occupational sitting time and improving worker health: the Take-a-Stand Project, 2011. Prev Chronic Dis. 2012;9:E154. [pmid: 23057991].
81 Sommers BD, Gunja MZ, Finegold K, et al. Changes in self-reported insurance coverage, access to care, and health under the Affordable Care Act. JAMA. Jul. 28. 2015;314(4):366-74. [pmid: 26219054].
82 Ott MG, Yong M, Zober A, et al. Impact of an occupational health promotion program on subsequent illness and mortality experience. Int Arch Occup Environ Health. Dec. 2010;83(8):887-94. [pmid: 20186547].
83 Hall J, Mansfield L, Kay T, et al. The effect of a sit-stand workstation intervention on daily sitting, standing and physical activity: protocol for a 12 month workplace randomised control trial. BMC Public Health. 2015;15:152. [pmid: 25879905].