# Methods

The methods for this review of Total Worker Health^®^ (TWH) interventions follow those specified for the Agency for Healthcare Research and Quality (AHRQ) Evidence-based Practice Center (EPC) program. This guidance is codified in the “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (hereafter, Methods Guide, available at www.effectivehealthcare.ahrq.gov).

## Topic Refinement and Review Protocol

The purpose of this review is to provide an evidence report that the Pathways to Prevention (P2P) Workshop Program of the Office of Disease Prevention at the National Institutes of Health (NIH) can use to inform a workshop focused on TWH.19 The initial Key Questions (KQs) were provided by NIH's P2PWorking Group. The RTI International-University of North Carolina at Chapel Hill (RTI-UNC) EPC further refined the KQs. We incorporated guidance from a Technical Expert Panel (TEP) into the final research protocol, which was posted on the AHRQ Web site on May 26, 2015, at www.effectivehealthcare.ahrq.gov/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=2085.

## Literature Search Strategy

### Search Strategy

We searched MEDLINE^®^, the Cochrane Library, the Cochrane Central Trials Registry, and PsycInfo from January 1, 1990, to September 21, 2015. Appendix A presents the full search strategy. Its start date (January 1, 1990) reflects the timing of increased attention and focus on “integrated” interventions. A review of TWH background documents from the National Institute of Occupational Safety and Health (NIOSH), previously published narrative reviews, and our literature scan indicates that the majority of programs began after 1990.

We used either Medical Subject Headings or major headings as search terms when available or key words when appropriate, focusing on terms to describe the relevant population and interventions of interest. We reviewed our search strategy with the TEP and incorporated their input into our search strategy. An experienced information scientist (an EPC librarian) conducted the searches. We conducted quality checks to ensure that our searches identified known studies (i.e., studies identified on NIOSH's TWH Web site and expert reviews focused on integrated interventions).

We searched for unpublished studies relevant to this review using ClinicalTrials.gov and Academic Search Premier; on our behalf, the AHRQ Scientific Resource Center solicited scientific information packages via Federal Register notices or informational requests. We received a bibliography from NIOSH listing studies relevant to the TWH program. We used this bibliography to ensure that our database searches had not missed relevant citations.

We also manually searched reference lists of pertinent reviews and included trials and background articles on this topic to look for any relevant citations that our searches might have missed. We imported all citations into an EndNote® X7 electronic database.

### Inclusion and Exclusion Criteria

We developed eligibility (inclusion and exclusion) criteria with respect to PICOTS (populations, interventions, comparators, outcomes, time frames, settings), study designs, and study durations for each KQ (Table 1). The focus of this review is on providing an overall synthesis of TWH or “integrated” interventions. We cast a broad net and included any studies focused on interventions that could be considered integrated based on the intervention criteria outlined in Table 1. We included studies conducted in any workplace setting in a developed country (“very high” human development index per the United Nations Development Programme)20 to increase the applicability of our conclusions to worksites within the United States.

Table 1 Inclusion/exclusion criteria for studies of Total Worker Heath interventions

PICOTS | Inclusion | Exclusion
Population | Employed adults (18 years of age or older) | Children and adolescents under age 18
Intervention | Any “integrated intervention” that meets the definition of a TWH strategy, defined as “a strategic and operational coordination of policies, programs, and practices designed to simultaneously prevent work-related injuries and illnesses, and enhance overall workforce health and well-being.”11 We will not judge inclusion and exclusion based on the degree or type of integration^a^ To meet inclusion criteria, an intervention must include a component aimed specifically at improving workplace health and safety^b^ and a component aimed at improving overall health, health behaviors, or risk factors for chronic diseases^c^ Interventions may include a range of components that focus on changes in policy; organizational structure; work organization; environmental factors; or individual worker education, counseling, training, or social support (or combinations of these components). | All other interventions
Comparator | All KQs: Usual practice, usual care, standard care, or no intervention; head-to-head studies comparing an integrated intervention with another intervention that differs in content, intensity, or degree of integration KQ 1 only: Pre-post comparisons (in addition to the comparators listed above) | No comparison; nonconcordant historical controls
Outcomes | KQ 1: This is a descriptive summary of studies that meet inclusion criteria for all other domains (e.g., intervention and study design criteria); we will describe the range of outcomes reported across studies (in addition to the ones listed below for KQs 2, 3, and 4). KQ 2a: Health and safety outcomes: Mortality; incidence of injuries, cardiovascular disease, or cancer; morbidity related to injuries, illnesses, or chronic disease (including work-related injuries and illnesses); depression or anxiety; validated measures of functional status, quality of life, stress or distress KQ 2b: Intermediate outcomes: Tobacco, alcohol, or illicit drug use; weight or body mass index; blood pressure; cholesterol (total cholesterol, low-density lipoprotein cholesterol and high-density lipoprotein cholesterol); incidence of diabetes; frequency of physical activity; healthy eating behavior (e.g., increased consumption of fruit and vegetables); rates of hazardous exposures or “near misses” KQ 2c: Utilization outcomes and occupational injury and illness surveillance outcomes: Hospitalizations, emergency department visits, or outpatient clinic visits; measures of workers' compensation claims or injury or illness surveillance outcomes KQ 2d: Harms: Any potential harm reported in included studies, such as increased barriers to reporting work-related injuries or illnesses, work stress, adverse effects on personal health, discrimination, victim-blaming, and others KQ 3: This is a descriptive summary of interventions that are effective for improving a health and safety outcome or an intermediate outcome (from our KQ 2 analysis). KQ 4: This is a descriptive summary of contextual factors identified as potential modifiers of intervention effectiveness across all included studies. Contextual factors may include (but are not limited to) the following: legal-regulatory environment (e.g., state laws with respect to union representation); employer characteristics, policies, or benefits (e.g., availability of health insurance coverage or paid sick leave); work organization (e.g., shift work); and social or economic factors (e.g., income or availability of community resources to support or promote health). KQs 5, 6: These entail a descriptive summary of, respectively, research gaps and future research needs related to TWH interventions. | KQs 2, 3, 4: All other outcomes, such as measures of aerobic capacity (e.g., VO_2_ max) or exercise performance (e.g., number of sit-ups performed); intake of specific foods; measures of self-efficacy; participation in specific health promotion or safety programs (that are separate from the intervention); economic evaluation outcomes (e.g., cost or return on investment); work productivity measures (e.g., absenteeism)
Timing | Any duration of followup | None
Setting | Studies conducted in any workplace setting in a developed country (“very high” human development index per the United Nations Development Programme)20 | Studies conducted in other countries
Study designs | All KQs: Original research, including randomized controlled trials, nonrandomized controlled trials, prospective cohort studies with a concurrent control group KQ 1: Pre-post cohort studies without a control group (in addition to the study designs listed above) | All other designs including case reports, case series, retrospective cohort studies, nonsystematic reviews, systematic reviews, studies with historical (rather than concurrent) control groups

KQ = Key Question; PICOTS = populations, interventions, comparators, outcomes, timing, and setting; TWH = Total Worker Health; VO_2_ max = maximal rate of oxygen consumption as measured during incremental exercise.

a Variations in the degree to which interventions are “integrated” and how integration is accomplished, as well as the specific intervention components included, are considered characteristics of the integrated interventions and are the focus of KQ 1 (characteristics of interventions) and KQ 3 (characteristics of effective interventions).

b Occupational Safety and Health: Intervention (or program) components aimed at reducing hazardous exposures at work that can lead to work-related injury, illness, and disability. Interventions can be at the organizational or individual level (or both). Examples include (but are not limited to) the following: employer policies to improve (or remove) work hazards, engineering controls designed to eliminate or substitute hazards, adoption of improved personal protective equipment, and individual-level health and safety training to employees

c Worksite Health Promotion: Intervention (or program) components aimed at promoting worker health by decreasing risk factors for chronic diseases (e.g., smoking, sedentary behavior, obesity, blood pressure, and others), improving stress, and promoting overall well-being (e.g., via social support or physical activity). Intervention components may incorporate employee assistance programs, clinical prevention services, disease management programs, and other health benefits. Interventions may also include community-based services (e.g., referral for community-based health services) or environmental changes (e.g., increasing access to healthy foods at a worksite).

We did not exclude any categories of workers or studies based on the type of outcomes reported. For KQ 2, we limited our evidence synthesis to commonly reported outcomes that are considered to be important measures of worker health and safety. We chose these outcomes by reviewing prior studies of TWH interventions and asking for input from the TEP on our inclusion and exclusion criteria before finalizing the research protocol.

### Study Selection

Two members of the research team independently reviewed all titles and abstracts (identified through searches) for eligibility against our inclusion/exclusion criteria (Table 1). We retrieved any publications marked for inclusion by either reviewer for evaluation of the full text. For titles and abstracts that lacked adequate information to determine inclusion or exclusion, we retrieved the full text for review. Then, two investigators independently reviewed the full texts to determine final inclusion or exclusion. The reviewers resolved any disagreements by discussion and consensus or by consulting a third member of the review team.

All results in both review stages were tracked in an EndNote database. We recorded the principal reason that each excluded full-text publication did not satisfy the eligibility criteria (Appendix B).

### Data Extraction

For studies that met our inclusion criteria, we designed and used structured data extraction forms to gather pertinent information from each article, including characteristics of study populations, settings, interventions, comparators, study designs, methods, and results. One investigator extracted the relevant data from each included article; all data abstractions were reviewed for completeness and accuracy by a second member of the team. We recorded intention-to-treat results if available. All data abstraction was performed using Microsoft Excel® software. Once the final report is published online on the AHRQ Website, we will upload all abstracted data to AHRQ's Systematic Review Data Repository (SRDR) for use in future research.21

## Risk of Bias Assessment of Individual Studies

To assess the risk of bias (internal validity) of studies eligible for KQ 2, we used predefined criteria based on the AHRQ Methods Guide. These criteria included questions to assess selection bias, confounding, performance bias, detection bias, and attrition bias (i.e., those about adequacy of randomization, allocation concealment, similarity of groups at baseline, masking, attrition, use of intention-to-treat analysis, method of handling dropouts and missing data, reliability and validity of outcome measures, and treatment fidelity).22 Appendix C lists the specific questions used for evaluating the risk of bias of all included studies. It also includes a table showing the responses to these questions and risk of bias ratings for each study and explains the rationale for all ratings that were either high or medium. As with our abstracted data, we will upload risk of bias ratings for the review's included studies to SRDR.21

In general terms, results from a low risk of bias study are considered to be valid. A study with medium risk of bias is susceptible to some risk of bias but probably not enough to invalidate its results. A study assessed as high risk of bias has significant risk of bias (e.g., stemming from serious errors in design, conduct, or analysis) that may invalidate its results. To assess publication bias, we looked for evidence of unpublished literature through searches of gray literature (clinicaltrials.gov). We also reviewed (when available) the original protocols for included trials to assess for selective outcome reporting.

We determined the risk of bias rating using the responses to all questions assessing the various types of bias listed above. To receive a low risk of bias rating, we required favorable responses to most questions, and any unfavorable responses had to be relatively minor (e.g., minor baseline differences between study groups unlikely to bias the results). We gave high risk of bias ratings to studies that we determined to have a major methodological shortcoming in one or more categories based on our qualitative assessment. Common methodological shortcomings contributing to high risk of bias ratings were high rates of attrition or differential attrition, inadequate methods used to handle missing data, and baseline differences between intervention and control groups that were not addressed in the analysis. We describe the results of all included studies for KQ 2 regarding of the risk of bias rating.

Two independent reviewers assessed the risk of bias for each study. Disagreements between reviewers were resolved by discussion and consensus or by consulting a third member of the team.

## Data Synthesis

We did not perform any meta-analyses because of the heterogeneity across studies in terms of included populations, interventions, and outcomes. We summarized all included studies in narrative form and in summary tables that tabulate the important features of the study populations, design, intervention, outcomes, and results for KQ 1 and KQ 2.

KQ 3 asks primarily “What are the characteristics of effective interventions?” The aim of KQ 3 was to describe the characteristics of effective interventions; it is intended as a descriptive question to provide information about the interventions that work for employers or researchers who may want to implement or design TWH interventions. To address this question, we extracted detailed information on intervention components (described in KQ 1). We then focused on characteristics that relate to two main domains: (1) approach to integration (e.g., organizational integration across departments responsible for occupational safety and health and employee wellness, employee participation, and other factors) and (2) specific content of the intervention. We describe common components and combinations of components for all interventions that were effective for improving any outcome eligible for KQ 2 (at least low strength of evidence [SOE] for benefit).

For KQ 4, we compiled contextual factors identified in included studies as potential modifiers of effectiveness. Finally, KQ 5 and KQ 6 focus on evidence gaps in terms of PICOTS and future research needs, respectively.

## Strength of the Body of Evidence

We graded the SOE of the accumulated evidence on a given issue to answer the specific KQs on the benefits and harms of the interventions in this review; we used the guidance established for the EPC program.23 Developed to grade the overall strength of a body of evidence, this approach now incorporates five key domains: study limitations (including study design and aggregate risk of bias), consistency, directness, precision of the evidence, and reporting bias. It also considers other optional domains that may be relevant for some scenarios, such as plausible confounding that would decrease the observed effect and strength of association (i.e., magnitude of effect).

Table 2 describes the grades of evidence that can be assigned. Grades reflect the strength of the body of evidence to answer outcomes relevant to KQ 2 (comparative effectiveness, efficacy, and harms of the interventions in this review). Two reviewers assessed each domain for each key outcome, and differences were resolved by consensus. For each assessment, one of the two reviewers was always an experienced EPC investigator.

Table 2 Definitions of the grades of overall strength of evidence

Grade | Definition
High | We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable (i.e., another study would not change the conclusions).
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

Source: Berkman et al.23

An unfavorable assessment for any one of the four key domains (e.g., inconsistency, indirectness, imprecision, or medium aggregate risk of bias) typically resulted in downgrading from high to moderate SOE. Two unfavorable assessments typically resulted in downgrading to low SOE. When only one study reported an outcome of interest (with unknown consistency and imprecision), we usually graded the SOE as insufficient; when similar interventions had consistent results in different populations of workers or at different outcome timings we graded the SOE as low. Appendix D presents tables showing our assessments for each domain and the resulting SOE grades for outcomes eligible for KQ 2, organized by outcome category.

## Applicability

We assessed applicability of the evidence following guidance from the Methods Guide.24 We used the PICOTS framework to explore factors that affect applicability. Some factors identified a priori that may limit the applicability of evidence include the following: geographic setting, work setting (industry and worksite), occupation (and associated occupational hazards) of enrolled populations, sex of enrolled populations (e.g., few women may be enrolled in the studies), and race or ethnicity of enrolled populations.

## Peer Review and Public Commentary

This report was posted for public comment and peer reviewed. We addressed all comments in the final report, making revisions as needed; a disposition of comments report will be publicly posted 3 months after release of the final report.