# Introduction

## Background

The American worksite has been a venue for both health protection and health promotion (HP) programs. Health protection programs are interventions aimed specifically at preventing occupational injuries or illnesses. Work-related injuries and illnesses lead to morbidity, mortality, and considerable financial and social costs.1-3 HP programs, often called wellness programs, are interventions aimed at improving overall health and well-being. They often address modifiable behavior risk factors such as smoking, physical activity, and diet, which are leading causes of morbidity and mortality in the United States.4

Traditionally, occupational safety and health (OSH) programs and HP programs have functioned independently within the workplace.5 In the past decade, however, interest in integrating these programs has grown appreciably;5,6 this interest grows out of evidence supporting the idea that workplace factors contribute to adverse health outcomes traditionally considered to be unrelated to work (e.g., cardiovascular disease, depression, and others).7

The National Institute for Occupational Safety and Health (NIOSH) focused attention on integrated approaches in 2011 by creating the Total Worker Health^®^ (TWH) program. NIOSH summarized the rationale for integrating OSH and HP interventions in 2012 as follows:8 (1) risk of adverse health outcomes is increased by exposures to both occupational hazards and behavioral risk factors; (2) occupational exposures and risk factors for chronic diseases are related and may have synergistic adverse health effects; (3) workers at highest risk for hazardous occupational exposures often have more risk factors for chronic disease; and (4) integrating OSH with HP efforts may increase worker participation in health-related programs and benefit the broader work environment. TWH is currently defined as “policies, programs, and practices that integrate protection from work-related safety and health hazards with promotion of injury and illness prevention efforts to advance worker well-being.”7 Earlier descriptions of TWH focus primarily on integrating OSH and traditional worksite HP programs;8 NIOSH now emphasizes recognition that work is a social determinant of health and that job-related factors (e.g., wages, hours of work, workload and stress levels, among others) are important factors in determining the well-being of workers.7

TWH is a registered trademark term that was not commonly used in past studies of integrated interventions. For this review, we use the term “TWH interventions” to refer to integrated interventions that are consistent with NIOSH's TWH initiative. A range of interventions that differ in content, complexity, and approach to integration could be considered consistent with NIOSH's TWH initiative. For example, prior studies considered to be integrated TWH interventions were developed through strategic intraorganizational coordination and employee participation that pair organizational change with individual-level content focused simultaneously on occupational hazard(s) and HP.9,10 TWH interventions can also consist of a subset of these traits; for example, an intervention may combine components aimed at improving ergonomics and promoting physical activity with the aim of decreasing musculoskeletal injuries and improving overall health. Prior research has outlined indicators and metrics of “integration” important in TWH interventions that include factors such as organizational leadership; data integration; organizational coordination across departments responsible for health protection and HP; adequate resources, accountability, and training; and other factors.11 However, no research has evaluated these indicators separately in order to isolate whether (and to what extent) they contribute to intervention effectiveness beyond other factors such as intervention content. Efforts have been made to develop common validated metrics for these aspects of integrated intervention, but most existing studies were conducted prior to this work.11,12

## Existing Guidelines

TWH is an emerging body of literature. However, NIOSH has created guidelines for employers interested in implementing TWH programs.8,13-16 The guidelines highlight the importance of organizational leadership and commitment, employee participation, needs assessment, planning, integrated objectives, integrated implementation teams, data integration across systems responsible for OSH and HP, adequate resources, and solutions based on both organizational and individual factors. They also recommend using participation incentives and provisions to ensure accountability, evaluation, and continual improvement.

## Rationale for Evidence Review

The goal of this review is to identify gaps in the evidence about the effectiveness and harms of TWH interventions to help identify future research priorities. Previous reviews of the literature have used different search and inclusion criteria, resulting in included studies of varied rigor and scope.17,18 Moreover, the effectiveness of the interventions in individual studies and in the prior reviews has been judged based on various metrics (e.g., various improvements in health behaviors, physiologic outcomes, and economic outcomes or a count of the number of significant outcomes). As a result, uncertainty remains about the benefit and harms of TWH interventions on specific health and safety outcomes.

The authors of these studies and reviews also did not address all the Key Questions (KQs) broached in this systematic review. For example, intervention effectiveness has not been considered in relation to the occupational groups, industries, and settings in which the interventions take place. Uncertainty also remains about the role of many contextual factors that affect worker safety and health (e.g., health care coverage, company size, and unionization) as a modifier of intervention effectiveness. For example, small employers, which often do not offer health insurance, may struggle to provide comprehensive integrated interventions. In addition, more studies may have been conducted since the previous reviews and need to be added to the body of evidence. These factors underscore the need for the current systematic review to synthesize the literature supporting TWH interventions, assess the strength of evidence for important outcomes, and highlight research gaps and future research needs.

## Scope and Key Questions

The purpose of this review is to provide an evidence report that the Pathways to Prevention Workshop Program of the Office of Disease Prevention at the National Institutes of Health can use to inform a workshop focused on TWH.19 This review will describe the body of evidence evaluating TWH interventions, evaluate the effectiveness of TWH interventions for improving health and safety outcomes, highlight the research gaps, and inform future research needs. The Pathways to Prevention Workshop Program Panel will use the evidence report as a resource to develop a summary of the current state of the science and future research needs related to TWH interventions.

Specifically, we address the following six KQs:

Key Question 1

What populations, work settings, intervention types, and outcomes have been included in studies assessing integrated interventions?

Key Question 2

What is the effectiveness of integrated interventions for improving the following outcomes, and what are the potential harms?

a. Health and safety outcomes (e.g., cardiovascular events or incidence of work-related injuries)
b. Intermediate outcomes (e.g., change in blood pressure, tobacco use, or hazardous exposures)
c. Utilization outcomes and occupational injury and illness surveillance outcomes (e.g., hospitalizations or measures of workers' compensation claims)
d. Harms (e.g., discrimination or victim blaming).

Key Question 3

What are the characteristics of effective integrated interventions?

Key Question 4

What contextual factors have been identified as potential modifiers of effectiveness in studies of integrated interventions?

Key Question 5

What evidence gaps exist in the body of literature assessing the effectiveness of integrated interventions in terms of the following: populations, work settings, intervention types, outcomes, study designs, research methods, and contextual factors that may modify intervention effectiveness?

Key Question 6

What are the future research needs?

## Analytic Framework

We developed an analytic framework to guide the systematic review process (Figure 1). The analytic framework illustrates the population, interventions, outcomes, and adverse effects that guided our literature search and synthesis.

Figure 1 Analytic framework for Total Worker Health interventions

BMI = body mass index; ED = emergency department; KQ = Key Question; QOL = quality of life; WC = workers' compensation.

The Analytic Framework depicts how integrated or Total Worker Health interventions can affect our outcomes of interest in employed adults. KQ 2a addresses the relationship between these interventions and health and safety outcomes (such as mortality; incidence of injuries, cardiovascular disease or cancer; morbidity related to injuries, illness or chronic disease; depression or anxiety; and validated measures of functional status, quality of life, and stress or distress). KQ 2c focuses on how integrated interventions can affect utilization outcomes (such as hospitalizations, emergency department visits, and outpatient clinic visits) and occupational injury and illness surveillance outcomes (such as worker's compensation claims). KQ 2b pertain to the relationship between integrated interventions and intermediate outcomes (such as tobacco, alcohol or other drug use; weight or BMI; blood pressure; cholesterol; exercise frequency; healthy eating behavior, and hazardous work exposures or “near misses”) that can precede health and safety outcomes, utilization outcomes, or occupational injury and illness surveillance outcomes. KQ 3 describes the characteristics of effective integrated interventions, while KQ 4 describes potential modifiers of their effectiveness for improving any of the outcome types just described. KQs 2d and 4 deal with the potential harms of these interventions (such as discrimination or victim blaming).

## Organization of This Report

The remainder of the review describes our methods in detail and presents the results of our synthesis of the literature with summary tables and the strength of evidence grades for outcomes eligible for KQ 2. The discussion section offers our conclusions, summarizes our findings, and provides other information relevant to interpreting this work for practice and future research. References and a list of acronyms and abbreviations follow the discussion section.

Appendix A contains the exact search strings we used in our literature searches. Studies excluded at the stage of reviewing full-text articles with reasons for exclusion are listed in Appendix B. Tables in Appendix C show the specific questions used for evaluating the risk of bias of all included studies eligible for KQ 2 (i.e., studies with a concurrent comparison group), document risk of bias ratings for each study, and explain the rationale for high or medium ratings. Appendix D presents information about our grading of the strength of the various bodies of evidence (tables for individual domain assessments and overall strength of evidence grades for each outcome). Appendix E contains a reference list of studies in progress that are relevant to TWH interventions.