# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Ebi Awosika, M.D., M.P.H.
  Employee Health and Well-Being
  Veterans Health Administration
  Washington, DC
- Guy Fragala, Ph.D., P.E., CSP, CSPHP
  Patient Safety Center of Inquiry
  Tampa, FL
- Roberto Lucchini, M.D.
  Icahn School of Medicine at Mount Sinai
  New York, NY
- Harold Paz, M.D., M.S.
  Professor Adjunct of Internal Medicine
  Yale University School of Medicine
  New Haven, CT
- Gregg Stave, M.D., J.D., M.P.H., FACP, FACOEM, FACPM
  Assistant Consulting Professor
  Department of Community and Family Medicine
  Duke University Medical Center
  Durham, NC