# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Brian Caveney, M.D., J.D., M.P.H.*
  Blue Cross & Blue Shield of North Carolina
  Durham, NC
- Susan Curry, Ph.D.
  University of Iowa (also NIH Pathways to Prevention Workshop Panel)
  Iowa City, IA
- LuAnn Heinen, M.P.P.*
  Vice President, Workforce Well-being, Productivity and Human Capital
  National Business Group on Health
  Washington, DC
- David Hopkins, M.D., M.P.H.*
  Centers for Disease Control and Prevention
  Atlanta, GA
- Jim Johnson
  DEKRA Insight
  Boston, MALaura Punnett, Sc.D.*
  University of Massachusetts Lowell
  Lowell, MA
- Jeannie Tomlinson, M.S.N., R.N., COHN-S, FAAOHN
  American Association of Occupational Health Nurses
  South Glastonbury, CT