# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project and deeply appreciate their considerable support, commitment, and contributions: Kim Wittenberg, M.A., our AHRQ Task Order Officer; Dale Steele, M.D., our Associate Editor; Susan Curry, Ph.D., the Chair of the NIH Pathways to Prevention Workshop Panel; Paris Watson, M.A., the Pathways to Prevention Panel manager; RTI-UNC EPC staff: Dan Jonas, M.D., M.P.H., EPC Co-Director; Carol Woodell, B.S.P.H., EPC Project Manager; Catherine Grodensky, M.P.H., who provided assistance with data abstraction; Lynn Whitener, Dr.P.H., M.S.L.S., who provided library services; Claire Baker, who provided assistance retrieving publications and manually searching reference lists of pertinent reviews; Charli Randolph, B.A., who provided assistance with preparing our responses to peer reviewer comments and appendixes; Sharon Barrell, M.A., M.S., our editor; and Loraine Monroe, our publications specialist.