# Discussion

## Key Findings and Strength of Evidence

For this report, we conducted a systematic review to evaluate the evidence for Total Worker Health^®^ (TWH) interventions. The purpose of this review is to provide an evidence report that the Pathways to Prevention Workshop Program of the Office of Disease Prevention at the National Institutes of Health can use to inform a workshop focused on TWH.19 Below, we summarize the main findings by each Key Question (KQ), including giving the strength of evidence (SOE) for the bodies of evidence pertaining to the effectiveness and harms of interventions (KQ 2). We then discuss the findings in relation to what is already known, applicability of the findings, implications for decisionmaking, limitations of the review process or evidence base, and conclusions.

We had 24 studies described in 33 publications. We summarized the work settings and populations, interventions, and outcomes of all included trials in KQ 1. Of these 24 studies, 15 had a concurrent control group and were also eligible for KQ 2 (which assessed the effectiveness and harms of TWH interventions).9,10,25,28,29,31-33,38,41,42,50,51,54,55 We rated the risk of bias as high for 10 of these studies; the remaining 2 studies were medium risk of bias.

We graded SOE only for outcomes reported in at least one study rated as medium risk of bias. When we graded evidence as insufficient, the evidence was unavailable, did not permit estimation of an effect, or did not permit us to draw a conclusion with at least a low level of confidence. An insufficient grade does not indicate that an intervention has been proven to lack effectiveness.

For KQ 3, we describe the characteristics of interventions for which we found at least low SOE for benefit. For KQ 4, we examined all 24 studies to determine whether authors noted important contextual factors that might have affected intervention effectiveness and to inform our assessment of the gaps in the literature (KQ 5) and future research needs (KQ 6) related to TWH interventions.

## Key Question 1 Characteristics of Studies Evaluating Total Worker Health Interventions

### Work Setting and Populations

Across all 24 studies, the heterogeneity was substantial with respect to the work settings, populations, intervention, and outcomes evaluated. The majority of studies enrolled workers from the manufacturing, construction, or health care and social assistance industries. Workers from the manufacturing and construction industry were more predominantly male and included a mix of blue-collar production workers and white-collar workers. Workers enrolled in studies set in the health care and social assistance industry were predominantly female nurses. Commonly targeted workers averaged between 30 and 50 years of age; only one study evaluated a younger workforce (mean <30 years of age), and only one study evaluated an older workforce (mean >50 years of age). Few studies described the baseline health status or medical comorbidity of included populations. The health promotion (HP) or occupational safety and health (OSH) services available at worksites in addition to the intervention under study were generally not described.

### Interventions and Comparators

All studies assessed an intervention focused on an integrated objective (in terms of addressing both occupational hazards and promoting overall health). Eight studies assessed an intervention that involved strategic integration across organizational departments responsible for OSH and HP, and 17 involved worker participation in the development, design, planning, and implementation of the intervention. Six studies assessed an intervention with both strategic integration and worker participation. Most studies were multicomponent interventions; only 3 evaluated a single-component intervention. Only one included study assessed the effectiveness of integration alone (without added OSH or HP content). Twelve studies assessed interventions that included new, comprehensive HP and OSH components not previously available to workers; 6 included mostly HP content (tailored to the specific needs of workers); and 5 studies focused primarily on reducing occupational injuries, illnesses, or exposures (including work–life stress and job stress) and also included educational or other content related to promoting healthy behavior. Of the 24 studies, 15 included concurrent control groups, most of which received no intervention. Four studies included active control groups focused on HP or OSH alone.

### Outcomes

Overall, included studies measured a wide variety of outcomes. Few studies assessed the same outcomes in similar populations of workers. Approximately half of studies measured a final health outcome (e.g., quality of life, functional status). Few studies evaluated work-related injuries or illness; work stress and changes in work safety behavior were commonly outcomes related to OSH. The most commonly reported intermediate health outcomes were body mass index, biomarkers associated with risk of cardiovascular disease (e.g., cholesterol), and health behaviors (primarily physical activity, smoking, and dietary behaviors). Several studies assessed outcomes that we did not include in KQ 2 (effectiveness and harms of TWH integrations); the two most common were measures of productivity and absenteeism.

## Key Question 2 Effectiveness and Harms of Interventions

Evidence for the effectiveness and harms of TWH interventions for improving included outcomes eligible for KQ 2 consisted of 12 randomized controlled trials (RCTs), 2 nonrandomized controlled trial (NRCTs), and 1 prospective cohort study.9,10,25,28,29,31-33,38,41,42,50,51,54,55

We rated 5 RCTs as medium risk of bias32,33 and the other 10 studies as high risk of bias. We rated studies as high risk of bias primarily because of a high risk of selection bias. Most studies had high overall attrition (ranging from 14 percent to 45 percent); many studies had differential attrition across study arms. In general, studies rated high risk of bias did not use any statistical methods to address missing data. Other common areas of bias included baseline differences between groups that the investigators did not address in their analyses.

The 15 KQ 2 studies were quite diverse; few studies of TWH interventions assessed the same outcomes among similar populations of workers. Table 13 summarizes our key findings by outcomes. We found low SOE to support the effectiveness of TWH interventions for improving rates of smoking and increasing the consumption of fruit and vegetable intake compared with no intervention; we also found low SOE to support the effectiveness of TWH interventions for reducing sedentary activity at work compared with any comparator. These results are summarized in Table 13. Evidence was insufficient to permit us to assess the effectiveness of integrated interventions for improving quality of life, decreasing stress, blood pressure, weight, or consumption of red meat, overall physical activity, work-specific physical activity, or increasing safety compliance and safety behaviors; SOE grades for these outcomes are shown in Appendix D.

Table 13 Summary of key findings and strength of evidence for Total Worker Health interventions

Population; Intervention, Comparator; Time Point | N Studies; N Subjects Study Limitations | Outcome and Results | Strength of Evidence
Construction laborers32 and manufacturing workers25 Integrated intervention vs. no intervention 22–26 weeks | 2; 737 Medium or high | Self-reported 7-day smoking abstinence One RCT (N = 188 smokers and recent quitters at baseline) rated medium ROB32 found that more workers in the integrated intervention group than in the control group reported 7-day abstinence at 26 weeks: 19% vs. 8%; p = 0.03.^a^ One RCT (N = 490 smokers at baseline) rated high ROB25 found that more workers at intervention worksites than at control worksites reported 7-day abstinence at 22 weeks (26% versus 17%; p = 0.014). | Low for benefit
Manufacturing workers9,33 and construction workers32 Integrated intervention vs. no intervention 26–104 weeks | 3; 6,056 Medium or high | Self-reported fruit and vegetable consumption Two RCTs rated medium ROB: One RCT (N = 578)32 found that more workers in the intervention group than in the control group increased consumption of fruit and vegetables: mean increase in servings per day = +1.52 (SD = 3.39) vs. -0.09 (SD = 3.31); p = ≤0.0001. One RCT (N = 3,092)33 found that more workers at intervention worksites than at control worksites reported consuming 5 or more servings of fruits and vegetables per day: b mean change from baseline = +7.5% vs. +1.1%; p = 0.048. One RCT (N = 2,386) rated high ROB9 found that more workers at intervention worksites than at control worksitesincreased consumption of fruits and vegetables: mean change from baseline servings per day = 0.22 vs. 0.09; p = 0.04. | Low for benefit
Sedentary office workers,51,54 Integrated intervention vs. any comparator 16–52 weeks | 2; 262 Medium | Sedentary activity at work One RCT (N = 412)51 found decreased sedentary activity in a physical environment intervention group compared with controls: difference between groups in minutes per day spent sedentary =-57.9; 95% CI, -111.7 to 4.2; p = 0.03.^c^ One RCT (N = 60)54 found a decreased percentage of worktime spent sedentary among the integrated intervention group^d^ compared with an OSH-only group: -2.0 (95% CI, -4.4 to 0.3) vs. -0.4 (95% CI, -1.1 to 0.2); p = 0.08. | Low for benefit

CI = confidence interval; N = number; OSH = occupational safety and health; RCT = randomized controlled trial; ROB = risk of bias; SD = standard deviation.

a This RCT also found benefit for rates of 7-day abstinence of any tobacco use favoring the integrated intervention (19% versus 8%; p= 0.005).32

b In the overall sample of workers, there was no difference between intervention and control worksites (mean change from baseline percentage consuming 5 or more servings per day: +5.4% versus 1.7%; p=0.41); and managers at intervention worksites reported decreased consumption of fruit and vegetables compared with managers at control worksites (mean change from baseline consuming 5 or more servings per day: -5.5% vs. 3.6%; p=0.048).33

c There was no difference between the other two active comparators (social environmental intervention and combined social and physical environmental intervention) and the control group on any measure of work-specific physical activity or sedentary behavior outcome.51

d Workers were randomized to an ergonomic workstation optimization intervention alone or an integrated intervention that included the same ergonomic intervention plus access to a seated activity permissive workstation.54

## Key Question 3 Components of Effective Interventions

We evaluated common characteristics of interventions that were effective for improving any outcome eligible for KQ 2 for which the SOE for benefit was at least low. We focused on characteristics of interventions that relate to the approach to integration and specific content of the intervention. Overall, we were able to make very few SOE conclusions because of the limitations of the evidence base. Effective interventions were heterogeneous and separating out individual components from the overall type (or “bundles”) of interventions that showed efficacy for outcomes eligible for KQ 2 was not possible. Most effective interventions were informed by worker participation—in the development, design, planning, or implementation of the intervention (or in more than one of these steps). All effective interventions included comprehensive program content that addressed the potential additive or synergistic risks of hazardous workplace exposures and health behavior. Most effective interventions tailored intervention components or materials to cultural or social aspects of the worker population (e.g., to workers with low literacy skills or workers for whom English is not their first language). All effective interventions are multicomponent, complex interventions that reinforce messages about health and safety through multiple levels of influence or multiple modes of delivery (or both) over time.

## Key Question 4 Contextual Factors

We abstracted data from included studies that related to contextual factors that the original authors had identified as potential modifiers of intervention effectiveness. We included factors that had been noted in the results (e.g., whether the intervention was more or less effective at worksites that differed by a specific contextual factor) and also those mentioned in the discussion that could have potentially modified the effectiveness of interventions.

Eight studies identified a contextual factor that could have played a role in modifying the effectiveness of interventions. Work organization factors and union membership status were the two commonly mentioned contextual factors. Other factors mentioned in at least one study included the following: presence of another (concurrent) OSH or HP policy implemented during the study period, health insurance status or access to primary care services, support from higher management; availability of resources, and employee stress or strain related to company downsizing during the intervention period.

## Key Question 5 Research Gaps

We found numerous gaps in the literature base supporting TWH interventions in terms of work settings and populations, interventions, comparators, and deficiencies in methods.

### Work Settings and Populations

No studies enrolled workers from states in the Southwest region of the United States; only one study each was conducted in a Southeastern or Western state (Arkansas and Oregon, respectively).

No studies enrolled workers from industries in these sectors: wholesale and retail trade; information (publishing, broadcasting, telecommunications); real estate; professional, scientific, and technical services; educational services; arts, entertainment, and recreation; or accommodation and food services. The service sector as a whole (e.g., retail, transportation, communications industries, health care) is underrepresented in included studies when considering the prevalence of work-related injuries among workers employed in this sector. In terms of specific occupational groups, few studies enrolled office and administrative support workers (the occupational group with the largest employment in the United States).69 The following occupations were not represented in included studies: sales and related occupations (the second-largest major occupation group in the United States)69 and food preparation and serving workers (the third-largest major occupation group in the United States).69

No study enrolled populations of workers who were very young or very old. No study addressed differences in outcomes among subgroups of workers defined by age, sex, race, ethnicity, comorbidity, or income. People who work part time (regardless of their occupation) were often excluded from studies.

### Interventions

Studies evaluated quite diverse interventions; the type and level of integration involved in interventions varied substantially. We found no direct evidence on whether certain strategies of integration are more or less effective than others. A minority of included studies (eight studies) evaluated an intervention that clearly involved a systems-level approach to integration; that is, multiple departments within the worksite were involved with planning, implementing, and managing the intervention.

We found no studies that directly assessed whether specific combinations (or specific types) of program content were more or less effective than other combinations. Studies differed in terms of the degree to which program content focused on OSH concerns versus overall health and well-being.

We could not assess whether strategies were more or less effective based on their complexity (single versus multicomponent) or level of influence (e.g., engineering or administrative controls, individual worker education, or both).

### Comparators

In general, studies were not designed to assess directly the effectiveness of integration alone (compared with no integration). Most studies compared an intervention that included new OSH and HP content (or components) with no intervention. The effects of the new HP or OSH component (or both) offered to the intervention group could not be separated from the effects of integration. Studies that compared an intervention with no intervention (or usual workplace programs) generally did not describe the HP or OSH programs already in place and available to workers.

### Outcomes

Although we considered a wide range of outcomes for this review, we were able to rate the evidence for only three: smoking cessation, fruit and vegetable consumption, and sedentary activity at work. Very few studies with a concurrent control group measured outcomes important to OSH. Whether integrated interventions improve workplace safety (compared with OSH programs or policies that are not integrated with HP) is unclear.

We found no eligible studies eligible for KQ 2 (effectiveness and harms of interventions) reporting on the following outcomes: incidence of injuries, cardiovascular disease, or cancer; morbidity related to injuries, illnesses, or chronic disease (including work-related injuries and illnesses); depression or anxiety; body mass index; and measures of health care utilization (hospitalizations, emergency department visits, or outpatient clinic visits). A few studies reported on the following outcomes: validated measures of quality of life or functional status, stress (job or general stress), rates of workers' compensation claims, short-term disability claims, alcohol use, and illicit drug use.

No included studies prespecified harms as an outcome of interest. We looked for evidence on the following potential harms of interventions but did not find any: increased barriers to reporting work-related injuries or illnesses, work stress, adverse effects on personal health, discrimination, or victim blaming.

### Deficiencies in Methods

Of the 24 included studies, 15 had a pre-post design; because of the inherent risk of bias in pre-post studies, we did not include them in our assessment of the benefits and harms of TWH interventions. Among the 15 studies eligible for KQ 2 (i.e., those with a concurrent control group), many had methodological limitations. Among RCTs, we found inadequate reporting of randomization and allocation concealment. Most RCTs did their randomization at the worksite level; the number of worksites randomized was sometimes small. Studies often did not adequately describe the flow of participants; this was particularly true of those that randomized or assigned interventions at the worksite level.

Most studies measured outcomes based on survey responses before and after an intervention. Response rates to the baseline surveys among eligible workers were sometimes low or not reported, and this practice contributed to selection bias.

Overall attrition was high in several studies (14 percent to 54 percent in studies rated high risk of bias). Most studies did not conduct an intention-to-treat analysis (i.e., they analyzed only completers). We encountered baseline differences between groups in several studies; statistical analyses did not often address these differences. Several studies had small sample sizes and thus lacked power for determining intended effects.

Investigators sometimes did not provide information on their statistical methods; also, authors sometimes did not provide measures of variance (e.g., confidence intervals) for outcomes. In several studies, contamination of the control arms compromised internal validity; for example, another worksite policy or program initiated during the intervention period could have influenced outcomes measured in the study.

Finally, in some cases, the length of followup may not have been adequate to assess the stability of findings over time. Only seven studies measured outcomes at or beyond 1 year.

## Key Question 6 Future Research Needs

### Work Settings and Populations

Future research could target specific worksites in diverse regions of the United States that differ in terms of state government policy on economic development and labor; these factors can influence where employers locate and the attention they give to worker safety.

The applicability of interventions that were effective for reducing smoking, improving fruit and vegetable consumption, and reducing sedentary work activity is limited. Future studies should consider similar interventions in other groups of workers (e.g., other blue-collar workers) or different types of worksites to help clarify (1) the SOE for these interventions and (2) the applicability across various work settings and populations.

Consideration should be given to a broader set of populations of workers in the service sector, such as retail, transportation, and communications industries and health care in future TWH interventions. These populations have a high burden of occupational injuries. Occupational groups representing the largest number of U.S. workers should also be a focus of future research; these include (but might not be limited to) office and administrative support workers, sales and related occupations, and food preparation and serving workers. Future studies could enroll workers from diverse work settings (who receive a similar intervention, for example) to assess which factors related to the work setting modify the benefits (and potential harms) of TWH interventions.

Future studies could assess whether there are differences in outcomes among subgroups of workers defined by occupation, age, sex, race, ethnicity, comorbidity, or income (when appropriate). It is not clear whether certain categories of workers would benefit more from TWH compared with others. Future studies could enroll populations who are likely to have specific concerns related to work–life balance (e.g., caregivers of young children or elderly parents, single parents) or workers with unique health and safety concerns (older workers or workers with disabilities).

### Interventions

Future studies should clearly describe the approach used to integrate OSH and HP programs, policies, or goals. Investigators should lay out a framework for how the integrated intervention addresses both OSH and overall health. Studies should focus on interventions targeted at the work environment or work structure. Work schedules (e.g., shift work, work hours), for example, have been highlighted as an issue relevant to TWH. Few studies have assessed whether specific integrated strategies that modify the work environment improve worker health more than those focusing primarily on providing education or behavioral counseling to individual workers.

### Comparators

An established body of literature supports the efficacy of worksite wellness interventions on smoking and other important outcomes.75 Future studies should try to assess directly the effectiveness of integration itself; in other words, this aspect of TWH interventions should be isolated from the effects of a new or improved OSH or HP component. Studies should directly compare an integrated approach with a program that has similar OSH and HP elements available but does not deliberately coordinate them. In addition, investigators should clearly describe what programs related to health and safety are already in place and available to workers outside of the intervention being evaluated.

### Outcomes

Future studies should consider the feasibility of measuring OSH outcomes. To understand whether “integration” improves both OSH and HP, researchers need to examine indicators of improved safety.

Future studies should also consider direct measures of worker health if possible; for example, using validated measures of health status, functional status, and wellness. Researchers should measure the incidence or morbidity associated with chronic diseases when feasible, particularly in populations of workers at higher risk of chronic conditions (e.g., older workers).

Research teams should also chose intermediate outcomes carefully. These outcomes should be based on strong evidence for linkages to final health outcomes and for relevance to a particular population of workers.

Finally, future studies should consider assessing harms or potential unintended consequences of the interventions. Measures of harms and unanticipated effects should be made at both the individual worker and organizational levels.

### Deficiencies in Methods

Worksite randomized trials should follow the recommendations for reporting outlined in the Consolidated Standards of Reporting Trials (CONSORT) statement extension to cluster randomized trials77 or the Ottawa Statement on the ethical design and conduct of cluster randomized trials.78 In particular, authors should provide a clear flow diagram to show the flow of participants from group assignments through the final analysis. Of the 24 studies we included in this review, 9 had a pre-post design; because of the inherent risk of bias in pre-post studies, we did not include them in our assessment of the benefits and harms of TWH interventions. Among the 15 studies eligible for KQ 2 (i.e., those with a concurrent control group), many had methodological limitations.

Randomized trials are not always feasible because of barriers associated with studying populations of workers. Well-designed prospective cohort studies (or nonrandomized trials) with a concurrent control group could inform the SOE related to TWH interventions. Studies without a control group are unlikely to contribute significantly to an understanding of the SOE supporting TWH interventions (because of the inherent bias in the design); these designs should be avoided.

Investigators should plan for high attrition (and differential attrition between intervention and control groups). In addition, they should use methods to address missing data when necessary; approaches such as imputation of missing data or use of a baseline observation carried forward method (if appropriate to the outcome) should be considered.

Studies should address baseline differences between groups (when they are present) using appropriate statistically methods. Furthermore, investigators should report measures of variance (e.g., confidence intervals) for all outcomes they evaluate. Finally, in reporting their studies, authors should highlight whether other (concurrent) OSH and HP policies or programs had been in place or implemented during the intervention in question; this will enable them to assess bias associated with contamination.

## Findings in Relation to What Is Already Known

This is an emerging body of literature; we did not find a previous systematic review that was similar in scope or that assessed the SOE related to common outcomes reported in studies of TWH interventions. We identified one prior systematic review18 and one expert (or narrative) review17 that provided a broad overview of TWH interventions.

The results of our current review are, in general, consistent with those in previous reviews with respect to conclusions about the limitations of the evidence base. For example Anger and colleagues noted that integrated interventions improved risk factors for chronic diseases. They concluded, however, that the evidence that integration itself confers a significant benefit is lacking and is “perhaps the most glaring gap in the TWH literature.”18

Like previous reviews, we took a broad approach to defining “integration.” Not surprisingly, our review and the two earlier reviews differ slightly in terms of included studies and whether we considered them integrated or not. For example, one study assessing a worksite wellness program designed for firefighters was included in the review by Anger and colleagues; we excluded this study because it had no explicit coordination between OSH and HP programs and no obvious OSH content or focus of the intervention.79 We also excluded studies evaluating “sit-stand” workstations only (with no explicit coordination with HP activities or promotion of physical activity outside of work).80

Our review differs from others in terms of methods. Prior reviews have either not addressed potential bias associated with TWH interventions or used study design labels as a proxy for assessment of the risk of bias of included studies.18 We used standard techniques for assessing risk of bias for individual trials or observational studies (documented in Appendix C) and grading the SOE for entire bodies of evidence (Appendix D).

Moreover, in terms of overall conclusions about the effectiveness of TWH interventions, our review differs in that we assessed the SOE for specific outcomes. Prior reviews have made generalized statements about the positive effects of TWH interventions or have summarized the benefits primarily by noting the number of statistically significant outcomes found across studies; they generally have not considered the consistency or precision associated with findings.17,18 In general, the two prior reviews make stronger conclusions regarding the benefits of integrated integration than we reached.

### Applicability

During our review process, we systematically abstracted key factors that may affect the applicability of the evidence base. We identified these key factors a priori. We defined applicability according to Agency for Healthcare Research and Quality guidance: “the extent to which the effects observed in published studies are likely to reflect the expected results when a specific intervention is applied to the population of interest under real-world conditions.”24 For this review, we focused on issues that relate to populations of workers and worksites in the United States.

Approximately one-half of the studies we included had been conducted in this country; the others were conducted in European or Scandinavian countries. Included studies focused primarily on populations employed either in the manufacturing or construction industries or in health care. Populations enrolled in included studies were generally between the ages of 30 and 50; the baseline comorbidity of workers was often not described. Results of included studies may not be applicable to workers who are very young or very old or who have a high burden of comorbid medical conditions. The proportion of workers who had access to medical care or other, ongoing worksite health programs was often not well described. Whether the results of included studies would apply to worksites that have established HP and OSH programs in place (whether or not they are integrated) remains unclear.

Studies that contributed to our SOE grades for smoking and healthy eating outcomes had all been conducted among U.S. blue-collar workers (manufacturing worksites in the Massachusetts or unionized construction workers). The evidence for which we developed SOE grades is based on survey data collected before 2004 and comes from the same group of researchers.9,10,32,33 Within the past decade (i.e., since the mid-2000s), workplace HP and OSH programs have very likely been improved; whether the results of these trials would be applicable to worksites that already have active HP programs (or policies) that promote smoking cessation and healthy eating is not clear.

More recent changes in health policy or practice (such as community health interventions and health care) may limit the applicability of studies published 10 or more years ago. After the implementation of the Affordable Care Act, national surveys show improvements in self-reported health care coverage, access to primary care and medications, greater affordability, and better health among younger populations of men (at least in states that expanded Medicaid coverage).81 Access to smoking cessation services may be more widely available because of these changes; intervention components evaluated in older studies could now be considered “usual care” in some settings.

## Limitations of the Review Process

We cast a broad net in terms of our inclusion criteria that relate to interventions. The studies that met our inclusion criteria used a range of strategies to address both OSH and overall health and well-being. Included studies were often published before the terms “integrated intervention” or “total worker health” were used to describe interventions. Because of a lack of consistent terminology related to “integration” and (potentially) inadequate reporting or description of intervention components in some studies, we may have overlooked some interventions that could be considered integrated. This was also a limitation in terms of synthesizing the evidence across complex interventions that use various approaches to addressing OSH and overall health. Our inclusion criteria for interventions are based on the definition of a TWH program from the National Institute of Occupational Safety and Health for “total worker health” and other, related guidance on integration.11 The definition of TWH itself has shifted (in 2015) away from a more narrow focus on integrating OSH and HP to “an approach that advocates for a holistic understanding of the factors that contribute to worker well-being.”71 Our review scope did not include all studies that might fall under the larger umbrella of concerns relevant to TWH.

Our searches were based on studies generally considered to be focused on integration; however, these studies are not indexed by standard or consistent terms that are specific to integration or TWH. To address this deficiency, we solicited and received a database from NIOSH that listed studies deemed relevant to TWH. Our search strategies had identified the vast majority of these studies. Nevertheless, some studies that we excluded might still be considered related to TWH. All in all, therefore, whether certain types of interventions are considered integrated remains inconsistent. As noted previously, our review and two other prior reviews differed slightly in terms of included studies; for example, we excluded at least three studies found in those prior reviews as “wrong intervention” because they primarily addressed HP only or OSH only.82,83

Publication bias and selective reporting of outcomes are potential limitations. Although we searched for unpublished trials and unpublished outcomes, we did not find direct evidence of either of these biases. Many of the included trials were published before trial registries (e.g., clinicaltrials.gov) became available; had we been able to consult such registries, we would have had greater certainty about the potential for either type of bias.

Finally, for this review, we excluded non-English-language studies based largely on limitations of time and resources. However, we identified non-English-language studies in our searches and did not see any references that had the potential to be useful in this review. Searches of the NIOSH references did not uncover any non-English-language studies. Given this, and the fact that TWH is a relatively new strategy, we believe that limiting our review to English-language studies had little effect.

## Limitations of the Evidence Base

The evidence base assessing TWH interventions was limited in scope and volume. It was inadequate to draw conclusions for some of our questions or subquestions of interest. Authors of different studies did not usually report the same outcomes or assess similar intervention types. Because of gaps in the trial evidence and because conducting trials in workplace settings is challenging, we included observational studies in this review.

For KQ 2, we limited our synthesis to studies with a concurrent control group. Studies with a pre-post comparison only generally do not provide valid and useful information to address questions of the benefits and harms of interventions. We did include pre-post studies to inform the assessment of gaps and future research needs, primarily in terms of describing gaps in the types of populations and interventions assessed in prior studies. Limiting by study design is unlikely to have had a major effect in terms of our assessment of the SOE.

Among studies eligible for KQ 2, many had methodological limitations introducing significant risk of bias. The major problems across studies relate to selection bias and attrition bias. These are described above under the section on research gaps (methodological limitations). Briefly, many studies relied on surveys to assess improvements in worker health; nonresponse bias is a concern. Overall attrition in studies was often high. For the 10 studies that had very high overall attrition (>20 percent), high differential attrition (>15 percent), or both, only 1 of these studies employed methods to address missing data42 (e.g., last observation carried forward). Selection bias at the worksite level is also a potential concern; employers who agree to participate in studies assessing integrated interventions may differ in important ways from employers who decline to participate. Most trials analyzed only completers and did not use any methods to address missing data.

Among other problems seen (even in studies with medium risk of bias overall), we noted especially the following: no reporting of randomization and allocation concealment, difference in intervention and control groups at baseline, small sample sizes (and thus lack of power for determining intended effects), and lack of clarity in defining intervention components. Finally, studies often lacked of information on statistical methods (or data on confidence intervals or similar information on statistical tests).

## Conclusions

Overall, we found the body of evidence to be small, heterogeneous in terms of populations; interventions; and measured outcomes; and, in some areas of interest, nonexistent. The small size of the body of evidence is not altogether surprising given that the concept of “integration” is relatively new. The body of evidence may reasonably be expected to grow over the next few years. Evidence of low SOE supported the effectiveness of TWH interventions for improving the following: rates of smoking cessation over 22 to 26 weeks, increasing the consumption of fruit and vegetable intake over 26 to 104 weeks, and reducing sedentary work activity over 16 to 52 weeks. Evidence was insufficient to assess the effectiveness of integrated interventions for improving the following outcomes: quality of life, stress, blood pressure, weight, overall and work-specific levels of physical activity, consumption of red meat, safety behaviors, and safety compliance. Effective interventions were informed by worker participation and included comprehensive program content that highlighted the potential additive or synergistic risks of hazardous workplace exposures and health behavior. The applicability of these findings is limited; most trials enrolled blue-collar workers (from manufacturing worksites in Massachusetts or unionized construction workers) before 2004.

Additional adequately powered multisite RCTs or other prospective studies with a concurrent control are needed to replicate encouraging findings that have been observed to date in only a few trials. Investigators also need to design studies explicitly to assess the benefits of integration separate from new OSH or HP components. Including a broader range of workers in future studies could increase the applicability of TWH interventions and enable reviewers to assess the consistency of findings. It might also answer the question of whether integrated strategies are more effective (or not) in groups of workers who differ by demographic, social, or occupational characteristics that contribute to adverse health outcomes.