# Strength of Evidence Tables

Table D1 Strength of evidence: Smoking cessation

Population; Intervention, Comparator; Outcome measure; Time-point | Number of Studies; Subjects Study Design | Study Limitations | Consistency | Directness | Precision | Direction and Magnitude of effect | Strength of Evidence
Construction laborers1 and manufacturing workers2 Integrated Intervention versus no intervention; Self-reported 7-day abstinence 22-26 weeks | 2; 737 RCTs | Medium or High | Consistent | Indirect | Precise | One RCT (N = 188 smokers and recent quitters at baseline) rated medium ROB1 found more workers in the integrated intervention group reported 7-day abstinence at 26 weeks than workers in the control group: 19% vs. 8%; p= 0.03^a^ One RCT (N = 490 smokers at baseline) rated high ROB 2 found more workers at intervention worksites reported 7-day abstinence at 22 weeks compared with workers at control worksites (26% versus 17%; p=0.014) | Low for benefit

a This RCT found also found benefit for rates of 7-day abstinence of any tobacco use favoring the integrated intervention (19% versus 7%; p= 0.005).1

RCT = randomized controlled trial; ROB= risk of bias.

Table D2 Strength of evidence: Healthy eating behavior (increased consumption of fruit and vegetables)

Population; Intervention Category; Time-point | Number of Studies; Subjects Study Design | Study Limitations | Consistency | Directness | Precision | Direction and Magnitude of effect | Strength of Evidence
Manufacturing workers3,4 and construction workers1 Integrated Intervention versus no intervention; 26-104 weeks | 3; 6056 RCTs | Medium or High | Consistent | Indirect | Precise | Two RCTs rated medium ROB: One RCT (N=578)1 found that more workers in the intervention group increased consumption of fruit and vegetables than workers in the control group: mean increase in servings per day= +1.52 (SD=3.39) vs. -0.09 (SD=3.31); p= <0.0001 One RCT (N=3,092)3 found more workers at intervention worksites reported consuming 5 or more servings of fruits and vegetables per day than workers at control worksites^a^: mean change from baseline= +7.5% vs. +1.1%; p=0.048 One RCT (N= 2,386) rated high ROB4 found more workers at intervention worksites increased consumption of fruit and vegetables than workers at control worksites: mean change from baseline servings per day= 0.22 vs. 0.09; p=0.04 | Low for benefit

a In the overall sample of workers, there was no difference between intervention and control worksites (mean change from baseline % consuming 5 or more servings per day: +5.4% versus 1.7%; p=0.41); and managers at intervention worksites reported decreased consumption of fruit and vegetables compared with managers at control worksites (mean change from baseline consuming 5 or more servings per day: -5.5% vs. 3.6%; p=0.048).3

RCT = randomized controlled trial; ROB= risk of bias; SD = standard deviation.

Table D3 Strength of evidence: Healthy eating behavior (decreased consumption of red meat)

Population; Intervention Category; Time-point | Number of Studies; Subjects Study Design | Study Limitations | Consistency | Directness | Precision | Direction and Magnitude of effect | Strength of Evidence
Manufacturing workers;3 Integrated Intervention versus no intervention; 78 weeks | 1; 309 RCT | Medium | Unknown | Indirect | Imprecise | Percent of workers who reported consuming 3 or fewer servings of red meat per week: mean change from baseline= +4.1% in the intervention group vs. +3.0% in the control group; p=0.72 | Insufficient

RCT = randomized controlled trial.

Table D4 Strength of evidence: Increased levels of physical activity

Population; Intervention Category; Time-point | Number of Studies; Subjects Study Design | Study Limitations | Consistency | Directness | Precision | Type of Physical Activity Measure Direction and Magnitude of effect | Strength of Evidence
Manufacturing workers,3 and office workers employed at a financial institution5 Integrated Intervention versus no intervention; 16-78 weeks | 2; 3504 RCTs | Medium | Unknown | Indirect | Precise for outcome in manufacturing workers); imprecise for outcome in sedentary office workers | Overall physical activity: One RCT (N= 3,092; manufacturing workers)3 found increased self-reported physical activity levels at intervention worksites compared with control worksites^a^: change from baseline % reporting ≥ 2.5 hours of physical activity per week= +7.1 vs. -2.1; p=0.09 One RCT (N= 412; sedentary office workers)5 found no difference between three integrated intervention groups and a control group on any measure of overall physical activity (weekly levels of light, moderate and vigorous physical activity; leisure time activity, active commuting and sports activity) | Insufficient
Sedentary office workers,5,6 Integrated Intervention versus any comparator 16-52 weeks | 2; 262 RCTs | Medium | Unknown (different outcome measures) | Indirect | Precise for stair climbing at work; Imprecise for occupational physical activity level | Work-specific physical activity: One RCT (N=412)5 found increased stair climbing at work in a physical environment intervention compared with controls: difference between groups in number of times workers reported using stairs per day= 1.0; 95% CI, 0.5 to 1.5; p <0.01. One RCT (N=60)6 found no difference between groups in total occupational physical activity, or work time spent in moderate or vigorous physical activity; workers in the integrated intervention increased the percent of work time spent in light physical activity more than a OSH-only group: 0.7% (95% CI,-0.2 to 1.7) vs. -0.4% (95% CI, -1.1 to 0.2); p=0.04 | Insufficient
Sedentary office workers,5,6 Integrated Intervention versus any comparator 16-52 weeks | 2; 262 RCTs | Medium | Consistent | Indirect | Precise | Sedentary activity at work: One RCT (N=412)5 found decreased sedentary activity in a physical environment intervention group compared with controls: difference between groups in minutes per day spent sedentary= -57.9; 95% CI, -111.7 to 4.2; p=0.03.^b^ One RCT (N= 60) 6 found decreased percent of work time spent sedentary among the integrated intervention group c compared with a OSH-only group: -2.0 (95% CI, -4.4 to 0.3) vs. -0.4 (95% CI, -1.1 to 0.2); p=0.08 | Low for benefit

a In the overall sample of workers, there was no difference between intervention and control worksites (mean change from baseline % reporting ≥ 2.5 hours of physical activity per week= +5.4% versus -0.9%; p=0.23); and managers at intervention worksites reported decreased levels of physical activity compared with managers at control worksites (mean change from baseline % reporting ≥ 2.5 hours of physical activity per week= -2.0% vs. +3.7%; p=0.009).3

b There was no difference between the other two active comparators (social environment intervention and combined social and physical environment intervention) and the control group on any measure of work-specific physical activity or sedentary behavior outcome.5

c Workers were randomized to an ergonomic workstation optimization intervention alone or an integrated intervention that included the same ergonomic intervention plus access to a seated activity permissive workstation.6

RCT= randomized controlled trial.

Table D5 Strength of evidence: Work stress

Population; Intervention Category; Time-point | Number of Studies; Subjects Study Design | Study Limitations | Consistency | Directness | Precision | Direction and Magnitude of effect | Strength of Evidence
Office workers employed at a financial institution;5 Integrated Intervention versus no intervention; 52 weeks | 1; 412 RCT | Medium | Unknown | Direct | Imprecise | Workers in the combined intervention group a experienced greater reduction in exhaustion measured by the Oldenburg Burnout Inventory than the control group. There was no difference between the control group and any of the three active comparator arms on the following outcomes: need for recovery after work, detachment after work and relaxation after work. | Insufficient

a The study randomized workers to one of four arms, including: (1) no intervention control group, (2) social environment intervention, (3) physical environment intervention, and (4) combined social and physical environment intervention.5

RCT= randomized controlled trial.

Table D6 Strength of evidence: Quality of life (SF-12)

Population; Intervention Category; Time-point | Number of Studies; Subjects Study Design | Study Limitations | Consistency | Directness | Precision | Direction and Magnitude of effect | Strength of Evidence
Construction and utility workers;7 Integrated Intervention versus no intervention; 52 weeks | 1; 264 RCT | Medium | Unknown | Direct | Imprecise | No difference between groups a on the SF-12 physical health component summary score: difference between groups on post-intervention score (SE): = -0.32 (0.82); p=0.69 | Insufficient

a Workers were randomized to an intervention aimed at improving work-life stress, (via supervisor behavior training and employee work groups) or no intervention.

RCT= randomized controlled trial; SE= standard error; SF-12 = Medical Outcomes Study Short Form (12 items)

Table D7 Strength of evidence: Safety Compliance and Safety Behaviors

Population; Intervention Category; Time-point | Number of Studies; Subjects Study Design | Study Limitations | Consistency | Directness | Precision | Direction and Magnitude of effect | Strength of Evidence
Construction and utility workers;7 Integrated Intervention versus no intervention; 52 weeks | 1; 264 RCT | Medium | Unknown | Direct | Imprecise | No difference between groups^a^ in mean safety participation scores (0.14; SE=0.09; p=0.014) or mean safety compliance scores (-0.02; SE=0.08;p=0.83).7 | Insufficient

a Workers were randomized to an intervention aimed at improving work-life stress, (via supervisor behavior training and employee work groups) or no intervention. Safety compliance and safety participation were measured via self-report on items such as “I use the correct safety procedures” and “I voluntarily carry out tasks or activities that help to improve workplace safety”; responses were rated on a 5-point scale and computed as a mean response (higher scores = higher levels of safety and compliance).

RCT= randomized controlled trial; SE= standard error; SF-12 = Medical Outcomes Study Short Form (12 items)

Table D8 Strength of evidence: Blood pressure

Population; Intervention Category; Time-point | Number of Studies; Subjects Study Design | Study Limitations | Consistency | Directness | Precision | Direction and Magnitude of effect | Strength of Evidence
Sedentary desk job workers;6 Construction and utility workers;7 Integrated Intervention versus any comparator 16 to 52 weeks | 2; 324 RCTs | Medium | Unknown | Indirect | Imprecise | One RCT (N= 264; construction and utility workers) found a small statistically significant improvement in MAP in the integrated intervention group^a^ compared with controls at 52 weeks (change in MAP= -2.15 mm Hg; SE=1.03; p=0.038).7 One RCT (N= 60; sedentary office workers) found no difference between groups^b^ at 16 weeks; only p-values reported for systolic blood pressure (p=0.90) and diastolic blood pressure (p=0.48).6 | Insufficient

a Workers were randomized to an intervention aimed at improving work-life stress, (via supervisor behavior training and employee work groups) or no intervention.

b Workers were randomized to an ergonomic workstation optimization intervention alone or an integrated intervention that included the same ergonomic intervention plus access to a seated activity permissive workstation.6

MAP = mean arterial blood pressure; OSH= Occupational Safety and Health; RCT= randomized controlled trial; SE= standard error

Table D9 Strength of evidence: Weight

Population; Intervention Category; Time-point | Number of Studies; Subjects Study Design | Study Limitations | Consistency | Directness | Precision | Direction and Magnitude of effect | Strength of Evidence
Sedentary desk job workers;6 Integrated Intervention versus OSH-only intervention; 16 weeks | 1; 60 RCT | Medium | Unknown | Indirect | Imprecise | No difference between groups^a^ in the weight change from baseline to follow-up at 16 weeks (p=0.80; data not reported) | Insufficient

OSH = Occupational Safety and Health; RCT= randomized controlled trial.

a Workers were randomized to an ergonomic workstation optimization intervention alone or an integrated intervention that included the same ergonomic intervention plus access to a seated activity permissive workstation.6

## References for Appendix D

1 Sorensen G, Barbeau EM, Stoddard AM, et al. Tools for health: the efficacy of a tailored intervention targeted for construction laborers. Cancer Causes Control. Feb. 2007;18(1):51-9. [pmid: 17186421].
2 Okechukwu CA, Krieger N, Sorensen G, et al. MassBuilt: effectiveness of an apprenticeship site-based smoking cessation intervention for unionized building trades workers. Cancer Causes Control. Aug. 2009;20(6):887-94. [pmid: 19301135].
3 Sorensen G, Barbeau E, Stoddard AM, et al. Promoting behavior change among working-class, multiethnic workers: results of the healthy directions--small business study. Am J Public Health. Aug. 2005;95(8):1389-95. [pmid: 16006422].
4 Sorensen G, Stoddard A, Hunt MK, et al. The effects of a health promotion-health protection intervention on behavior change: the WellWorks Study. Am J Public Health. Nov. 1998;88(11):1685-90. [pmid: 9807537].
5 Coffeng JK, Boot CR, Duijts SF, et al. Effectiveness of a worksite social &amp; physical environment intervention on need for recovery, physical activity and relaxation; results of a randomized controlled trial. PLoS One. 2014;9(12):e114860. [pmid: 25542039].
6 Carr LJ, Leonhard C, Tucker S, et al. Total Worker Health Intervention increases activity of sedentary workers. Am J Prev Med. 2015. Jul. 31. [pmid: 26260492].
7 Hammer LB, Truxillo DM, Bodner T, et al. Effects of a workplace intervention targeting psychosocial risk factors on safety and health outcomes. BioMed Research International. 2015;2015:12.