# Risk of Bias Ratings

Table C1 Risk of bias assessments for TWH studies eligible for Key Question 2, part 1

Author, Year Trial Name (if applicable) | Study Design | Eligibility criteria clearly described? | [underlined: RCTs ONLY]: Method of randomization method adequate? | [underlined: RCTs ONLY]: Randomization at worksite or individual level? | [underlined: RCTs ONLY:] Allocation concealment adequate? | [underlined: Obs Studies ONLY]: Groups recruited from same source population? | Baseline Chx similar? | Intervention fidelity adequate?
Allen, 2003^1^ International's Allergy Project | NRCT | Yes | NA | NA | NA | Yes | Yes | NR/CND
Boggild, 2001^2^ | Prospective cohort study | No | NA | NA | NA | No | No | NR/CND
Carr, 2015^3^ | RCT | Yes | Yes | Individual | Yes | NA | Yes | NR/CND
Coffeng, 2014^4^ Be Active &; Relax “Vitality in Practice” | RCT | Yes | Yes | Worksite | NR/CND | NA | Yes | NR/CND
Eriksen, 2002^5^ | RCT | Yes | Yes | Worksite | Yes | NA | No | NR/CND
Hammer, 2015^6^ Safety and Health Improvement Program (SHIP) | RCT | Yes | NR/CND | Other (see comments) | NR/CND | NA | Yes | NR/CND
Maes, 1998^7^ The Brabantia Project | NRCT | No | NA | NA | NA | No | No | No
Okechukwu, 2009^8^ MassBuilt | RCT | Yes | NR/CND | Worksite | NR/CND | NA | No | NR/CND
Palumbo, 2012^9^ | RCT | Yes | NR/CND | Individual | NR/CND | NA | NR/CND | Yes
Sorensen, 1998^10-12^ WellWorks | RCT | Yes | NR/CND | Worksite | NR/CND | NA | NR/CND | NR/CND
Sorensen, 2003^13-15^ WellWorks-2 | RCT | Yes | Yes | Worksite | Yes | NA | No | NR/CND
Sorensen, 2005^16-18^ Healthy Directions-Small Business | RCT | Yes | NR/CND | Worksite | NR/CND | NA | No | NR/CND
Sorensen, 2007^19^ Tools for Health | RCT | Yes | NR/CND | Individual | NR/CND | NA | Yes | NR/CND
Tveito, 2009^20^ Integrated Health Programme | RCT | Yes | Yes | Individual | NR/CND | NA | NR/CND | NR/CND
von Thiele Schwarz, 2015^21^ | RCT | Yes | NR/CND | Hospital Ward | NR/CND | NA | No | Yes

Chx, Characteristics; CND, cannot determine; Obs, observational; NA, not applicable; NR, not reported; NRCT, non-randomized controlled trial; RCT, randomized controlled trial; ROB, risk of bias

Table C2 Risk of bias assessments for TWH studies eligible for Key Question 2, part 2

Author, Year | Reported adherence to the intervention? | Overall attrition? | Differential attrition? | Differential (≥15%) or overall high attrition (generally ≥20%) raising concern for bias? | Analysis conducted on an ITT basis?
Allen, 2003^1^ International's Allergy Project | NR | NR | NR | NR/CND | No
Boggild, 2001^2^ | Variable a | Workplace: None; Workers: baseline survey response 68%; 24 weeks (101 baseline respondents - 75 completed post-test)/101 = 26% | Unclear b | Yes | No
Carr, 2015^3^ | Activity monitor: 92%; Active workstation: 70% | Overall: 10%; Lost to Followup: 8%; Discontinued: 2% | 0% | No | No
Coffeng, 2014^4^ Be Active &; Relax “Vitality in Practice” | See comments | 6 months: 15%; 12 months: 20% | Attrition (% sample) by study arm for the control/social/physical/combo groups: 6 months: 8/11/15/29; 12 months: 9/20/21/32 | Yes | Yes
Eriksen, 2002^5^ | NR | Workers, 52 weeks: (860 randomized/completed pre-survey - 472 completed follow-up)/860 randomized=45%; Workers, 12 weeks: (860 randomized/completed pre-survey - 628 completed post-test)/860 randomized = 27% | Workers, 52 weeks: 40-52% across groups; Workers, 12 weeks: 20-33% across groups | Yes | Yes
Hammer, 2015^6^ Safety and Health Improvement Program (SHIP) | See comments | 10% (see comments) | 4% (see comments) | No | Yes
Maes, 1998^7^ The Brabantia Project | Variable c | Workers: baseline survey response (52%); Workers, 156 weeks: (346 baseline respondents - 264 follow-up survey respondents)/346 = 24% | 0% | Yes | No
Okechukwu, 2009^8^ MassBuilt | NR | Workers: baseline survey response 94%; at 6 months: (1817 initial responders - 1213 completers)/1817=33% | NR/CND | Yes | Yes
Palumbo, 2012^9^ | Average attendance of 13 classes= 82% | Workers: 21% | 14% | Yes | Yes
Sorensen, 1998^10-12^ WellWorks | See comments | Worksites: NR; Workers, mean baseline survey response across sites 61% (range 36-99%); Workers, post-intervention: (5914 baseline respondents – 2658 follow-up survey respondents)/5914 = 60% | NR | Yes | No
Sorensen, 2003^13-15^ WellWorks-2 | NR | Worksite: 2/17 (11.8%); Workplace processes (for safety outcomes): 24/131 (18.3%); Workers, baseline survey response rate: 57%; baseline respondents to final survey: (9019-5156)/9019 = 43% | Worksite: unclear; Workplace processes: unclear, differential N provided for only 16 of 24 missing workplace processes; Workers: unclear d | Yes | No
Sorensen, 2005^16-18^ Healthy Directions-Small Business | Variable e | Worksites: 8%; Workers: baseline respondents to final survey: (1740 baseline respondents - 974 who completed baseline and follow-up survey)/1740 = 44% | Worksites: 0%; Workers: NR | Yes | Yes
Sorensen, 2007^19^ Tools for Health | NR | 14% | 3% | No | Yes
Tveito, 2009^20^ Integrated Health Programme | NR | 28% | 18% | Yes | Yes
von Thiele Schwarz, 2015^21^ | NR | Workers: (312 workers with baseline survey - 202 workers completed all surveys)/312 workers = 35% Workers, baseline survey response rate: 87.5% | NR/CND | Yes | NA

a The authors state that some wards did not consistently adhere to schedule due to “staff shortage, sickness and maternity leave, new rules for handling overtime work, and the like.”2

b Authors state initial participation did not differ between wards. “Dropout rate” between baseline and 6 months was significantly higher in “intervention control wards and lower in the day-working control wards.”2

c The authors note that participation for health promotion activities varied: 10-20% participation rate for health education sessions and 60-70% for health fair and exhibition.

d The authors only provide sufficient data to calculate differential attrition for the cross-sectional sample of workers who completed a baseline and following-up survey (7%); for the embedded sample who completed a baseline survey, the non-response rate to the follow-up survey by group (intervention versus control) is NR.

e Varied by intervention component and worksite: 74% of final survey respondents reported participating in ≥1 of 17 health promotion and/or safety programs at intervention sites vs. 29% at control sites. Mean worksite participation was 47% per event per site (range: 17-56%)17

CND, cannot determine; ITT, intent-to-treat; N, number; NA, not applicable; NR, not reported

Table C3 Risk of bias assessments for TWH studies eligible for Key Question 2, part 3

Author, Year | Cross-overs or contamination raising concern for bias? | Eligible outcome measures valid and reliable? | Outcome assessors masked? | Duration of follow-up adequate to assess outcome? | Appropriate method used to handle missing data? | Analysis adjusted for potential confounders? | ROB | Comments on Risk of Bias Rating
Allen, 2003^1^ International's Allergy Project | No | Yes | NR/CND | No | No | No | High | Experimental and control sites differed at baseline (age, job type, union concentration and allergy medicine regimens). Participation varied substantially by worksite and intervention component. Outcome measures were poorly described and evaluated after only one education cycle; authors note several cycles may be required to produce desired changes. Multiple elements of study design were NR. Attrition was NR; analyses focus on completers (pre-post surveys).
Boggild, 2001^2^ | No | Yes | No | Yes | No | NR/CND | High | High overall attrition and differential attrition contributed to high risk of selection bias. Groups differed at baseline (satisfaction with works schedule, exercise frequency and smoking status); there was no adjustment for differences or other confounding variables in the analysis. Some wards chose to implement a partial rather than full set of intervention components. Authors compared three groups based on participation (full, partial, none); reasons for choosing or not choosing the full intervention may relate to work conditions or baseline differences across wards.
Carr, 2015^3^ | NR/CND | Yes | Yes | Yes | No | Yes | Medium | In total 57% of employees (N=167) completed both baseline and follow-up surveys.
Coffeng, 2014^4^ Be Active &; Relax “Vitality in Practice” | NR/CND | Yes | No | Yes | Yes | Yes | Medium | Selection bias is a concern; of 1182 eligible workers, 412 enrolled in the study (35% response rate). Participation may have been very low at some sites; the percent of participants that used any of the intervention components at least once ranged from 45-76% across sites. Authors report that cross-over/contamination is unlikely since randomization was at the department level, but did note that the control group may have used some environmental modifications. There was substantial overall and differential attrition; authors reported that there was no difference in baseline characteristics between completers and non-completers. Authors performed a linear mixed model analysis for each outcome measure assuming data was missing at random.
Eriksen, 2002^5^ | No | Yes | NR/CND | Yes | Partially | No | High | High overall and differential attrition contributed to selection bias. Groups differed at baseline (number of working hours per week and years in current occupation). Authors conducted a modified ITT analysis and handled missing data using a LOCF approach for some outcomes
Hammer, 2015^6^ Safety and Health Improvement Program (SHIP) | NR/CND | NR/CND | No | Yes | Yes | Yes | Medium | Randomization and allocation concealment were not described. All supervisors and workgroups completed sessions; adherence (or participation) by individual workers is unclear. There was an e evaluation of the extent and effect of missing data on results; missing data patterns were described, imputation was utilized, and additional analytic approaches were used to accommodate the missing data. In total, 57% of employees (N=167) completed both baseline and follow-up surveys. Of 90% of randomized employees who completed either a baseline or 12 month survey included in the analysis; overall attrition based on the N analyzed was 10%.
Maes, 1998^7^ The Brabantia Project | NR/CND | No | No | Yes | No | Yes | High | At baseline: intervention group had more women (26% vs. 12%) and less education (61% vs. 49% with only an elementary education) than control group. Groups also differed in variables associated with working conditions. Only gender and educational level were entered as covariates in analyses. Adherence to some intervention components was very low. Important outcomes were mostly reported as composite scales or scores. Overall attrition was high (24%).
Okechukwu, 2009^8^ MassBuilt | NR/CND | Yes | NR/CND | Yes | No | Yes | High | Groups differed in race, gender, and income at baseline. There is high overall attrition (33%) and no methods used to handle missing data. Differential attrition NR.
Palumbo, 2012^9^ | NR/CND | Yes | NR/CND | Yes | No | No | High | Baseline characteristics are noted in text but not provided in a table. Study is small (N=14) with overall high attrition (21%) and differential attrition (14%), and no methods were used to address missing data. Numerous risk of bias elements NR.
Sorensen, 1998^10-12^ WellWorks | NR/CND | Yes | No | Yes | No | Yes | High | High risk of selection bias. There was substantial attrition for the primary outcome measure; differential attrition is unclear. Participation varied across intervention activities and by job status; overall participation in ≥1 activity during two year intervention was 34-40%. Self-reported quit rate measure has risk of recall bias. Numerous risk of bias elements NR.
Sorensen, 2003^13-15^ WellWorks-2 | NR/CND | Yes | No | Yes | No | NR/CND | High | Groups differed at baseline in terms of age, education and job type. There is high attrition (54%) not accounted for in the analysis; differential attrition is not clearly reported. Self-reported quit rate measure has risk of recall bias. Safety measures not validated. Authors report adjusting for baseline differences between arms, but covariates are unclear. Numerous risk of bias elements NR.
Sorensen, 2005^16-18^ Healthy Directions-Small Business | No | Yes | NR/CND | Yes | No | Yes | Medium | Groups differed at baseline; intervention sites had more women than control sites. “Minimal intervention” control group not well described. Fidelity to intervention is unclear; participation varied by worksite. Attrition is high; authors report conducting ITT analysis using LOCF for missing data for two worksites that dropped out (results not reported separately, do not address missing data for non-responders from other worksites). Analyses adjusted for potential confounding by worksites, occupation, and race/ethnicity.
Sorensen, 2007^19^ Tools for Health | NR/CND | Yes | NR/CND | Yes | Yes | NA | Medium | Groups differed slightly at baseline; intervention group had more participants with post-high school training and higher salary compared with control group. Multiple study design elements (e.g., fidelity, randomization methods, allocation concealment) not well described. Eligible outcomes assessed by self-report (smoking, dietary changes) and subject to recall bias.
Tveito, 2009^20^ Integrated Health Programme | NR/CND | Yes | Yes | Yes | No | NA | High | High attrition (overall and differential) contribute to risk of selection bias. Dropouts were younger and had more sick leave than completers. Baseline groups are not well described (e.g., age, comorbidities, job type). Adherence, intervention fidelity are not reported.
von Thiele Schwarz, 2015^21^ | Yes | NR/CND | NR/CND | Yes | No | No | High | High attrition (>30%), potentially confounding differences between groups not fully addressed or adjusted for in the analysis contributed to bias. Baseline intervention and control groups differed by job type and length of employment onwards. Contamination is also concern; control units had OSH functions integrated into continuous improvement processes during intervention period. Self-rated health outcome does not appear to be externally validated.

CND, cannot determine; ITT, intent-to-treat; LOCF, last observation carried forward; N, number; NA, not applicable; NR, not reported; OSH, occupational safety and health

## References for Appendix C

1 Allen HM Jr., Borden St, Pikelny DB, et al. An intervention to promote appropriate management of allergies in a heavy manufacturing workforce: evaluating health and productivity outcomes. J Occup Environ Med. Sep. 2003;45(9):956-72. [pmid: 14506339].
2 Boggild H, Jeppesen HJ. Intervention in shift scheduling and changes in biomarkers of heart disease in hospital wards. Scand J Work Environ Health. Apr. 2001;27(2):87-96. [pmid: 11409601].
3 Carr LJ, Leonhard C, Tucker S, et al. Total Worker Health Intervention increases activity of sedentary workers. Am J Prev Med. 2015. Jul. 31. [pmid: 26260492].
4 Coffeng JK, Boot CR, Duijts SF, et al. Effectiveness of a worksite social & physical environment intervention on need for recovery, physical activity and relaxation; results of a randomized controlled trial. PLoS One. 2014;9(12):e114860. [pmid: 25542039].
5 Eriksen HR, Ihlebaek C, Mikkelsen A, et al. Improving subjective health at the worksite: a randomized controlled trial of stress management training, physical exercise and an integrated health programme. Occup Med (Lond). Oct. 2002;52(7):383-91. [pmid: 12422025].
6 Hammer LB, Truxillo DM, Bodner T, et al. Effects of a workplace intervention targeting psychosocial risk factors on safety and health outcomes. BioMed Research International. 2015;2015:12.
7 Maes S, Verhoeven C, Kittel F, et al. Effects of a Dutch work-site wellness-health program: the Brabantia Project. Am J Public Health. Jul. 1998;88(7):1037-41. [pmid: 9663150].
8 Okechukwu CA, Krieger N, Sorensen G, et al. MassBuilt: effectiveness of an apprenticeship site-based smoking cessation intervention for unionized building trades workers. Cancer Causes Control. Aug. 2009;20(6):887-94. [pmid: 19301135].
9 Palumbo MV, Wu G, Shaner-McRae H, et al. Tai Chi for older nurses: a workplace wellness pilot study. Appl Nurs Res. Feb. 2012;25(1):54-9. [pmid: 20974089].
10 Sorensen G, Stoddard A, Hunt MK, et al. The effects of a health promotion-health protection intervention on behavior change: the WellWorks Study. Am J Public Health. Nov. 1998;88(11):1685-90. [pmid: 9807537].
11 Sorensen G, Stoddard A, Ockene JK, et al. Worker participation in an integrated health promotion/health protection program: results from the WellWorks project. Health Educ Q. May. 1996;23(2):191-203. [pmid: 8744872].
12 Sorensen G, Himmelstein JS, Hunt MK, et al. A model for worksite cancer prevention: integration of health protection and health promotion in the WellWorks Project. Am J Health Promot. Sep-Oct. 1995;10(1):55-62. [pmid: 10155659].
13 Sorensen G, Stoddard AM, LaMontagne AD, et al. A comprehensive worksite cancer prevention intervention: behavior change results from a randomized controlled trial (United States). J Public Health Policy. 2003;24(1):5-25. [pmid: 12760241].
14 Lamontagne AD, Stoddard AM, Youngstrom RA, et al. Improving the prevention and control of hazardous substance exposures: a randomized controlled trial in manufacturing worksites. Am J Ind Med. Oct. 2005;48(4):282-92. [pmid: 16142731].
15 Hunt MK, Lederman R, Stoddard AM, et al. Process evaluation of an integrated health promotion/occupational health model in WellWorks-2. Health Educ Behav. Feb. 2005;32(1):10-26. [pmid: 15642751].
16 Sorensen G, Barbeau E, Stoddard AM, et al. Promoting behavior change among working-class, multiethnic workers: results of the healthy directions--small business study. Am J Public Health. Aug. 2005;95(8):1389-95. [pmid: 16006422].
17 Hunt MK, Barbeau EM, Lederman R, et al. Process evaluation results from the Healthy Directions-Small Business study. Health Educ Behav. Feb. 2007;34(1):90-107. [pmid: 16740502].
18 Barbeau E, Roelofs C, Youngstrom R, et al. Assessment of occupational safety and health programs in small businesses. Am J Ind Med. Apr. 2004;45(4):371-9. [pmid: 15029570].
19 Sorensen G, Barbeau EM, Stoddard AM, et al. Tools for health: the efficacy of a tailored intervention targeted for construction laborers. Cancer Causes Control. Feb. 2007;18(1):51-9. [pmid: 17186421].
20 Tveito TH, Eriksen HR. Integrated health programme: a workplace randomized controlled trial. J Adv Nurs. Jan. 2009;65(1):110-9. [pmid: 19032505].
21 von Thiele Schwarz U, Augustsson H, Hasson H, et al. Promoting employee health by integrating health protection, health promotion, and continuous improvement: a longitudinal quasi-experimental intervention study. J Occup Environ Med. Feb. 2015;57(2):217-25. [pmid: 25654524].