# Exclusions

X1: | Not original research
X2: | Ineligible population
X3: | Wrong or no intervention
X4: | Wrong or no comparator
X5: | Wrong setting
X6: | Wrong study design
X7: | Non-English
X8: | Ineligible publication type (used specifically for relevant ongoing studies' protocols)

1 Aaras A, Horgen G, Bjorset HH, et al. Musculoskeletal, visual and psychosocial stress in VDU operators before and after multidisciplinary ergonomic interventions. A 6 years prospective study--Part II. Appl Ergon. Dec. 2001;32(6):559-71. Exclusion Code: X3. [pmid: 11703042].
2 Abrams DB, Boutwell WB, Grizzle J, et al. Cancer control at the workplace: the Working Well Trial. Prev Med. Jan. 1994;23(1):15-27. Exclusion Code: X3. [pmid: 8016028].
3 Adera T, Amir C, Anderson L. Use of comparison populations for evaluating the effectiveness of hearing loss prevention programs. AIHAJ. Jan-Feb. 2000;61(1):11-5. Exclusion Code: X3. [pmid: 10772609].
4 Alkhajah TA, Reeves MM, Eakin EG, et al. Sit-stand workstations: a pilot intervention to reduce office sitting time. Am J Prev Med. 2012;43:298-303. Exclusion Code: X3 (gray zone). [pmid: 22898123].
5 Allread WG. Measuring adjustability's benefits. Occup Health Saf. Apr. 2004;73(4):54-61. 84. Exclusion Code: X3. [pmid: 15141537].
6 Anderson MA, Stoltzfus JA. The 3M corporate experience: health as a business strategy. Am J Health Promot. May-Jun. 2001;15(5):371-3. Exclusion Code: X1. [pmid: 11502025].
7 Anger WK, Elliot DL, Bodner T, et al. Effectiveness of Total Worker Health interventions. J Occup Health Psychol. 2015;20(2):226-47. Exclusion Code: X1. [pmid: 25528687].
8 Apfelbacher CJ, Soder S, Diepgen TL, et al. The impact of measures for secondary individual prevention of work-related skin diseases in health care workers: 1-year follow-up study. Contact Dermatitis. Mar. 2009;60(3):144-9. Exclusion Code: X3. [pmid: 19260911].
9 Ariyoshi H, Suzaki Y, Takayama N, et al. A health promotion program at a Japanese newspaper undergoing restructuring. AAOHN J. Sep. 2010;58(9):383-7. Exclusion Code: X3. [pmid: 20795580].
10 Arneson H, Ekberg K. Evaluation of empowerment processes in a workplace health promotion intervention based on learning in Sweden. Health Promot Int. Dec. 2005;20(4):351-9. Exclusion Code: X3. [pmid: 16169884].
11 Aust B, Ducki A. Comprehensive health promotion interventions at the workplace: experiences with health circles in Germany. J Occup Health Psychol. Jul. 2004;9(3):258-70. Exclusion Code: X6. [pmid: 15279520].
12 Azizi E, Flint P, Sadetzki S, et al. A graded work site intervention program to improve sun protection and skin cancer awareness in outdoor workers in Israel. Cancer Causes Control. 2000:513-21. Exclusion Code: X3. [pmid: 10880033].
13 Backman D, Gonzaga G, Sugerman S, et al. Effect of fresh fruit availability at worksites on the fruit and vegetable consumption of low-wage employees. J Nutr Educ Behav. Jul-Aug. 2011;43(4 Suppl 2):S113-21. Exclusion Code: X3. [pmid: 21683280].
14 Badii M, Keen D, Yu S, et al. Evaluation of a comprehensive integrated workplace-based program to reduce occupational musculoskeletal injury and its associated morbidity in a large hospital. J Occup Environ Med. Nov. 2006;48(11):1159-65. Exclusion Code: X3. [pmid: 17099452].
15 Baker E, Israel BA, Schurman S. The integrated model: Implications for worksite health promotion and occupational health and safety practice. Health Educ Q. 1996;23(2):175-90. Exclusion Code: X1. [pmid: 8744871].
16 Barbeau EM, McLellan D, Levenstein C, et al. Reducing occupation-based disparities related to tobacco: roles for occupational health and organized labor. Am J Ind Med. Aug. 2004;46(2):170-9. Exclusion Code: X1. [pmid: 15273970].
17 Bennett JB, Patterson CR, Reynolds GS, et al. Team awareness, problem drinking, and drinking climate: workplace social health promotion in a policy context. Am J Health Promot. Nov-Dec. 2004;19(2):103-13. Exclusion Code: X3. [pmid: 15559710].
18 Beresford SA, Bishop SK, Brunner NL, et al. Environmental assessment at worksites after a multilevel intervention to promote activity and changes in eating: the PACE project. J Occup Environ Med. Jan. Suppl 1. 2010;52:S22-8. Exclusion Code: X3. [pmid: 20061883].
19 Bergstrom G, Bjorklund C, Fried I, et al. A comprehensive workplace intervention and its outcome with regard to lifestyle, health and sick leave: the AHA study. Work. 2008;31(2):167-80. Exclusion Code: X3 (gray zone). [pmid: 18957735].
20 Bertera RL. The effects of workplace health promotion on absenteeism and employment costs in a large industrial population. Am J Public Health. Sep. 1990;80(9):1101-5. Exclusion Code: X3 (gray zone). [pmid: 2382748].
21 Bertera RL. Behavioral risk factor and illness day changes with workplace health promotion: two-year results. Am J Health Promot. May-Jun. 1993;7(5):365-73. Exclusion Code: X3 (gray zone). [pmid: 10148712].
22 Bittman B, Bruhn KT, Stevens C, et al. Recreational music-making: a cost-effective group interdisciplinary strategy for reducing burnout and improving mood states in long-term care workers. Adv Mind Body Med. Fall-Winter. 2003;19(3-4):4-15. Exclusion Code: X3. [pmid: 14686266].
23 Blasche G, Pfeffer M, Thaler H, et al. Work-site health promotion of frequent computer users: comparing selected interventions. Work. Jan. 1. 2013;46(3):233-41. Exclusion Code: X3. [pmid: 23324690].
24 Borland RM, Hocking B, Godkin GA, et al. The impact of a skin cancer control education package for outdoor workers. Med J Aust. May. 20. 1991;154(10):686-8. Exclusion Code: X3. [pmid: 2034151].
25 Borstad JD, Buetow B, Deppe E, et al. A longitudinal analysis of the effects of a preventive exercise programme on the factors that predict shoulder pain in construction apprentices. Ergonomics. Feb. 2009;52(2):232-44. Exclusion Code: X3. [pmid: 19296319].
26 Bourbonnais R, Brisson C, Vinet A, et al. Effectiveness of a participative intervention on psychosocial work factors to prevent mental health problems in a hospital setting. Occup Environ Med. May. 2006;63(5):335-42. Exclusion Code: X3. [pmid: 16621854].
27 Bourbonnais R, Brisson C, Vinet A, et al. Development and implementation of a participative intervention to improve the psychosocial work environment and mental health in an acute care hospital. Occup Environ Med. May. 2006;63(5):326-34. Exclusion Code: X3. [pmid: 16621853].
28 Bourgeois FT, Simons WW, Olson K, et al. Evaluation of influenza prevention in the workplace using a personally controlled health record: randomized controlled trial. J Med Internet Res. 2008;10(1):e5. Exclusion Code: X3 (gray zone). [pmid: 18343794].
29 Brooks L, Merkel SF, Glowatz M Jr., et al. A comprehensive reproductive health program in the workplace. Am Ind Hyg Assoc J. Apr. 1994;55(4):352-7. Exclusion Code: X1. [pmid: 8209841].
30 Brunges M, Avigne G, Wasik M. Health promotion in the operating room--a quality improvement project. AORN J. Jan. 2006;83(1):171-2. 5. 7. Exclusion Code: X3. [pmid: 16528906].
31 Budden JS, Sagarin BJ. Implementation intentions, occupational stress, and the exercise intention-behavior relationship. J Occup Health Psychol. Oct. 2007;12(4):391-401. Exclusion Code: X3. [pmid: 17953497].
32 Buller DB, Andersen PA, Walkosz BJ, et al. Enhancing industry-based dissemination of an occupational sun protection program with theory-based strategies employing personal contact. Am J Health Promot. Jul-Aug. 2012;26(6):356-65. Exclusion Code: X3. [pmid: 22747318].
33 Buller DB, Andersen PA, Walkosz BJ, et al. Randomized trial testing a worksite sun protection program in an outdoor recreation industry. Health Educ Behav. Aug. 2005;32(4):514-35. Exclusion Code: X3. [pmid: 16009748].
34 Butterworth S, Linden A, McClay W, et al. Effect of motivational interviewing-based health coaching on employees' physical and mental health status. J Occup Health Psychol. Oct. 2006;11(4):358-65. Exclusion Code: X3. [pmid: 17059299].
35 Cahill K, Lancaster T. Workplace interventions for smoking cessation. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2014. Exclusion Code: X1.
36 Carlson E, Murphy M. Impacting health through on-the-job counseling: role for professional nurses. Medsurg Nurs. Sep-Oct. 2010;19(5):295-9. Exclusion Code: X3. [pmid: 21189743].
37 Chapman LJ, Newenhouse AC, Meyer RH, et al. Evaluation of an intervention to reduce musculoskeletal hazards among fresh market vegetable growers. Appl Ergon. Jan. 2004;35(1):57-66. Exclusion Code: X3. [pmid: 14985141].
38 Charbonneau A, Bruning W, Titus-Howard T, et al. The community initiative on depression: report from a multiphase work site depression intervention. J Occup Environ Med. Jan. 2005;47(1):60-7. Exclusion Code: X6. [pmid: 15643160].
39 Chatterjee DS. A multicentre health promotion programme for coronary heart disease. Occup Health (Lond). Jan. 1997;49(1):12-5. Exclusion Code: X3. [pmid: 9283463].
40 Chau JY, Daley M, Dunn S, et al. The effectiveness of sit-stand workstations for changing office workers' sitting time: results from the Stand@Work randomized controlled trial pilot. Int J Behav Nutr Phys Act. 2014;11:127. Exclusion Code: X3. [pmid: 25291960].
41 Cheatham D, Shaver E, Wogalter M. Developing effective warnings for the workplace. Occup Health Saf. Jun. 2003;72(6):28-30. 2. 148. Exclusion Code: X1. [pmid: 12813935].
42 Chen J, Wu X, Gu D. Hypertension and cardiovascular diseases intervention in the capital steel and iron company and Beijing Fangshan community. Obes Rev. Mar. 9 Suppl 1. 2008:142-5. Exclusion Code: X3. [pmid: 18307717].
43 Chenoweth D. Work-site health promotion programs need analysis of cost-effectiveness. Occup Health Saf. Apr. 1990;59(4):25. 95. Exclusion Code: X1. [pmid: 2110641].
44 Christensen JR, Faber A, Ekner D, et al. Diet, physical exercise and cognitive behavioral training as a combined workplace based intervention to reduce body weight and increase physical capacity in health care workers - a randomized controlled trial. BMC Public Health. 2011;11:671. Exclusion Code: X3. [pmid: 21871113].
45 Clark MM, Soyring JE, Jenkins SM, et al. The integration of studio cycling into a worksite stress management programme. Stress Health. Apr. 2014;30(2):166-76. Exclusion Code: X3. [pmid: 23897838].
46 Cohen-Katz J, Wiley SD, Capuano T, et al. The effects of mindfulness-based stress reduction on nurse stress and burnout, Part II: A quantitative and qualitative study. Holist Nurs Pract. Jan-Feb. 2005;19(1):26-35. Exclusion Code: X3. [pmid: 15736727].
47 Community Preventive Services Task Force. Recommendations for worksite-based interventions to improve workers' health. Am J Prev Med. Feb. 2010;38(2S):S232-6. Exclusion Code: X1. [pmid: 20117609].
48 Cooley D, Pedersen S. A pilot study of increasing nonpurposeful movement breaks at work as a means of reducing prolonged sitting. J Environ Public Health. 2013;2013:128376. Exclusion Code: X3. [pmid: 23690798].
49 Creaser W. Prevention through Design (PtD) safe design from an Australian perspective. J Safety Res. 2008;39(2):131-4. Exclusion Code: X1. [pmid: 18454953].
50 Dalton BA, Harris JS. A comprehensive approach to corporate health management. J Occup Med. Mar. 1991;33(3):338-47. Exclusion Code: X3. [pmid: 1903156].
51 Dawley HH Jr., Dawley LT, Correa P, et al. A comprehensive worksite smoking control, discouragement, and cessation program. Int J Addict. Jun. 1991;26(6):685-96. Exclusion Code: X3. [pmid: 1757172].
52 Deitz D, Cook R, Hersch R. Workplace health promotion and utilization of health services: follow-up data findings. J Behav Health Serv Res. Jul-Sep. 2005;32(3):306-19. Exclusion Code: X3. [pmid: 16010186].
53 Deitz D, Cook RF, Hersch RK, et al. Heart healthy online: an innovative approach to risk reduction in the workplace. J Occup Environ Med. May. 2014;56(5):547-53. Exclusion Code: X3. [pmid: 24806568].
54 DeJoy DM, Wilson MG, Padilla HM, et al. Process evaluation results from an environmentally focused worksite weight management study. Health Educ Behav. Aug. 2012;39(4):405-18. Exclusion Code: X3. [pmid: 22002249].
55 Dellve L, Skagert K, Vilhelmsson R. Leadership in workplace health promotion projects: 1- and 2-year effects on long-term work attendance. Eur J Public Health. Oct. 2007;17(5):471-6. Exclusion Code: X3. [pmid: 17307747].
56 Devine CM, Maley M, Farrell TJ, et al. Process evaluation of an environmental walking and healthy eating pilot in small rural worksites. Eval Program Plann. Feb. 2012;35(1):88-96. Exclusion Code: X3. [pmid: 22054528].
57 Dey P, Halder S, Collins S, et al. Promoting uptake of influenza vaccination among health care workers: a randomized controlled trial. J Public Health Med. Dec. 2001;23(4):346-8. Exclusion Code: X3. [pmid: 11873900].
58 Dinesh J. Modifying the Workplace to Decrease Sedentary Behavior and Improve Health. Northeastern University. Boston, Massachusetts. ClinicalTrials.gov. March. 25. 2015. 2015. Exclusion Code: X8.
59 Donham KJ, Kline AK, Kelly KM, et al. Respirator and hearing protection use in the certified safe farm program. J Agromedicine. 2013;18(1):18-26. Exclusion Code: X3. [pmid: 23301887].
60 Dunstan DW, Wiesner G, Eakin EG, et al. Reducing office workers' sitting time: rationale and study design for the Stand Up Victoria cluster randomized trial. BMC Public Health. 2013;13:1057. Exclusion Code: X6. [pmid: 24209423].
61 Dutra LM, Kim SS, Williams DR, et al. Worksite safety climate, smoking, and the use of protective equipment by blue-collar building workers enrolled in the MassBUILT smoking cessation trial. J Occup Environ Med. Oct. 2014;56(10):1082-7. Exclusion Code: X6. [pmid: 25285831].
62 Edington M, Karjalainen T, Hirschland D, et al. The UAW-GM health promotion program. Successful outcomes. AAOHN J. Jan. 2002;50(1):26-31. Exclusion Code: X3. [pmid: 11842778].
63 Edmunds S, Stephenson D, Clow A. The effects of a physical activity intervention on employees in small and medium enterprises: a mixed methods study. Work. Jan. 1. 2013;46(1):39-49. Exclusion Code: X3. [pmid: 23241703].
64 Elliot D, Garg B, Kuehl K, et al. Why Are Women Law Enforcement Officers More Burned-Out and What Might Help Them?. Occup Med Health Aff. 2015;3(204):1-4. Exclusion Code: X3.
65 Elliot DL, Mackinnon DP, Mabry L, et al. Worksite wellness program implementation: a model of translational effectiveness. Transl Behav Med. Jun. 2012;2(2):228-35. Exclusion Code: X3. [pmid: 24073114].
66 Esposito NW, Redman RW, Moore KA, et al. Preventing violence in an academic setting: one school of nursing's approach. Nurs Educ Perspect. Jan-Feb. 2005;26(1):24-8. Exclusion Code: X3. [pmid: 15816256].
67 Fanello S, Jousset N, Roquelaure Y, et al. Evaluation of a training program for the prevention of lower back pain among hospital employees. Nurs Health Sci. Mar-Jun. 2002;4(1-2):51-4. Exclusion Code: X3. [pmid: 12084021].
68 Figl-Hertlein A, Horsak B, Dean E, et al. A physiotherapy-directed occupational health programme for Austrian school teachers: a cluster randomised pilot study. Physiotherapy. Mar. 2014;100(1):20-6. Exclusion Code: X3. [pmid: 23835185].
69 Flannery K, Resnick B, McMullen TL. The impact of the Worksite Heart Health Improvement Project on work ability: a pilot study. J Occup Environ Med. Nov. 2012;54(11):1406-12. Exclusion Code: X3. [pmid: 23135301].
70 Flaxman PE, Bond FW. Worksite stress management training: moderated effects and clinical significance. J Occup Health Psychol. Oct. 2010;15(4):347-58. Exclusion Code: X3. [pmid: 21058850].
71 Fouad MN, Kiefe CI, Bartolucci AA, et al. A hypertension control program tailored to unskilled and minority workers. Ethn Dis. Autumn. 1997;7(3):191-9. Exclusion Code: X3. [pmid: 9467701].
72 Frank AJ. Fatigue management. Emerg Med Serv. Feb. 2004;33(2):84-6. Exclusion Code: X1. [pmid: 14994680].
73 Freak-Poli R, Wolfe R, Brand M, et al. Eight-month postprogram completion: change in risk factors for chronic disease amongst participants in a 4-month pedometer-based workplace health program. Obesity (Silver Spring). Sep. 2013;21(9):E360-8. Exclusion Code: X3. [pmid: 23408732].
74 Frederic M, Ozguler A, Baer M, et al. Is the workplace a safer place to have a stroke?. J Occup Environ Med. Feb. 2014;56(2):127-8. Exclusion Code: X3. [pmid: 24504248].
75 Gates DM, Brehm BJ. Challenges of a worksite health promotion project. AAOHN J. Mar. 2010;58(3):117-22. Exclusion Code: X3. [pmid: 20210262].
76 Gingerich SB, Anderson DR, Koland H. Impact of financial incentives on behavior change program participation and risk reduction in worksite health promotion. Am J Health Promot. Nov-Dec. 2012;27(2):119-22. Exclusion Code: X3. [pmid: 23113782].
77 Girgis A, Sanson-Fisher RW, Watson A. A workplace intervention for increasing outdoor workers' use of solar protection. Am J Public Health. Jan. 1994;84(1):77-81. Exclusion Code: X3. [pmid: 8279616].
78 Glasgow RE, Terborg JR, Hollis JF, et al. Take heart: results from the initial phase of a work-site wellness program. Am J Public Health. Feb. 1995;85(2):209-16. Exclusion Code: X3. [pmid: 7856780].
79 Godard C, Chevalier A, Lecrubier Y, et al. APRAND programme: an intervention to prevent relapses of anxiety and depressive disorders. First results of a medical health promotion intervention in a population of employees. Eur Psychiatry. Oct. 2006;21(7):451-9. Exclusion Code: X3. [pmid: 16675204].
80 Goetzel RZ, Ozminkowski RJ, Bruno JA, et al. The long-term impact of Johnson &amp; Johnson's Health &amp; Wellness Program on employee health risks. J Occup Environ Med. May. 2002;44(5):417-24. Exclusion Code: X6. [pmid: 12024687].
81 Goetzel RZ, Roemer EC, Short ME, et al. Health improvement from a worksite health promotion private-public partnership. J Occup Environ Med. Mar. 2009;51(3):296-304. Exclusion Code: X3. [pmid: 19225415].
82 Golaszewski T, Barr D, Cochran S. An organization-based intervention to improve support for employee heart health. Am J Health Promot. Sep-Oct. 1998;13(1):26-35. Exclusion Code: X3. [pmid: 10186932].
83 Granacher U, Wick C, Rueck N, et al. Promoting balance and strength in the middle-aged workforce. Int J Sports Med. Jan. 2011;32(1):35-44. Exclusion Code: X3. [pmid: 21072736].
84 Grayson D, Dale AM, Bohr P, et al. Ergonomic evaluation: part of a treatment protocol for musculoskeletal injuries. AAOHN J. Oct. 2005;53(10):450-7. quiz 8-9. Exclusion Code: X3. [pmid: 16255528].
85 Guidotti TL, Deb P, Bertera R, et al. The Fort McMurray Demonstration Project in Social Marketing: no demonstrable effect on already falling injury rates following intensive community and workplace intervention. J Community Health. Oct. 2009;34(5):392-9. Exclusion Code: X5. [pmid: 19521753].
86 Guise JM, Chang C, Viswanathan M, et al. Systematic Reviews of Complex Multicomponent Health Care Interventions. Research White Paper. AHRQ Publication No.14-EHC003-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2014. www.effectivehealthcare.ahrq.gov/reports/final.cfm. Exclusion Code: X1.
87 Hall J, Mansfield L, Kay T, et al. The effect of a sit-stand workstation intervention on daily sitting, standing and physical activity: protocol for a 12 month workplace randomised control trial. BMC Public Health. 2015;15:152. Exclusion Code: X3 (gray zone). [pmid: 25879905].
88 Harvey L, Fowles JB, Xi M, et al. When activation changes, what else changes? the relationship between change in patient activation measure (PAM) and employees' health status and health behaviors. Patient Educ Couns. Aug. 2012;88(2):338-43. Exclusion Code: X3. [pmid: 22459636].
89 Hasson D, Anderberg UM, Theorell T, et al. Psychophysiological effects of a web-based stress management system: a prospective, randomized controlled intervention study of IT and media workers [ISRCTN54254861]. BMC Public Health. 2005;5:78. Exclusion Code: X3 (gray zone). [pmid: 16042796].
90 Hasson H, Brown C, Hasson D. Factors associated with high use of a workplace web-based stress management program in a randomized controlled intervention study. Health Educ Res. Aug. 2010;25(4):596-607. Exclusion Code: X3. [pmid: 20150531].
91 Hasson H, Gilbert-Ouimet M, Baril-Gingras G, et al. Implementation of an organizational-level intervention on the psychosocial environment of work: comparison of managers' and employees' views. J Occup Environ Med. Jan. 2012;54(1):85-91. Exclusion Code: X3. [pmid: 22193115].
92 Hayes Sara L, Mann Mala K, Morgan Fiona M, et al. Collaboration between local health and local government agencies for health improvement. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2012. Exclusion Code: X1.
93 Helitzer DL, Hathorn G, Benally J, et al. Culturally relevant model program to prevent and reduce agricultural injuries. J Agric Saf Health. Jul. 2014;20(3):175-98. Exclusion Code: X3. [pmid: 25174150].
94 Hemphala H, Eklund J. A visual ergonomics intervention in mail sorting facilities: effects on eyes, muscles and productivity. Appl Ergon. Jan. 2012;43(1):217-29. Exclusion Code: X3. [pmid: 21726852].
95 Henning R, Nobrega S, Flum M, et al. Engaging workers in health promotion and health protection efforts: A participatory approach for innovation and sustainability at two worksites. Lapointe P, Pelletier J, Vaudreuil F, editors. Different perspectives on work changes: papers from the Second International Workshop on Work and Intervention Practices, Québec, August 27, 28, 29 2008. Québec. PUL, Presse de l'Université Laval. 2009:199-208. Exclusion Code: X6.
96 Hirai T, Kusaka Y, Suganuma N, et al. Work form affects maximum oxygen uptake for one year in workers. Ind Health. 2011;49(3):321-7. Exclusion Code: X3. [pmid: 21273736].
97 Hnizdo E, Berry A, Hakobyan A, et al. Worksite wellness program for respiratory disease prevention in heavy-construction workers. J Occup Environ Med. Mar. 2011;53(3):274-81. Exclusion Code: X6. [pmid: 21386692].
98 Hogg-Johnson S, Robson L, Cole DC, et al. A randomised controlled study to evaluate the effectiveness of targeted occupational health and safety consultation or inspection in Ontario manufacturing workplaces. Occup Environ Med. Dec. 2012;69(12):890-900. Exclusion Code: X3. [pmid: 22918898].
99 Hoving Jan L, Lacaille D, Urquhart Donna M, et al. Non-pharmacological interventions for preventing job loss in workers with inflammatory arthritis. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2014. Exclusion Code: X1.
100 Howard J. Prevention through Design--introduction. J Safety Res. 2008;39(2):113. Exclusion Code: X1. [pmid: 18454949].
101 Hunt MK, Lederman R, Stoddard A, et al. Process tracking results from the Treatwell 5-a-Day Worksite Study. Am J Health Promot. Jan-Feb. 2000;14(3):179-87. Exclusion Code: X3. [pmid: 10787771].
102 Hwang GS, Jung HS, Yi Y, et al. Smoking cessation intervention using stepwise exercise incentives for male workers in the workplace. Asia Pac J Public Health. Jan. 2012;24(1):82-90. Exclusion Code: X3. [pmid: 21159694].
103 Hymel PA, Loeppke RR, Baase CM, et al. Workplace health protection and promotion: a new pathway for a healthier--and safer--workforce. J Occup Environ Med. Jun. 2011;53(6):695-702. Exclusion Code: X1. [pmid: 21654443].
104 Ikegami K, Tahara H, Yamada T, et al. Effects of a mental health training program for manufacturing company managers. J UOEH. Jun. 1. 2010;32(2):141-53. Exclusion Code: X3. [pmid: 20549903].
105 Isaac F, Flynn P. Johnson & Johnson LIVE FOR LIFE Program: now and then. Am J Health Promot. May-Jun. 2001;15(5):365-7. Exclusion Code: X1. [pmid: 11502022].
106 Israel BA, Schurman SJ, House JS. Action research on occupational stress: involving workers as researchers. Int J Health Serv. 1989;19(1):135-55. Exclusion Code: X3. [pmid: 2925298].
107 Jackson J, Kohn-Parrott KA, Parker C, et al. Blood Pressure Success Zone: You Auto Know. A worksite-based program to improve blood pressure control among auto workers. Popul Health Manag. Oct. 2011;14(5):257-63. Exclusion Code: X3. [pmid: 21988347].
108 Janer G, Sala M, Kogevinas M. Health promotion trials at worksites and risk factors for cancer. Scand J Work Environ Health. Jun. 2002;28(3):141-57. Exclusion Code: X3. [pmid: 12109553].
109 Jeffery RW, Forster JL, French SA, et al. The Healthy Worker Project: a work-site intervention for weight control and smoking cessation. Am J Public Health. Mar. 1993;83(3):395-401. Exclusion Code: X3. [pmid: 8438979].
110 Jeffery RW, Kelder SH, Forster JL, et al. Restrictive smoking policies in the workplace: effects on smoking prevalence and cigarette consumption. Prev Med. Jan. 1994;23(1):78-82. Exclusion Code: X3. [pmid: 8016037].
111 Jeffrey RW, Forster JL, Baxter JE, et al. An empirical evaluation of the effectiveness of tangible incentives in increasing participation and behavior change in a worksite health promotion program. Am J Health Promot. Nov-Dec. 1993;8(2):98-100. Exclusion Code: X3. [pmid: 10146823].
112 Jeon YH, Simpson JM, Chenoweth L, et al. The effectiveness of an aged care specific leadership and management program on workforce, work environment, and care quality outcomes: design of a cluster randomised controlled trial. Implement Sci. 2013;8:126. Exclusion Code: X3. [pmid: 24160714].
113 Jonas DE, Cusack K, Forneris CA, et al. Psychological and Pharmacological Treatments for Adults With Posttraumatic Stress Disorder (PTSD). (Prepared by the RTI International-University of North Carolina Evidence-based Practice Center under Contract No. 290-2007-10056-I.). AHRQ Publication No. 13-EHC011-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2013. Exclusion Code: X1.
114 Jorgensen MB, Rasmussen CD, Ekner D, et al. Successful reach and adoption of a workplace health promotion RCT targeting a group of high-risk workers. BMC Med Res Methodol. 2010;10:56. Exclusion Code: X3. [pmid: 20546592].
115 Jung AP, Dale RB, Bishop PA. Ambient-temperature beverages are consumed at a rate similar to chilled water in heat-exposed workers. J Occup Environ Hyg. Jan. 2007;4(1):54-7. Exclusion Code: X3. [pmid: 17162481].
116 Kagan NI, Kagan H, Watson MG. Stress reduction in the workplace: The effectiveness of psychoeducational programs. J Couns Psychol. 1995;42(1):71-8. Exclusion Code: X3.
117 Karjalainen K, Malmivaara A, Mutanen P, et al. Mini-intervention for subacute low back pain: two-year follow-up and modifiers of effectiveness. Spine (Phila Pa 1976). May. 15. 2004;29(10):1069-76. Exclusion Code: X3. [pmid: 15131431].
118 Karlqvist L, Gard G. Health-promoting educational interventions: a one-year follow-up study. Scand J Public Health. Feb. 2013;41(1):32-42. Exclusion Code: X3. [pmid: 23221375].
119 Kerin A, Aguirre A. Improving health, safety, and profits in extended hours operations (shiftwork). Ind Health. Jan. 2005;43(1):201-8. Exclusion Code: X3. [pmid: 15732324].
120 Kines P, Andersen D, Andersen LP, et al. Improving safety in small enterprises through an integrated safety management intervention. J Safety Res. Feb. 2013;44:87-95. Exclusion Code: X3. [pmid: 23398709].
121 Klumb M, Morgan R. Case study: workstations. Workforce empowerment. Occup Health Saf. Sep. 2002;71(9):168-71. Exclusion Code: X1. [pmid: 12369358].
122 Kobayashi Y, Kaneyoshi A, Yokota A, et al. Effects of a worker participatory program for improving work environments on job stressors and mental health among workers: a controlled trial. J Occup Health. 2008;50(6):455-70. Exclusion Code: X3. [pmid: 19023175].
123 Koplin AN, Davidow B, Backman P, et al. The combined employee health risk--occupational hazard appraisal: the New York City experience. J Public Health Policy. Spring. 1988;9(1):42-55. Exclusion Code: X6. [pmid: 3360914].
124 Krcmar S. Preventing injuries. Rehab Manag. Mar. 2006;19(2):22. 4. 6 passim. Exclusion Code: X1. [pmid: 16538959].
125 Kristal AR, Patterson RE, Glanz K, et al. Psychosocial correlates of healthful diets: baseline results from the Working Well Study. Prev Med. May. 1995;24(3):221-8. Exclusion Code: X3. [pmid: 7644443].
126 Kristensen TS. Workplace intervention studies. Occup Med. Jan-Mar. 293. 2000;15:1-305. Exclusion Code: X1. [pmid: 10620785].
127 Kuehl KS, Elliot DL, Goldberg L, et al. The safety and health improvement: enhancing law enforcement departments study: feasibility and findings. Front Public Health. 2014;2:38. Exclusion Code: X3. [pmid: 24847475].
128 Kuehl KS, Elliot DL, Goldberg L, et al. Economic benefit of the PHLAME wellness programme on firefighter injury. Occup Med (Lond). Apr. 2013;63(3):203-9. Exclusion Code: X6. [pmid: 23416849].
129 Kwak L, Kremers SP, Visscher TL, et al. Behavioral and cognitive effects of a worksite-based weight gain prevention program: the NHF-NRG in balance-project. J Occup Environ Med. Dec. 2009;51(12):1437-46. Exclusion Code: X3. [pmid: 19952793].
130 Laestadius JG, Ye J, Cai X, et al. The proactive approach--is it worthwhile? A prospective controlled ergonomic intervention study in office workers. J Occup Environ Med. Oct. 2009;51(10):1116-24. Exclusion Code: X3. [pmid: 19786895].
131 Larsson A, Karlqvist L, Gard G. Effects of work ability and health promoting interventions for women with musculoskeletal symptoms: a 9-month prospective study. BMC Musculoskelet Disord. 2008;9:105. Exclusion Code: X3. [pmid: 18644154].
132 Larsson J, Landstad BJ, Wiklund H, et al. Control charts as an early-warning system for workplace health outcomes. Work. 2011;39(4):409-25. Exclusion Code: X3. [pmid: 21811031].
133 Lavoie-Tremblay M, Bourbonnais R, Viens C, et al. Improving the psychosocial work environment. J Adv Nurs. Mar. 2005;49(6):655-64. Exclusion Code: X3. [pmid: 15737225].
134 LeCheminant JD, Merrill RM. Improved health behaviors persist over two years for employees in a worksite wellness program. Popul Health Manag. Oct. 2012;15(5):261-6. Exclusion Code: X3. [pmid: 22823340].
135 Lee C, Duffy SA, Louzon SA, et al. The impact of Sun Solutions educational interventions on select health belief model constructs. Workplace Health Saf. Feb. 2014;62(2):70-9. Exclusion Code: X3 (gray zone). [pmid: 24812691].
136 Licata M, Gillham K, Campbell E. Health promotion practices of restaurants and cafes in Australia: changes from 1997 to 2000 using an annual telemarketing intervention. Health Promot Int. Sep. 2002;17(3):255-62. Exclusion Code: X6. [pmid: 12147640].
137 Linde JA, Nygaard KE, MacLehose RF, et al. HealthWorks: results of a multi-component group-randomized worksite environmental intervention trial for weight gain prevention. Int J Behav Nutr Phys Act. 2012;9:14. Exclusion Code: X3. [pmid: 22340088].
138 Linden TC, Jackson C, Rutledge S, et al. The Heart of Grinnell: A Community-Wide Rural Health Wellness Initiative: a pilot observational study and a prospective study design. Altern Ther Health Med. Jul-Aug. 2010;16(4):46-9. Exclusion Code: X2. [pmid: 20653295].
139 Lipscomb HJ. Effectiveness of interventions to prevent work-related eye injuries. Am J Prev Med. May. 2000;18(4 Suppl):27-32. Exclusion Code: X3. [pmid: 10793278].
140 Loeppke R, Nicholson S, Taitel M, et al. The impact of an integrated population health enhancement and disease management program on employee health risk, health conditions, and productivity. Popul Health Manag. Dec. 2008;11(6):287-96. Exclusion Code: X3. [pmid: 19108644].
141 Long DA, Sheehan P. A case study of population health improvement at a Midwest regional hospital employer. Popul Health Manag. Jun. 2010;13(3):163-73. Exclusion Code: X3. [pmid: 20521905].
142 Loughlin C, Mercer D. Designing healthy workplaces. Day A, Kelloway EK, Hurrell JJ Jr., editors. Workplace well-being: How to build psychologically healthy workplaces. Wiley-Blackwell. 2014:299-323. Exclusion Code: X1.
143 Lu C, Schultz AB, Sill S, et al. Effects of an incentive-based online physical activity intervention on health care costs. J Occup Environ Med. Nov. 2008;50(11):1209-15. Exclusion Code: X3. [pmid: 19001947].
144 Mackenzie CS, Poulin PA, Seidman-Carlson R. A brief mindfulness-based stress reduction intervention for nurses and nurse aides. Appl Nurs Res. May. 2006;19(2):105-9. Exclusion Code: X3. [pmid: 16728295].
145 Mann JA 3rd. Education issues in Prevention through Design. J Safety Res. 2008;39(2):165-70. Exclusion Code: X1. [pmid: 18454962].
146 Martin A, Sanderson K, Scott J, et al. Promoting mental health in small-medium enterprises: an evaluation of the “Business in Mind” program. BMC Public Health. 2009;9:239. Exclusion Code: X3. [pmid: 19604351].
147 Martin P, Higton P, Scholefield H. Close encounters. Nurs Manag (Harrow). Jul. 2005;12(4):15-8. Exclusion Code: X3. [pmid: 16044861].
148 Martinson BC, Murray DM, Jeffery RW, et al. Intraclass correlation for measures from a worksite health promotion study: estimates, correlates, and applications. Am J Health Promot. Jul-Aug. 1999;13(6):347-57. Exclusion Code: X3. [pmid: 10557507].
149 Masur-Levy P, Tavris DR, Elsey-Pica L. Cardiovascular risk changes in a work-site health promotion program. J Am Diet Assoc. Oct. 1990;90(10):1427-8. Exclusion Code: X3. [pmid: 2212427].
150 Matterne U, Diepgen TL, Weisshaar E. Effects of a health-educational and psychological intervention on socio-cognitive determinants of skin protection behaviour in individuals with occupational dermatoses. Int Arch Occup Environ Health. Feb. 2010;83(2):183-9. Exclusion Code: X3. [pmid: 19641933].
151 Mauceri E, Bienkowski C, Hanson KA, et al. A health outcome assessment of the Cardio Metabolic Mission Health Program at Novartis. J Occup Environ Med. Jun. 2011;53(6):647-52. Exclusion Code: X3. [pmid: 21654435].
152 May DR, Reed K, Schwoerer CE, et al. Ergonomic office design and aging: a quasi-experimental field study of employee reactions to an ergonomics intervention program. J Occup Health Psychol. Apr. 2004;9(2):123-35. Exclusion Code: X3. [pmid: 15053712].
153 Mayer AS, Brazile WJ, Erb SA, et al. Developing effective health and safety training materials for workers in beryllium-using industries. J Occup Environ Med. Jul. 2013;55(7):746-51. Exclusion Code: X3. [pmid: 23787563].
154 Mayer JA, Slymen DJ, Clapp EJ, et al. Promoting sun safety among US Postal Service letter carriers: impact of a 2-year intervention. Am J Public Health. Mar. 2007;97(3):559-65. Exclusion Code: X3. [pmid: 17267715].
155 Menendez CC, Amick BC 3rd, Robertson M, et al. A replicated field intervention study evaluating the impact of a highly adjustable chair and office ergonomics training on visual symptoms. Appl Ergon. Jul. 2012;43(4):639-44. Exclusion Code: X3. [pmid: 22030069].
156 Merrill RM, Aldana SG, Garrett J, et al. Effectiveness of a workplace wellness program for maintaining health and promoting healthy behaviors. J Occup Environ Med. Jul. 2011;53(7):782-7. Exclusion Code: X3. [pmid: 21670705].
157 Merrill RM, Hull JD. Factors associated with participation in and benefits of a worksite wellness program. Popul Health Manag. Aug. 2013;16(4):221-6. Exclusion Code: X6. [pmid: 23405876].
158 Michie S, Williams S. Reducing work related psychological ill health and sickness absence: a systematic literature review. Occup Environ Med. Jan. 2003;60(1):3-9. Exclusion Code: X3. [pmid: 12499449].
159 Miller TR, Zaloshnja E, Spicer RS. Effectiveness and benefit-cost of peer-based workplace substance abuse prevention coupled with random testing. Accid Anal Prev. May. 2007;39(3):565-73. Exclusion Code: X3. [pmid: 17125723].
160 Moen P, Kelly EL, Tranby E, et al. Changing work, changing health: can real work-time flexibility promote health behaviors and well-being?. J Health Soc Behav. Dec. 2011;52(4):404-29. Exclusion Code: X3. [pmid: 22144731].
161 Morgan PJ, Collins CE, Plotnikoff RC, et al. The impact of a workplace-based weight loss program on work-related outcomes in overweight male shift workers. J Occup Environ Med. Feb. 2012;54(2):122-7. Exclusion Code: X3. [pmid: 22269987].
162 National Institute for Occupational Safety and Health (NIOSH). NIOSH Published Papers on Benefits of Health Programs. Prof Saf. 2012;57(8):22. Exclusion Code: X1.
163 National Institute for Occupational Safety and Health (NIOSH). NIOSH Offers Guidelines for Implementing Total Worker Health Programs. Prof Saf. 2014;59(1):13. Exclusion Code: X1.
164 Naydeck BL, Pearson JA, Ozminkowski RJ, et al. The impact of the highmark employee wellness programs on 4-year healthcare costs. J Occup Environ Med. Feb. 2008;50(2):146-56. Exclusion Code: X3. [pmid: 18301171].
165 Neuhaus M, Healy GN, Dunstan DW, et al. Workplace sitting and height-adjustable workstations: a randomized controlled trial. Am J Prev Med. Jan. 2014;46(1):30-40. Exclusion Code: X3. [pmid: 24355669].
166 Nowack KM, Schnall P, Melamed S, et al. Screening and management of the workplace for CVD risk. Occup Med. Jan-Mar. 2000;15(1):231-56. Exclusion Code: X1. [pmid: 10702088].
167 Nurminen E, Malmivaara A, Ilmarinen J, et al. Effectiveness of a worksite exercise program with respect to perceived work ability and sick leaves among women with physical work. Scand J Work Environ Health. Apr. 2002;28(2):85-93. Exclusion Code: X3 (gray zone). [pmid: 12019592].
168 O'Brien I, Driscoll T, Ackermann B. Hearing conservation and noise management practices in professional orchestras. J Occup Environ Hyg. 2012;9(10):602-8. Exclusion Code: X3. [pmid: 22937950].
169 O'Donnell M. Studying workplace health. CMAJ. Jun. 2. 1998;158(11):1434-5. Exclusion Code: X6. [pmid: 9629104].
170 O'Donnell MP. Will classic workplace health promotion program strategies work for Medicare?. Am J Health Promot. May-Jun. 2013;27(5):iv-v. Exclusion Code: X3. [pmid: 23631478].
171 Olson R. Evaluation of COMmunity of Practice And Safety Support (COMPASS) for Home Care Workers. Oregon Health and Science University. Portland, Oregon. ClinicalTrials.gov. March. 11. 2014. 2014. Exclusion Code: X8.
172 Olson R, Elliot D, Hess J, et al. The COMmunity of Practice And Safety Support (COMPASS) Total Worker Health study among home care workers: study protocol for a randomized controlled trial. Trials. 2014;15:411. Exclusion Code: X6. [pmid: 25348013].
173 O'Malley P, Emsley H, Davis D, et al. No brawn needed. Nurs Manage. Apr. 2006;37(4):26. 8. 30 passim. Exclusion Code: X3. [pmid: 16603945].
174 Ott MG, Oberlinner C, Lang S, et al. Health and safety protection for chemical industry employees in a rotating shift system: program design and acute injury and illness experience at work. J Occup Environ Med. Feb. 2009;51(2):221-31. Exclusion Code: X6. [pmid: 19209044].
175 Ott MG, Yong M, Zober A, et al. Impact of an occupational health promotion program on subsequent illness and mortality experience. Int Arch Occup Environ Health. Dec. 2010;83(8):887-94. Exclusion Code: X3 (gray zone). [pmid: 20186547].
176 Oude Hengel KM, Blatter BM, van der Molen HF, et al. Meeting the challenges of implementing an intervention to promote work ability and health-related quality of life at construction worksites: a process evaluation. J Occup Environ Med. Dec. 2011;53(12):1483-91. Exclusion Code: X3. [pmid: 22104978].
177 Oude Hengel KM, Joling CI, Proper KI, et al. Intervention Mapping as a framework for developing an intervention at the worksite for older construction workers. Am J Health Promot. Sep-Oct. 2011;26(1):e1-10. Exclusion Code: X3. [pmid: 21879927].
178 Ozer IRA. Safety and Wellness: The Critical Connection. Occup Health Saf. 2013;82(9):75-8. Exclusion Code: X1. [pmid: 24260947].
179 Ozminkowski RJ, Ling D, Goetzel RZ, et al. Long-term impact of Johnson & Johnson's Health & Wellness Program on health care utilization and expenditures. J Occup Environ Med. Jan. 2002;44(1):21-9. Exclusion Code: X3. [pmid: 11802462].
180 Pal TM, Groothoff JW, Post D, et al. Follow-up study of workers in a nylon carpet yarn plant after remedial actions taken against a contaminated humidification system. Int Arch Occup Environ Health. Aug. 2000;73(6):376-83. Exclusion Code: X3. [pmid: 11007340].
181 Park KO, Schaffer BS, Griffin-Blake CS, et al. Effectiveness of a healthy work organization intervention: ethnic group differences. J Occup Environ Med. Jul. 2004;46(7):623-34. Exclusion Code: X3. [pmid: 15247801].
182 Parker KB, DeJoy DM, Wilson MG, et al. Application of the Environmental Assessment Tool (EAT) as a process measure for a worksite weight management intervention. J Occup Environ Med. Jan. Suppl 1. 2010;52:S42-51. Exclusion Code: X3. [pmid: 20061887].
183 Patterson RE, Kristal AR, Biener L, et al. Durability and diffusion of the nutrition intervention in the Working Well Trial. Prev Med. Sep-Oct. 1998;27(5 Pt 1):668-73. Exclusion Code: X3. [pmid: 9808797].
184 Patterson RE, Kristal AR, Glanz K, et al. Components of the working well trial intervention associated with adoption of healthful diets. Am J Prev Med. Jul-Aug. 1997;13(4):271-6. Exclusion Code: X3. [pmid: 9236963].
185 Pedersen MT, Andersen CH, Zebis MK, et al. Implementation of specific strength training among industrial laboratory technicians: long-term effects on back, neck and upper extremity pain. BMC Musculoskelet Disord. 2013;14:287. Exclusion Code: X3. [pmid: 24106771].
186 Pelletier KR. Clinical and cost outcomes of multifactorial, cardiovascular risk management interventions in worksites: a comprehensive review and analysis. J Occup Environ Med. Dec. 1997;39(12):1154-69. Exclusion Code: X6. [pmid: 9429168].
187 Peper E, Gibney KH, Wilson VE. Group training with healthy computing practices to prevent repetitive strain injury (RSI): a preliminary study. Appl Psychophysiol Biofeedback. Dec. 2004;29(4):279-87. Exclusion Code: X3. [pmid: 15707257].
188 Peters KK, Carlson JG. Worksite stress management with high-risk maintenance workers: A controlled study. International journal of stress management. 01. 01. 1999;6(1):21-44. Exclusion Code: X3 (gray zone).
189 Pillastrini P, Mugnai R, Bertozzi L, et al. Effectiveness of an at-work exercise program in the prevention and management of neck and low back complaints in nursery school teachers. Ind Health. Aug. 2009;47(4):349-54. Exclusion Code: X3. [pmid: 19672007].
190 Pipe TB, Buchda VL, Launder S, et al. Building personal and professional resources of resilience and agility in the healthcare workplace. Stress Health. Feb. 2012;28(1):11-22. Exclusion Code: X3. [pmid: 22259154].
191 Poole K, Kumpfer K, Pett M. The impact of an incentive-based worksite health promotion program on modifiable health risk factors. Am J Health Promot. Sep-Oct. 2001;16(1):21-6. ii. Exclusion Code: X3. [pmid: 11575052].
192 Poston WS, Haddock CK, Jahnke SA, et al. An examination of the benefits of health promotion programs for the national fire service. BMC Public Health. 2013;13:805. Exclusion Code: X3. [pmid: 24007391].
193 Prochaska JO, Butterworth S, Redding CA, et al. Initial efficacy of MI, TTM tailoring and HRI's with multiple behaviors for employee health promotion. Prev Med. Mar. 2008;46(3):226-31. Exclusion Code: X3. [pmid: 18155287].
194 Pronk NP. Integrated worker health protection and promotion programs: overview and perspectives on health and economic outcomes. J Occup Environ Med. Dec. 2013;55(12 Suppl):S30-7. Exclusion Code: X1. [pmid: 24284747].
195 Pronk NP, Katz AS, Lowry M, et al. Reducing occupational sitting time and improving worker health: the Take-a-Stand Project, 2011. Prev Chronic Dis. 2012;9:E154. Exclusion Code: X3. [pmid: 23057991].
196 Pruitt RH. Effectiveness and cost efficiency of interventions in health promotion. J Adv Nurs. Aug. 1992;17(8):926-32. Exclusion Code: X3. [pmid: 1506543].
197 Punnett L, Cherniack M, Henning R, et al. A conceptual framework for integrating workplace health promotion and occupational ergonomics programs. Public Health Rep. Jul-Aug. Suppl 1. 2009;124:16-25. Exclusion Code: X1. [pmid: 19618803].
198 Rahe RH, Taylor CB, Tolles RL, et al. A novel stress and coping workplace program reduces illness and healthcare utilization. Psychosom Med. Mar-Apr. 2002;64(2):278-86. Exclusion Code: X3. [pmid: 11914444].
199 Rasmussen CD, Holtermann A, Mortensen OS, et al. Prevention of low back pain and its consequences among nurses' aides in elderly care: a stepped-wedge multi-faceted cluster-randomized controlled trial. BMC Public Health. 2013:1088. Exclusion Code: X6. [pmid: 24261985].
200 Rasmussen CD, Jorgensen MB, Carneiro IG, et al. Participation of Danish and immigrant cleaners in a 1-year worksite intervention preventing physical deterioration. Ergonomics. 2012;55(2):256-64. Exclusion Code: X6. [pmid: 21846286].
201 Ribeiro SB, Wagmacker DS, de Oliveira LB. Evaluation of the exercise intervention with the “Back School” education program in a Brazilian company of cigars: a case study. Work. Suppl 1. 2012;41:2412-6. Exclusion Code: X3. [pmid: 22317078].
202 Richmond R, Kehoe L, Heather N, et al. Evaluation of a workplace brief intervention for excessive alcohol consumption: the workscreen project. Prev Med. Jan. 2000;30(1):51-63. Exclusion Code: X3. [pmid: 10642460].
203 Rivilis I, Cole DC, Frazer MB, et al. Evaluation of a participatory ergonomic intervention aimed at improving musculoskeletal health. Am J Ind Med. Oct. 2006;49(10):801-10. Exclusion Code: X3. [pmid: 16960887].
204 Ruotsalainen Jani H, Verbeek Jos H, Mariné A, et al. Preventing occupational stress in healthcare workers. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2014. Exclusion Code: X1.
205 Saksvik PO, Nytro K. Improving subjective health and reducing absenteeism in a natural work life-intervention. Scand J Psychol. Feb. 2001;42(1):17-24. Exclusion Code: X3. [pmid: 11273575].
206 Scott LD, Hofmeister N, Rogness N, et al. Implementing a fatigue countermeasures program for nurses: a focus group analysis. J Nurs Adm. May. 2010;40(5):233-40. Exclusion Code: X3. [pmid: 20431458].
207 Segui-Gomez M. Evaluating worksite-based interventions that promote safety belt use. Am J Prev Med. May. 2000;18(4 Suppl):11-22. Exclusion Code: X6. [pmid: 10793276].
208 Shaw WS, Robertson MM, Pransky G, et al. Training to optimize the response of supervisors to work injuries--needs assessment, design, and evaluation. AAOHN J. May. 2006;54(5):226-35. Exclusion Code: X3. [pmid: 16729659].
209 Shephard RJ. Twelve years experience of a fitness program for the salaried employees of a Toronto life assurance company. Am J Health Promot. Mar-Apr. 1992;6(4):292-301. Exclusion Code: X3. [pmid: 10148753].
210 Shimazu A, Umanodan R, Schaufeli WB. Effects of a brief worksite stress management program on coping skills, psychological distress and physical complaints: a controlled trial. Int Arch Occup Environ Health. Oct. 2006;80(1):60-9. Exclusion Code: X3. [pmid: 16633813].
211 Silberman J, Schwartz S, Giuseffi DL, et al. Reductions in employee productivity impairment observed after implementation of web-based worksite health promotion programs. J Occup Environ Med. Dec. 2011;53(12):1404-12. Exclusion Code: X6. [pmid: 22173284].
212 Simpson JM, Oldenburg B, Owen N, et al. The Australian National Workplace Health Project: design and baseline findings. Prev Med. Sep. 2000;31(3):249-60. Exclusion Code: X3. [pmid: 10964639].
213 Smith K. Evaluation of a stretching program to increase worker flexibility. Workplace Health Saf. Aug. 2013;61(8):329-32. Exclusion Code: X3. [pmid: 23930658].
214 Sorensen G, Project A. Integrated Approaches to Improving the Health and Safety of Health Care Workers. Harvard School of Public Health. Boston, MA. ClinicalTrials.gov. March. 19. 2013. 2013. Exclusion Code: X8.
215 Sorensen G, Barbeau EM. Integrating occupational health, safety and worksite health promotion: opportunities for research and practice. Med Lav. Mar-Apr. 2006;97(2):240-57. Exclusion Code: X1. [pmid: 17017356].
216 Sorensen G, Glasgow RE, Topor M, et al. Worksite characteristics and changes in worksite tobacco-control initiatives. Results from the COMMIT study. J Occup Environ Med. Jun. 1997;39(6):520-6. Exclusion Code: X3. [pmid: 9211209].
217 Sorensen G, McLellan D, Dennerlein JT, et al. Integration of health protection and health promotion: rationale, indicators, and metrics. J Occup Environ Med. Dec. 2013;55(12 Suppl):S12-8. Exclusion Code: X1. [pmid: 24284762].
218 Sorensen G, Stoddard A, Quintiliani L, et al. Tobacco use cessation and weight management among motor freight workers: results of the gear up for health study. Cancer Causes Control. Dec. 2010;21(12):2113-22. Exclusion Code: X3. [pmid: 20725775].
219 Spekle EM, Heinrich J, Hoozemans MJ, et al. The cost-effectiveness of the RSI QuickScan intervention programme for computer workers: Results of an economic evaluation alongside a randomised controlled trial. BMC Musculoskelet Disord. 2010;11:259. Exclusion Code: X3. [pmid: 21070621].
220 Stave GM. The Glaxo Wellcome health promotion program: the contract for health and wellness. Am J Health Promot. May-Jun. 2001;15(5):358-60. Exclusion Code: X1. [pmid: 11502018].
221 Steenstra IA, Knol DL, Bongers PM, et al. What works best for whom? An exploratory, subgroup analysis in a randomized, controlled trial on the effectiveness of a workplace intervention in low back pain patients on return to work. Spine (Phila Pa 1976). May. 20. 2009;34(12):1243-9. Exclusion Code: X3. [pmid: 19412140].
222 Stein AD, Shakour SK, Zuidema RA. Financial incentives, participation in employer-sponsored health promotion, and changes in employee health and productivity: HealthPlus Health Quotient Program. J Occup Environ Med. Dec. 2000;42(12):1148-55. Exclusion Code: X3. [pmid: 11125677].
223 Stokols D, Pelletier KR, Fielding JE. The ecology of work and health: Research and policy directions for the promotion of employee health. Health Educ Q. 1996;23(2):137-58. Exclusion Code: X1. [pmid: 8744869].
224 Strijk JE, Proper KI, van der Beek AJ, et al. A worksite vitality intervention to improve older workers' lifestyle and vitality-related outcomes: results of a randomised controlled trial. J Epidemiol Community Health. Nov. 2012;66(11):1071-8. Exclusion Code: X3. [pmid: 22268128].
225 Strycker LA, Foster LS, Pettigrew L, et al. Steering Committee enhancements on health promotion program delivery. Am J Health Promot. Jul-Aug. 1997;11(6):437-40. Exclusion Code: X3. [pmid: 10168265].
226 Su SB, Wang JN, Lu CW, et al. Reducing urinary tract infections among female clean room workers. J Womens Health (Larchmt). Sep. 2006;15(7):870-6. Exclusion Code: X3. [pmid: 16999643].
227 Sun J, Buys N, Wang X. Effectiveness of a workplace-based intervention program to promote mental health among employees in privately owned enterprises in China. Popul Health Manag. Dec. 2013;16(6):406-14. Exclusion Code: X5. [pmid: 23672231].
228 Sundstrup E, Jakobsen MD, Andersen CH, et al. Participatory ergonomic intervention versus strength training on chronic pain and work disability in slaughterhouse workers: study protocol for a single-blind, randomized controlled trial. BMC Musculoskelet Disord. 2013;14:67. Exclusion Code: X3. [pmid: 23433448].
229 Swartz AM, Rote AE, Welch WA, et al. Prompts to disrupt sitting time and increase physical activity at work, 2011-2012. Prev Chronic Dis. 2014;11:E73. Exclusion Code: X3. [pmid: 24784909].
230 Takao S, Tsutsumi A, Nishiuchi K, et al. Effects of the job stress education for supervisors on psychological distress and job performance among their immediate subordinates: a supervisor-based randomized controlled trial. J Occup Health. Nov. 2006;48(6):494-503. Exclusion Code: X3. [pmid: 17179643].
231 Talvi AI, Jarvisalo JO, Knuts LR. A health promotion programme for oil refinery employees: changes of health promotion needs observed at three years. Occup Med (Lond). Feb. 1999;49(2):93-101. Exclusion Code: X3. [pmid: 10436561].
232 Tessaro IA, Taylor S, Belton L, et al. Adapting a natural (lay) helpers model of change for worksite health promotion for women. Health Educ Res. Oct. 2000;15(5):603-14. Exclusion Code: X3. [pmid: 11184219].
233 Tilley BC, Vernon SW, Myers R, et al. Planning the next step. A screening promotion and nutrition intervention trial in the work site. Ann N Y Acad Sci. Sep. 30. 1995;768:296-9. Exclusion Code: X3. [pmid: 8526371].
234 Torp S, Moen BE. The effects of occupational health and safety management on work environment and health: a prospective study. Appl Ergon. Nov. 2006;37(6):775-83. Exclusion Code: X3. [pmid: 16380071].
235 Toska M, Behrendt D, Erzberger M. Prävention psychischer Gesundheit als Teilaufgabe eines ganzheitlichen betrieblichen Gesundheitsmanagements. Prevention of mental health as part of a holistic health management. Psychiatr Prax. 2015;42(Suppl 1):S39-S43. Exclusion Code: X7. [pmid: 26135278].
236 Tsai HH, Yeh CY, Su CT, et al. The effects of exercise program on burnout and metabolic syndrome components in banking and insurance workers. Ind Health. 2013;51(3):336-46. Exclusion Code: X5. [pmid: 23518604].
237 Tsutsumi A, Nagami M, Yoshikawa T, et al. Participatory intervention for workplace improvements on mental health and job performance among blue-collar workers: a cluster randomized controlled trial. J Occup Environ Med. May. 2009;51(5):554-63. Exclusion Code: X3. [pmid: 19365287].
238 Unterbrink T, Pfeifer R, Krippeit L, et al. A manual-based group program to improve mental health: what kind of teachers are interested and who stands to benefit from this program?. Int Arch Occup Environ Health. Jan. 2014;87(1):21-8. Exclusion Code: X3. [pmid: 23212894].
239 Vainio H, Stayner L. Can health promotion at the workplace help prevent cancer?. Scand J Work Environ Health. Jun. 2002;28(3):137-9. Exclusion Code: X1. [pmid: 12109552].
240 van Berkel J, Boot CR, Proper KI, et al. Effectiveness of a worksite mindfulness-related multi-component health promotion intervention on work engagement and mental health: results of a randomized controlled trial. PLoS One. 2014;9(1):e84118. Exclusion Code: X3 (gray zone). [pmid: 24489648].
241 van Berkel J, Boot CR, Proper KI, et al. Effectiveness of a worksite mindfulness-based multi-component intervention on lifestyle behaviors. Int J Behav Nutr Phys Act. 2014;11:9. Exclusion Code: X3 (gray zone). [pmid: 24467802].
242 van der Molen HF, Frings-Dresen MH, Sluiter JK. The longitudinal relationship between the use of ergonomic measures and the incidence of low back complaints. Am J Ind Med. Jun. 2010;53(6):635-40. Exclusion Code: X3. [pmid: 20340111].
243 van der Molen HF, Hoonakker PL, Lehtola MM, et al. Writing a Cochrane systematic review on preventive interventions to improve safety: the case of the construction industry. Med Lav. Jul-Aug. 2009;100(4):258-67. Exclusion Code: X3. [pmid: 19764181].
244 van Dongen JM, Strijk JE, Proper KI, et al. A cost-effectiveness and return-on-investment analysis of a worksite vitality intervention among older hospital workers: results of a randomized controlled trial. J Occup Environ Med. Mar. 2013;55(3):337-46. Exclusion Code: X3. [pmid: 23439274].
245 van Holland BJ, de Boer MR, Brouwer S, et al. Sustained employability of workers in a production environment: design of a stepped wedge trial to evaluate effectiveness and cost-benefit of the POSE program. BMC Public Health. 2012;12:1003. Exclusion Code: X6. [pmid: 23164366].
246 Verweij LM, Proper KI, Weel AN, et al. Design of the Balance@Work project: systematic development, evaluation and implementation of an occupational health guideline aimed at the prevention of weight gain among employees. BMC Public Health. 2009;9:461. Exclusion Code: X3. [pmid: 20003405].
247 Vingard E, Blomkvist V, Rosenblad A, et al. A physical fitness programme during paid working hours - impact on health and work ability among women working in the social service sector: a three year follow up study. Work. 2009;34(3):339-44. Exclusion Code: X3. [pmid: 20037249].
248 Viswanathan M, Kraschnewski J, Nishikawa B, et al. Outcomes of Community Health Worker Interventions. (Prepared by RTI International–University of North Carolina Evidence-based Practice Center under Contract No. 290-2007-10056-I). Rockville, MD. Agency for Healthcare Research and Quality. Jun. 2009. Exclusion Code: X1.
249 von Thiele Schwarz U, Hasson H. Employee self-rated productivity and objective organizational production levels: effects of worksite health interventions involving reduced work hours and physical exercise. J Occup Environ Med. Aug. 2011;53(8):838-44. Exclusion Code: X3. [pmid: 21785369].
250 von Thiele Schwarz U, Lindfors P, Lundberg U. Health-related effects of worksite interventions involving physical exercise and reduced workhours. Scand J Work Environ Health. Jun. 2008;34(3):179-88. Exclusion Code: X3. [pmid: 18728907].
251 Vuori J, Toppinen-Tanner S, Mutanen P. Effects of resource-building group intervention on career management and mental health in work organizations: randomized controlled field trial. J Appl Psychol. Mar. 2012;97(2):273-86. Exclusion Code: X3. [pmid: 21942405].
252 Wahlstedt KG, Nygard CH, Kemmlert K, et al. The effects of a change in work organization upon the work environment and musculoskeletal symptoms among letter carriers. Int J Occup Saf Ergon. 2000;6(2):237-55. Exclusion Code: X3. [pmid: 10927669].
253 Waite PJ, Richardson GE. Determining the efficacy of resiliency training in the work site. J Allied Health. Fall. 2004;33(3):178-83. Exclusion Code: X3. [pmid: 15503750].
254 Walden CM, Still AT, Zinn B, et al. Perinatal effects of a pregnancy wellness program in the workplace. MCN Am J Matern Child Nurs. Nov-Dec. 1996;21(6):288-93. Exclusion Code: X3. [pmid: 8952282].
255 Wang PC, Harrison RJ, Yu F, et al. Follow-up of neck and shoulder pain among sewing machine operators: The Los Angeles garment study. Am J Ind Med. Apr. 2010;53(4):352-60. Exclusion Code: X3. [pmid: 20017187].
256 Ward JA, de Castro AB, Tsai JH, et al. An injury prevention strategy for teen restaurant workers. Washington State's ProSafety project. AAOHN J. Feb. 2010;58(2):57-65. quiz -7. Exclusion Code: X2. [pmid: 20180503].
257 Weber S. Healthcare ergonomics, part 2. J Am Acad Nurse Pract. Feb. 2006;18(2):43-4. Exclusion Code: X1. [pmid: 16460408].
258 Wergeland EL, Veiersted B, Ingre M, et al. A shorter workday as a means of reducing the occurrence of musculoskeletal disorders. Scand J Work Environ Health. Feb. 2003;29(1):27-34. Exclusion Code: X3. [pmid: 12630433].
259 Whysall Z, Haslam C, Haslam R. A stage of change approach to reducing occupational ill health. Prev Med. Nov. 2006;43(5):422-8. Exclusion Code: X3. [pmid: 16908057].
260 Yassi A, Lockhart K, Sykes M, et al. Effectiveness of joint health and safety committees: a realist review. Am J Ind Med. Apr. 2013;56(4):424-38. Exclusion Code: X6. [pmid: 23192461].
261 Yoshikawa T, Ogami A, Muto T. Evaluation of participatory training in managing mental health for supervisory employees in the financial industry. J Hum Ergol (Tokyo). Dec. 2013;42(1-2):45-54. Exclusion Code: X6. [pmid: 25647945].
262 Zarges T, Giles B. Prevention through Design (PtD). J Safety Res. 2008;39(2):123-6. Exclusion Code: X1. [pmid: 18454951].